# Discussion

## Overview

Effective health care relies on the three legs of physician clinical experience, patients' knowledge of their specific health situations and preferences, and an evidence base. Together, these three components provide the input for medical decisions. In the absence of a clear, unambiguous path to follow, patients are best served by shared decisionmaking, which requires clinicians to provide the best available information against which patients can weigh their preferences and risk tolerance.

The decisions around discontinuation of DMT treatment are extremely personal and individual. It is hard to envision ever having enough information to cover all contingencies. Providers and MS patients who have followed a prolonged DMT treatment plan have little information to guide decisions regarding discontinuing DMT. Thus, personal preferences about risks take on more weight.

No literature directly compared continuing versus discontinuing DMT in comparable populations. Only sparse information was available to address one part of the decisionmaking picture faced by providers and patients, long-term benefits and harms. Of 27 unique studies identified, only 16 provided sufficient information to adequately assess outcomes and risk of bias. As summarized in Table 14, low-strength evidence showed an increased all-cause mortality for patients who started interferon beta 1b 2 years earlier than the comparators, but no differences between treated and comparator groups in time to progression to secondary progressive MS (SPMS) (as measured by sustained Expanded Disability Status Scale (EDSS) greater than 6). Similarly, overall long-term harms were found to be no different than short-term harms. Low-strength evidence implies low confidence in the findings and the expectation that future research could change the findings. Evidence is insufficient to assess long-term benefits and harms for all other patient populations, type of DMT, or outcome.

Table 14 Summary of KQ1 findings with sufficient evidence

Outcomes | DMTs Used in Long-Term Studies Assessing Discontinuing or Continuing DMTs | Number of Studies Number of Participants | Findings | Strength of Evidence
All-Cause Survival | Interferon beta 1b | 1 study35 n=366 RRMS | All-cause mortality: 250 mg arm vs. placebo – HR 0.532 (98% CI, 0.31 to 0.90) 50 mg arm vs. placebo – HR 0.54 (95% CI, 0.32 to 0.92) favors treatment | Low (moderate risk of bias, unknown consistency)
Time to Progression to SPMS | Mixed Interferon | 1 study40 n=2656 RRMS | No difference from contemporary or historical control | Low (moderate risk of bias, unknown consistency)
Overall Harms | Interferon, glatiramer acetate, teriflunomide | 3 studies35,38,59 n=746 RRMS interferon beta 1b, 16y; 46 RRMS glatiramer acetate, 22 y; 131 RRMS, 16 SPMS, teriflunomide, 8.5y | Long-term harms not different than short term (qualitative finding) | Low (high risk of bias, consistent, indeterminate precision)

DMT =disease-modifying treatment; HR = hazard ratio; KQ = Key Question; RRMS = relapsing remitting multiple sclerosis; SPMS = secondary-progressive multiple sclerosis; y = year

The current literature did not examine whether long-term benefits for DMTs remain after a patient converts to SPMS. Such a finding would refute the practice of discontinuing current DMTs once a patient converts. However, given that mitoxantrone (with a maximum lifetime dose limit) is the only FDA-approved DMT for SPMS, there is little to suggest a long-term study past conversion to SPMS would be constructive. This assumption is supported by a recent systematic review and meta-analysis of 3082 SPMS patients, which found interferon beta did not reduce disability progression, and while there was a slight reduction in number of patients who had relapses during the 3 years, more treated than placebo patients dropped out due to adverse events.127

For the special cases of natalizumab and planned pregnancy discontinuations, evidence was insufficient to answer whether discontinuation is problem-free. Evidence from eight studies was insufficient to answer whether rebound due to discontinuing natalizumab exists. Studies lacked quantitative definitions of rebound, were high risk of bias, small sample sizes, and potential plausible confounders for post-natalizumab annualized relapse rates. Similarly, evidence from 12 studies was insufficient to address risks of fetal exposure to DMT during pregnancy in women with MS or the risks to the mother for the drug holiday due to study high risk of bias and small sample sizes. Further, women who discontinued DMT to attempt pregnancy who didn't conceive were not observed as comparison groups, nor were data gathered or grouped by time on drug holiday prior to and during pregnancy.

Harms from long-term DMT use, as is true for many treatments and medical conditions, is poorly reported in the literature. The low-strength evidence showing long-term harms to be generally similar to short-term may very well be upset by improved tracking and reporting. For example, a November, 2014 FDA Drug Safety Communication reported the first confirmed fatal case of PML for an MS patient using dimethyl fumarate (Tecfidera).128 The patient had used dimethyl fumarate for 4 years.

In the absence of evidence, providers and patients are left with little to inform their preferences and guide their decisions regarding if or when to discontinue treatments. The majority of included studies reported reasons for patients discontinuing treatments, but the information provided was without detail. Adverse events and inefficacy or progression of disability were two expected categories. Other possible reasons for discontinuation, such as a patient's desire to try alternative medicine approaches, perceived risk of long-term use, or financial concerns such as out of pocket costs or loss of insurance, are not noted. The “patient decision” category for discontinuing was consistently unexplored.

Key Question (KQ) 2 aimed to delve into what is known about patient and provider preferences. While the literature was sparse, with only 28 studies available to populate the conceptual map provided in Figure 1, each of the three major conceptual areas was at least partially represented. No study directly asked why people are reluctant to discontinue when treatment seems no longer effective, but taken as a whole the literature set provides some insight.

Overall, one can weave together the general themes found in the KQ2 literature. Admittedly, physicians cannot reliably predict patient preferences for shared decisionmaking and often perceive the relative importance of health status or acceptable risks differently. However, when it comes to the decision to discontinue DMT, the patient drives the decision, and this preference and role are generally unchallenged by the physician. In some DMT discontinuations, the balance of shared decisionmaking may shift to discordance between the physician and patient, with the physician deferring to patient preferences for continuing treatment or not. The quantified preferences work by Prosser and colleagues101 illustrates a paradox, where patients are less likely to prefer DMT during the early course of the disease, when disease symptoms are lower than the side effects of the DMT, and more likely to use it at later stages of the disease when the side effects are less than disease symptoms. This behavior is counter to the hypothesis under which DMTs are assumed to work, which is by reducing relapses early in the disease course to prevent or delay disease progression. Without more solid evidence for the long-term net benefits, or the thresholds at which treatment is no longer effective in preventing disease progression, the decision to discontinue treatment remains preference sensitive.

The preferences literature underscores the complexity of the topic and the processes underlying decisionmaking. Both rational and nonrational (such as heuristics) processes came into play, and neither had primacy over the other. Cost was a factor in both self-report and through observation of purchasing behavior. Cognitive deficits impairing decisional capacity may be overcome with adequate cuing. Information is a necessary component of decisionmaking, yet nonrational factors can influence what information is sought at what time.

Preferences, values, and beliefs are highly variable, may change over time, and are linked to the nature of the patients' relationships with their doctors. There may well be differences based on age, sex, race, class, and other factors. A patient's preference position between “treat my MS at any cost/comfort from knowledge of receiving treatment” and “need strong evidence that the medication will help and be worth the cost/side effects” may change over time and as the disease changes.

Changing perceptions regarding health states was common across different parts of the intrapersonal literature. Risk perceptions and quantified preferences (which are risk-based as well) both suggested that people with longer MS experience assigned higher values to, or viewed as less serious, disabled states. This is a finding consistent with other research into how people value different health states. Many people overestimate their aversion to hypothetical states of disability and hence eliminate treatment options that might lead to such disability, especially if it could be long-term.129-132 The hypothetical disutilities for these states are consistently higher than for those actually experiencing the state.

## Issues

Several challenges impede the gathering of evidence to inform decisions to discontinue DMTs. First, the potential differential effectiveness of DMTs for different patient subpopulations is unclear, due both to lack of studies examining the questions as well as the use of unsatisfactory study designs. Whether DMTs for clinically isolated syndrome (CIS) patients is effective remains an open question. DMTs may offer little benefit in exchange for side effects and potential harms for patients with a benign MS course. Conversely, who is at risk of worsened disease activity (such as a rebound effect or overshoot) when DMTs are discontinued, possibly prematurely? We cannot currently predict early or benign disease courses.

Second, similar to determining which CIS patients will convert to MS, or which MS patients will have a benign disease course without use of DMTs, the transition from relapsing-remitting MS (RRMS) to SPMS is difficult to ascertain and therefore poses challenges in the decision to discontinue treatment. Clear biomarkers do not exist, and neither do distinct boundaries for the transition. Currently, EDSS changes, or a score of 6 or 7, and clinical judgment are generally used. Furthermore, some patients with RRMS never transition to a clear secondary progressive phase. Since relapses tend to decrease in frequency with advancing age (they are rare after the sixth decade of life, and very rare after the seventh decade), the problem arises in determining whether a patient's lack of relapses is due to ongoing DMT or to the natural history of the disease. For example, consider a 75-year old patient who developed RRMS at age 30, has been taking DMT since 1994, has had no relapses or new MRI lesions since 1996, and has shown no evidence of secondary progression (stable EDSS). Is the lack of relapses due to ongoing DMT use, or has this patient's MS reached the stage where the risk of relapse is passed, yet there is no ongoing neurologic deterioration beyond what would be expected in normal aging (sometimes referred to as “burned out” MS)? Is it safe to discontinue DMT in such patients? Adequate data to answer this question are not yet available.

This observation leads to the third major challenge, measuring disability. The EDSS is the most commonly used scale in research, in part because it is the longest standing. Because the EDSS is largely driven by mobility assessment, available research is generally silent on potential benefits of DMT other than ambulation, such as upper limb function and cognitive impairments. Other validated measures of health status in MS that incorporate more function domains include the MSQOL-54, the Functional Assessment of Multiple Sclerosis (FAMS), and the Multiple sclerosis Quality-of-Life Inventory (MSQLI).133-135 Since the EDSS is often used as a validation standard, cross-walks between the EDSS and other scales are already somewhat established to assist with aggregating findings across studies for mobility disability and possibly inform transitions to SPMS. However, as seen in KQ2, given that people with MS can value health domains differently than physicians (or perhaps researchers),119 the broader range of disability assessment should be pursued regardless of any potential limitations comparing results with studies that used the EDSS exclusively.

Without adequate measures of quality of life, balancing the benefits of treatments against harms becomes challenging, especially across different drug regimens. DMTs are not benign with regard to side effects and risk profiles. The degree to which quality of life benefits of treatment are offset by quality of life decreases due to side effects and risk profiles is important. Such research is often done within the context of cost-benefit analysis,9,136-147 a methodology with its own set of strengths and limitations.

Much remains to be done to understand patient preferences. Emerging but useful information was available to explore KQ2, but no study directly asked the question about preference for discontinuing treatment or explored why patients may be unwilling to discontinue even when treatment no longer appears effective. Lonergan and colleagues approached the question tangentially, asking physicians about how they counsel patients when considering discontinuation.123 Providers who are involved with such counseling sessions would also benefit from research that separates understanding of preferences, which may be clear to the patient, and the mixed feelings such preferences may generate, ranging from fear or grief related to “giving up” on the disease to relief for no longer carrying the burden of DMTs.

Newly approved drugs, such as fingolimod, and drugs in the development pipeline are emphasizing oral administration, which may improve medication uptake and adherence to treatment programs. Self-injection can be a deterrent to patients with MS starting injectable DMTs and “shot-fatigue” is a significant factor for adherence. Oral medications will certainly have implications for preferences for continuing and discontinuing DMTs.

## Future Research

Since only three areas of evidence for KQ1 were sufficient to provide answers with low strength of evidence, essentially all questions related to KQ1 would benefit from further study. The utility of studies for estimating long-term treatment effectiveness in MS can be improved by using prospective, population-based designs with appropriate comparators and standardized data collection methods. Study cohorts must be better characterized with respect to demographic and clinical characteristics, as well as other factors that may influence outcome such as socioeconomic status, access to care, health behaviors, and comorbidities. Near-complete patient retention with regularly scheduled patient visits is also necessary. The ability to account for treatment effects would improve with better models to predict disability outcomes in MS, including disentangling the young versus old from the new versus long-term disease presence, since the two overlap. Techniques to adjust for selection bias such as regression analysis or propensity scores are more easily accomplished with rich datasets. With regard to the question of discontinuing for pregnancy, appropriate comparison groups need to include women who discontinued DMT to attempt pregnancy but didn't conceive. Since the pharmaceutical industry would not benefit from strong comparator studies focusing on treatment discontinuation, other funding sources will need to be identified.

Some current efforts to improve longer-term research do exist; for example, the prospective, 5 year OPT-Up study.148 While more geared toward initial treatment and switching choices, understanding discontinuation within that context is one of the study goals. Another prospective 10-year observational study based on the United Kingdom's MS risk sharing scheme is evaluating the effectiveness of the first DMTs, interferon and glatiramer acetate. After NICE recommended against DMTs in 2002,^149^ a pricing scheme was negotiated with participating pharmaceutical companies whereby the drug prices would be reduced if patient outcomes were lower than expected,150 thus the United Kingdom National Health Service and the pharmaceutical companies shared the financial risk for cost-effective treatment. The initial 2-year results published in 2009 found patient outcomes were worse than predicted.151 However, results were controversial; an independent group that reviewed the data concluded that both the control dataset and analysis model selected when setting up the risk-sharing scheme, had intrinsic flaws.152 Four-, 6-, and 8-year data have been collected and are being analyzed using an updated modeling methodology. This research initiative should help inform the long-term benefits of these injectable treatments and may suggest improvements to current MS registries or methods, making analysis of such registries more fruitful.

KQ2 covered a broad array of relevant topics, and investigator-driven research remains a likely source for innovative and interesting approaches to continued exploration. The AutoMS project, an international consortium of six European locations and Australia, was formed in 2010 to explore MS patient preferences for shared decisionmaking.153 Confirming the generalizability of their findings to the United States would be beneficial. Also useful would be well-designed qualitative and survey research, perhaps using mixed-methods approaches, aimed at exploring why and under what circumstances a patient might seek to terminate treatment, and why people may be reluctant to discontinue when treatment appears no longer effective.

Attention to areas such as implementation science and quality improvement, which combined are often referred to as healthcare improvement science, should be included in the future of MS research and the improvement of MS treatment decision and outcomes. Such areas may contribute systems-level factors to DMT selection and adherence, and to the successful implementation of shared decisionmaking.

## Limitations

Literature on preferences is not indexed to permit easy identification of relevant articles. Search strategies to capture the diffuse literature used natural language as keywords. While we tested multiple terms before settling on the final algorithm, relevant articles were likely missed, and thus the included literature set must be viewed as comprehensive but not exhaustive. Likewise, setting the review scope to exclude adherence literature – as adherence by definition connotes a decision to continue DMT use – may have precluded some relevant literature examining lack of adherence as a de facto decision to discontinue use.