# Risk of Bias for Included KQ1 Studies

Appendix Table D1 KQ1 risk of bias for articles in analytic study set

Study Country Funding | Type of Study | Overall Risk of Bias Assessment | Rationale
Glatiramer Acetate
Debouverie, 2007^1^ France Not reported | Prospective observational | High | Unclear inclusion criteria (25% “contraindication to interferon beta” not defined), unreliable outcome measure (relapse per MD), numerous unblinded outcomes assessors, no assessment of impact of attrition
Ford, 2010^2^ (Johnson) United States Industry | Prospective open-label | High | Attrition, unblinded outcomes assessment
Miller, 2008^3^ United States Industry | Followup of compassionate use | High | Attrition, no assessment of impact of attrition, small sample size, unequal length of followup, competing exposures not described
Teriflunomide
Confavreux, 2012^4^ N America, Europe Industry | Open-label extension of RCT: randomized placebo group | High | Attrition, no assessment of impact of attrition, reporting bias (Table 2, Fig. 2 by extension-phase drug only)
IFNβ1a
Uitdehaag, 2011^5^ (PRISMS, Gold) 22 centers: Europe, Canada, Australia Not funded | Retrospective long-term followup of open-label extension of mixed design | High | High attrition, no assessment of impact of attrition, competing exposures not described, potential for recall bias (relapse outcome), small sample, post-hoc analyses
IFNβ1b
Bencsik, 2006^6^ Hungary Not reported | Prospective cohort | High | Attrition, small/insufficient sample size, unblinded outcomes assessment, no comparator
Carmona, 2008^7^ Spain Not reported | Prospective cohort with historical control | High | Unclear selection of historical controls, insufficient reporting of baseline characteristics, attrition
Goodin, 2012^8^ Reder, 2010^9^ North America Industry | Long-term followup of RCT | Moderate | Competing exposures not described or included in the analysis
Kappos, 2009^10^ N America, Europe Industry | Open-label extension of RCT | High | Attrition, no assessment of impact of attrition
Rio, 2007^11^ Spain Not reported | Post-marketing study | High | Attrition, baseline differences in case-mix between groups were not accounted for in the analysis.
Interferon beta mixed
Patti, 2006^12^ Italy, 2 sites Reported not industry | Open-label observational | High | Attrition, no assessment of impact of attrition, no attempt to balance differences in baseline MS characteristics across groups, inconsistent reporting (text vs. Table 1), unblinded outcomes assessment
Portaccio, 2008^13^ Italy Not reported | Retrospective cohort | High | Unequal length of treatment, unequal length of followup, lack of detail about variables used in Cox models and attempts to deal with baseline differences in MS characteristics, questionable control of confounding factors in analysis
Shirani, 2012^14^ Canada Government | Retrospective cohort (database) with historical and contemporary control groups | Moderate | Lack of detail in describing the intervention (all IFNβs considered as one therapy, breaks in treatment ignored), competing exposures not described, unblinded assessors, sample selection (limits of database capture).
Mixed Drugs
Tedeholm, 2013^15^ Sweden Government | Retrospective cohort (databased) with historical control group | High | Selection bias, lack of generalizability of contemporary treated group to population-based historical control, probable treatment by indication
Rio, 2005^16^ Spain Not reported | Open-label nonrandomized post-marketing observational | High | Baseline differences in case-mix between groups were not accounted for in the analysis, unequal length of treatment across groups, unequal length of followup, incomplete and unclear tracking of patients over time (table values conflict with text), competing exposures not described, attrition
Bergamaschi, 2012^17^ Italy Unfunded | Retrospective cohort (database) categorized by Bayesian modeling for risk factors | Unclear | Unclear if modeling accounted for treatment by indication. Nearly 30% of the remaining registry cohort was excluded because they had not been treated, or had not been treated with a first-line therapy, or had also been treated with a second-line therapy.

Appendix Table D2 KQ1 risk of bias for articles in natalizumab set

Study Country Funding | Type of Study | Overall Risk of Bias Assessment | Rationale
ARR Outcomes
Jokubaitis, 2014^18^ Australia and international Government, non-profit, industry | Retrospective cohort | High | Retrospective, large sample with lack of individual-level outcome assessment, relapse severity measured by proxy (relapse treatment: ambulatory, hospitalization or none)
Havla, 2013^19^ Germany Not reported | Retrospective cohort | High | Retrospective, inadequate sample size, outcome (rebound definition) not clearly specified, confounding variables not addressed (reason for interruption, prior treatment)
Havla, 2011^20^ Germany Not reported | Prospective cohort | High | Inadequate sample size, outcome (rebound definition) not clearly specified, confounding variables not addressed (reason for interruption), prior treatment
Kaufman 2011^21^ United States Not funded | Retrospective chart review | High | Retrospective, outcome (rebound definition) not clearly specified, confounding variables not addressed (reason for interruption, prior treatment)
Kerbrat 2011^22^ France Not reported | Retrospective chart review | High | Retrospective, outcome (rebound definition) not clearly specified, attrition in MRI outcomes, confounding variables not addressed (prior treatment)
O'Connor 2011^23^ Canada Industry | Prospective post hoc analysis of trial data | High | Attrition in MRI outcomes, large sample with lack of individual-level outcome assessment, confounding variables not addressed (prior treatment)
Rossi, 2013^24^ Italy Industry | Prospective cohort | High | Outcome (rebound definition) not clearly specified, attrition in MRI outcomes, confounding variables not addressed (prior treatment)
Sorensen, 2014^25^ Denmark Not reported | Retrospective; national registry | High | Retrospective, confounding variables not addressed (reason for interruption, prior treatment)
MRI Outcomes
Boriello, 2012^26^ Spain Not reported | Prospective cohort post-marketing | High | Inadequate sample size, outcome (rebound definition) not clearly specified, confounding variables not addressed (baseline EDSS 5.0, prior treatment) inadequate reporting of relapses
Boriello, 2011^27^ Spain Not funded | Prospective cohort post-marketing | High | Inadequate sample size, outcome (rebound definition) not clearly specified, unequal length of MRI followup, confounding variables not addressed (prior treatment)
Miravalle, 2011^28^ United States Industry | Prospective cohort | High | Inadequate sample size, outcome (rebound definition) not clearly specified, inadequate reporting of relapses, confounding variables not addressed (prior treatment)
Rossi, 2013^24^ Italy Industry | Prospective cohort | High | Outcome (rebound definition) not clearly specified, attrition in MRI outcomes, confounding variables not addressed (prior treatment)

ARR=annualized relapse rate; EDSS=Expanded Disability Status Scale; MRI=magnetic resonance imaging

Table Appendix D3 KQ1 risk of bias for articles in pregnancy set

Study Country Funding | Type of Study | Overall Risk of Bias Assessment | Rationale
Interferon beta 1a
Sandberg-Wollheim, 2011^29^ Sweden Industry | Prospective global drug safety database | High | Unintended exposures not described
Sandberg-Wollheim, 2005^30^ Sweden Industry | Prospective individual patient data from 8 trials | High | Insufficient sample size, unintended exposures not described
Interferon beta mixed
Amato, 2010^31^ Italy Not reported | Prospective cohort, 21 clinics | High | Insufficient sample size, lack of detail in describing the intervention (e.g., specific drug) in results, lack of detail in describing statistical methods
Boskovic, 2005^32^ Canada Not reported | Prospective cohort, women who contacted risk counseling program | High | Insufficient sample size, lack of detail in describing the intervention (e.g., specific drug), inappropriate comparison, statistical methods to assess the outcome used inappropriately, lack of interpretability
Patti, 2008^33^ Italy Not reported | Retrospective cohort, one clinic | High | Retrospective design, insufficient sample size, lack of detail in describing the intervention (e.g., specific drug), lack of interpretability
Interferon beta mixed, glatiramer acetate
Finkelsztejn, 2011^34^ Brazil Not reported | Retrospective, voluntary database | High | Insufficient sample size, lack of detail in describing the intervention (e.g., specific drug), unintended exposures (e.g., smoking) not described, lack of interpretability
Fragoso, 2013^35^ International | Retrospective, voluntary database | High | Selectively recruited participants, insufficient sample size, lack of detail in describing the intervention (e.g., specific drug), unintended exposures (e.g., smoking) not described, unclear length of followup for maternal outcomes
Hellwig, 2012^36^ Germany Not funded | Retrospective, risk counseling database | High | Insufficient sample size, lack of detail in describing the intervention (e.g., specific drug), unintended exposures (e.g., smoking) not described
Lu, 2012^37^ Canada Government | Retrospective cohort, provincial database | High | Insufficient sample size, lack of detail in describing the intervention (e.g., specific drug)
Weber-Schoendorfer, 2009^38^ Germany | Prospective cohort, risk assessment program | High | insufficient sample size, lack of detail in describing the intervention (e.g., specific drug), inappropriate comparison
Glatiramer acetate
Giannini, 2012^39^ Italy Not reported | Prospective cohort, 21 clinics | High | Insufficient sample size
Natalizumab
Hellwig, 2011^40^ Germany Not funded | Prospective counseling database | High | insufficient sample size, unintended exposures (e.g., smoking) not described

## References for Appendix D

1 Debouverie M, Moreau T, Lebrun C, et al. A longitudinal observational study of a cohort of patients with relapsing-remitting multiple sclerosis treated with glatiramer acetate. Eur J Neurol. Nov. 2007;14(11):1266-74. [pmid: 17956447].
2 Ford C, Goodman AD, Johnson K, et al. Continuous long-term immunomodulatory therapy in relapsing multiple sclerosis: results from the 15-year analysis of the US prospective open-label study of glatiramer acetate. Mult Scler. Mar. 2010;16(3):342-50. [pmid: 20106943].
3 Miller A, Spada V, Beerkircher D, et al. Long-term (up to 22 years), open-label, compassionate-use study of glatiramer acetate in relapsing-remitting multiple sclerosis. Mult Scler. May. 2008;14(4):494-9. [pmid: 18208875].
4 Confavreux C, Li DK, Freedman MS, et al. Long-term follow-up of a phase 2 study of oral teriflunomide in relapsing multiple sclerosis: safety and efficacy results up to 8.5 years. Mult Scler. Sep. 2012;18(9):1278-89. [pmid: 22307384].
5 Uitdehaag B, Constantinescu C, Cornelisse P, et al. Impact of exposure to interferon beta-1a on outcomes in patients with relapsing-remitting multiple sclerosis: Exploratory analyses from the PRISMS long-term follow-up study. Therapeutic Advances in Neurological Disorders. 2011;4(1):3-14. [pmid: 21339904].
6 Bencsik K, Fuvesi J, Fricska-Nagy Z, et al. Short communication: treatment of relapsing-remitting multiple sclerosis 96 patients with IFN-beta 1b: results of a 6-year follow-up. J Interferon Cytokine Res. Feb. 2006;26(2):96-100. [pmid: 16487029].
7 Carmona O, Casado V, Moral E, et al. Interferon-beta1b in multiple sclerosis: effect on progression of disability and clinical markers of treatment response. Eur Neurol. 2008;60(6):279-84. [pmid: 18824855].
8 Goodin DS, Reder AT, Ebers GC, et al. Survival in MS: a randomized cohort study 21 years after the start of the pivotal IFN-1b trial. Neurology. Apr. 24. 2012;78(17):1315-22. [pmid: 22496198].
9 Reder AT, Ebers GC, Traboulsee A, et al. Cross-sectional study assessing long-term safety of interferon-beta-1b for relapsing-remitting MS. Neurology. Jun. 8. 2010;74(23):1877-85. [pmid: 20530324].
10 Kappos L, Freedman MS, Polman CH, et al. Long-term effect of early treatment with interferon beta-1b after a first clinical event suggestive of multiple sclerosis: 5-year active treatment extension of the phase 3 BENEFIT trial. Lancet neurol. Nov. 2009;8(11):987-97. [pmid: 19748319].
11 Rio J, Tintore M, Nos C, et al. Interferon beta in secondary progressive multiple sclerosis : daily clinical practice. Journal of Neurology. Jul. 2007;254(7):849-53. [pmid: 17361342].
12 Patti F, Pappalardo A, Florio C, et al. Effects of interferon beta-1a and -1b over time: 6-year results of an observational head-to-head study. Acta Neurologica Scandinavica. Apr. 2006;113(4):241-7. [pmid: 16542163].
13 Portaccio E, Zipoli V, Siracusa G, et al. Long-term adherence to interferon beta therapy in relapsing-remitting multiple sclerosis. Eur Neurol. 2008;59(3-4):131-5. [pmid: 18057899].
14 Shirani A, Zhao Y, Karim ME, et al. Association between use of interferon beta and progression of disability in patients with relapsing-remitting multiple sclerosis. Jama. Jul. 18. 2012;308(3):247-56. [pmid: 22797642].
15 Tedeholm H, Lycke J, Skoog B, et al. Time to secondary progression in patients with multiple sclerosis who were treated with first generation immunomodulating drugs. Mult Scler. 2013;19(6):765-74. [pmid: 23124789].
16 Rio J, Tintore M, Nos C, et al. Interferon beta in relapsing-remitting multiple sclerosis. An eight years experience in a specialist multiple sclerosis centre. Journal of Neurology. Jul. 2005;252(7):795-800. [pmid: 15772741].
17 Bergamaschi R, Quaglini S, Tavazzi E, et al. Immunomodulatory therapies delay disease progression in multiple sclerosis. Mult Scler. published online. May. 31. 2012:1-9. [pmid: 22653657].
18 Jokubaitis VG, Li V, Kalincik T, et al. Fingolimod after natalizumab and the risk of short-term relapse. Neurology. Apr. 8. 2014;82(14):1204-11. [pmid: 24610329].
19 Havla J, Tackenberg B, Hellwig K, et al. Fingolimod reduces recurrence of disease activity after natalizumab withdrawal in multiple sclerosis. Journal of Neurology. May. 2013;260(5):1382-7. [pmid: 23266894].
20 Havla J, Gerdes LA, Meinl I, et al. De-escalation from natalizumab in multiple sclerosis: recurrence of disease activity despite switching to glatiramer acetate. Journal of Neurology. Sep. 2011;258(9):1665-9. [pmid: 21431380].
21 Kaufman MD, Lee R, Norton HJ. Course of relapsing-remitting multiple sclerosis before, during and after natalizumab. Mult Scler. Apr. 2011;17(4):490-4. [pmid: 21135017].
22 Kerbrat A, Le Page E, Leray E, et al. Natalizumab and drug holiday in clinical practice: an observational study in very active relapsing remitting multiple sclerosis patients. J Neurol Sci. Sep. 15. 2011;308(1-2):98-102. [pmid: 21665227].
23 O'Connor PW, Goodman A, Kappos L, et al. Disease activity return during natalizumab treatment interruption in patients with multiple sclerosis. Neurology. May. 31. 2011;76(22):1858-65. [pmid: 21543733].
24 Rossi S, Motta C, Studer V, et al. Effect of glatiramer acetate on disease reactivation in MS patients discontinuing natalizumab. Eur J Neurol. Jan. 2013;20(1):87-94. [pmid: 22741530].
25 Sorensen PS, Koch-Henriksen N, Petersen T, et al. Recurrence or rebound of clinical relapses after discontinuation of natalizumab therapy in highly active MS patients. Journal of Neurology. 2014;261(6):1170-7. [pmid: 24728334].
26 Borriello G, Prosperini L, Mancinelli C, et al. Pulse monthly steroids during an elective interruption of natalizumab: a post-marketing study. Eur J Neurol. May. 2012;19(5):783-7. [pmid: 22054236].
27 Borriello G, Prosperini L, Marinelli F, et al. Observations during an elective interruption of natalizumab treatment: a post-marketing study. Mult Scler. Mar. 2011;17(3):372-5. [pmid: 21148264].
28 Miravalle A, Jensen R, Kinkel RP. Immune reconstitution inflammatory syndrome in patients with multiple sclerosis following cessation of natalizumab therapy. Archives of Neurology. Feb. 2011;68(2):186-91. [pmid: 20937940].
29 Sandberg-Wollheim M, Alteri E, Moraga MS, et al. Pregnancy outcomes in multiple sclerosis following subcutaneous interferon beta-1a therapy. Mult Scler. Apr. 2011;17(4):423-30. [pmid: 21220368].
30 Sandberg-Wollheim M, Frank D, Goodwin TM, et al. Pregnancy outcomes during treatment with interferon beta-1a in patients with multiple sclerosis. Neurology. Sep. 27. 2005;65(6):802-6. [pmid: 16093457].
31 Amato MP, Portaccio E, Ghezzi A, et al. Pregnancy and fetal outcomes after interferon-exposure in multiple sclerosis. Neurology. Nov. 16. 2010;75(20):1794-802. [pmid: 21079181].
32 Boskovic R, Wide R, Wolpin J, et al. The reproductive effects of beta interferon therapy in pregnancy: A longitudinal cohort. Neurology. 2005;65(6):807-11. [pmid: 16186517].
33 Patti F, Cavallaro T, Lo Fermo S, et al. Is in utero early-exposure to interferon beta a risk factor for pregnancy outcomes in multiple sclerosis?. Journal of Neurology. Aug. 2008;255(8):1250-3. [pmid: 18677640].
34 Finkelsztejn A, Fragoso YD, Ferreira ML, et al. The Brazilian database on pregnancy in multiple sclerosis. Clin Neurol Neurosurg. May. 2011;113(4):277-80. [pmid: 21159421].
35 Fragoso YD, Boggild M, MacIas-Islas MA, et al. The effects of long-term exposure to disease-modifying drugs during pregnancy in multiple sclerosis. Clinical Neurology and Neurosurgery. 2013;115(2):154-9. [pmid: 22633835].
36 Hellwig K, Haghikia A, Rockhoff M, et al. Multiple sclerosis and pregnancy: experience from a nationwide database in Germany. Therapeutic advances in neurological disorders. 2012;5(5):247-53. [pmid: 22973421].
37 Lu E, Dahlgren L, Sadovnick A, et al. Perinatal outcomes in women with multiple sclerosis exposed to disease-modifying drugs. Mult Scler. Apr. 2012;18(4):460-7. [pmid: 21914689].
38 Weber-Schoendorfer C, Schaefer C. Multiple sclerosis, immunomodulators, and pregnancy outcome: a prospective observational study. Mult Scler. Sep. 2009;15(9):1037-42. [pmid: 19692433].
39 Giannini M, Portaccio E, Ghezzi A, et al. Pregnancy and fetal outcomes after Glatiramer Acetate exposure in patients with multiple sclerosis: a prospective observational multicentric study. BMC Neurol. 2012;12:124. [pmid: 23088447].
40 Hellwig K, Haghikia A, Gold R. Pregnancy and natalizumab: results of an observational study in 35 accidental pregnancies during natalizumab treatment. Mult Scler. Aug. 2011;17(8):958-63. [pmid: 21613333].