# Evidence Tables

Appendix Table C1 Evidence table for KQ1 (not natalizumab interruption or pregnancy) studies

Appendix Table C2 Analytic set outcomes

Appendix Table C3 Analytic set harms

Appendix Table C4 Discontinuation details by study (if reported) from full reporting set

Appendix Table C5 Studies of natalizumab discontinuation

Appendix Table C6 Outcomes for studies of natalizumab discontinuation

Appendix Table C7 Studies of women with MS who experienced pregnancy and their fetuses

Appendix Table C8 Fetal outcomes for DMT exposure and maternal outcomes for drug holiday

## References for Appendix C

1 Bencsik K, Fuvesi J, Fricska-Nagy Z, et al. Short communication: treatment of relapsing-remitting multiple sclerosis 96 patients with IFN-beta 1b: results of a 6-year follow-up. J Interferon Cytokine Res. Feb. 2006;26(2):96-100. [pmid: 16487029].
2 Bermel RA, Weinstock-Guttman B, Bourdette D, et al. Intramuscular interferon beta-1a therapy in patients with relapsing-remitting multiple sclerosis: a 15-year follow-up study. Mult Scler. May. 2010;16(5):588-96. [pmid: 20167591].
3 Bermel RA, You X, Foulds P, et al. Predictors of long-term outcome in multiple sclerosis patients treated with interferon. Ann Neurol. Jan. 2013;73(1):95-103. [pmid: 23378325].
4 Bergamaschi R, Quaglini S, Tavazzi E, et al. Immunomodulatory therapies delay disease progression in multiple sclerosis. Mult Scler. published online. May. 2012;31:1-9. [pmid: 22653657].
5 Carmona O, Casado V, Moral E, et al. Interferon-beta1b in multiple sclerosis: effect on progression of disability and clinical markers of treatment response. Eur Neurol. 2008;60(6):279-84. [pmid: 18824855].
6 Confavreux C, Li DK, Freedman MS, et al. Long-term follow-up of a phase 2 study of oral teriflunomide in relapsing multiple sclerosis: safety and efficacy results up to 8.5 years. Mult Scler. Sep. 2012;18(9):1278-89. [pmid: 22307384].
7 Cunningham A, Gottberg K, von Koch L, et al. Non-adherence to interferon-beta therapy in Swedish patients with multiple sclerosis. Acta Neurologica Scandinavica. Mar. 2010;121(3):154-60. [pmid: 20055771].
8 Debouverie M, Moreau T, Lebrun C, et al. A longitudinal observational study of a cohort of patients with relapsing-remitting multiple sclerosis treated with glatiramer acetate. Eur J Neurol. Nov. 2007;14(11):1266-74. [pmid: 17956447].
9 Evans C, Tam J, Kingwell E, et al. Long-term persistence with the immunomodulatory drugs for multiple sclerosis: a retrospective database study. Clin Ther. Feb. 2012;34(2):341-50. [pmid: 22296946].
10 Ford C, Goodman AD, Johnson K, et al. Continuous long-term immunomodulatory therapy in relapsing multiple sclerosis: results from the 15-year analysis of the US prospective open-label study of glatiramer acetate. Mult Scler. Mar. 2010;16(3):342-50. [pmid: 20106943].
11 Ford CC, Johnson KP, Lisak RP, et al. A prospective open-label study of glatiramer acetate: over a decade of continuous use in multiple sclerosis patients. Mult Scler. Jun. 2006;12(3):309-20. [pmid: 16764344].
12 Johnson KP, Brooks BR, Ford CC, et al. Sustained clinical benefits of glatiramer acetate in relapsing multiple sclerosis patients observed for 6 years. Copolymer 1 Multiple Sclerosis Study Group. Mult Scler. Aug. 2000;6(4):255-66. [pmid: 10962546].
13 Johnson KP, Brooks BR, Ford CC, et al. Glatiramer acetate (Copaxone): comparison of continuous versus delayed therapy in a six-year organized multiple sclerosis trial. Mult Scler. Dec. 2003;9(6):585-91. [pmid: 14664471].
14 Johnson KP, Ford CC, Lisak RP, et al. Neurologic consequence of delaying glatiramer acetate therapy for multiple sclerosis: 8-year data. Acta Neurologica Scandinavica. Jan. 2005;111(1):42-7. [pmid: 15595937].
15 Goodin DS, Reder AT, Ebers GC, et al. Survival in MS: a randomized cohort study 21 years after the start of the pivotal IFN-1b trial. Neurology. Apr. 24. 2012;78(17):1315-22. [pmid: 22496198].
16 Reder AT, Ebers GC, Traboulsee A, et al. Cross-sectional study assessing long-term safety of interferon-beta-1b for relapsing-remitting MS. Neurology. Jun. 8. 2010;74(23):1877-85. [pmid: 20530324].
17 Ebers GC, Reder AT, Traboulsee A, et al. Long-term follow-up of the original interferon-beta1b trial in multiple sclerosis: design and lessons from a 16-year observational study. Clin Ther. Aug. 2009;31(8):1724-36. [pmid: 19808131].
18 Kappos L, Freedman MS, Polman CH, et al. Long-term effect of early treatment with interferon beta-1b after a first clinical event suggestive of multiple sclerosis: 5-year active treatment extension of the phase 3 BENEFIT trial. Lancet neurol. Nov. 2009;8(11):987-97. [pmid: 19748319].
19 Mesaros S, Stojsavljevic N, Dujmovic-Basuroski I, et al. Long-term adherence to interferon-beta treatment in a cohort of RRMS patients in Belgrade, Serbia. Clin Neurol Neurosurg. Oct. 2012;114(8):1145-8. [pmid: 22425462].
20 Milanese C, Beghi E, Giordano L, et al. A post-marketing study on immunomodulating treatments for relapsing-remitting multiple sclerosis in Lombardia: preliminary results. Neurol Sci. Dec. Suppl 4. 2005;26:S171-3. [pmid: 16388352].
21 Miller A, Spada V, Beerkircher D, et al. Long-term (up to 22 years), open-label, compassionate-use study of glatiramer acetate in relapsing-remitting multiple sclerosis. Mult Scler. May. 2008;14(4):494-9. [pmid: 18208875].
22 O'Rourke KE, Hutchinson M. Stopping beta-interferon therapy in multiple sclerosis: an analysis of stopping patterns. Mult Scler. Feb. 2005;11(1):46-50. [pmid: 15732266].
23 O'Rourke K, Walsh C, Antonelli G, et al. Predicting beta-interferon failure in relapsing-remitting multiple sclerosis. Mult Scler. Apr. 2007;13(3):336-42. [pmid: 17439902].
24 Patti F, Pappalardo A, Florio C, et al. Effects of interferon beta-1a and -1b over time: 6-year results of an observational head-to-head study. Acta Neurologica Scandinavica. Apr. 2006;113(4):241-7. [pmid: 16542163].
25 Portaccio E, Zipoli V, Siracusa G, et al. Long-term adherence to interferon beta therapy in relapsing-remitting multiple sclerosis. Eur Neurol. 2008;59(3-4):131-5. [pmid: 18057899].
26 Rio J, Nos C, Tintore M, et al. Defining the response to interferon-beta in relapsing-remitting multiple sclerosis patients. Ann Neurol. Feb. 2006;59(2):344-52. [pmid: 16437558].
27 Rio J, Porcel J, Tellez N, et al. Factors related with treatment adherence to interferon beta and glatiramer acetate therapy in multiple sclerosis. Mult Scler. Jun. 2005;11(3):306-9. [pmid: 15957512].
28 Rio J, Tintore M, Nos C, et al. Interferon beta in relapsing-remitting multiple sclerosis. An eight years experience in a specialist multiple sclerosis centre. Journal of Neurology. Jul. 2005;252(7):795-800. [pmid: 15772741].
29 Rio J, Tintore M, Nos C, et al. Interferon beta in secondary progressive multiple sclerosis : daily clinical practice. Journal of Neurology. Jul. 2007;254(7):849-53. [pmid: 17361342].
30 Shirani A, Zhao Y, Karim ME, et al. Association between use of interferon beta and progression of disability in patients with relapsing-remitting multiple sclerosis. Jama. Jul. 18. 2012;308(3):247-56. [pmid: 22797642].
31 Sorensen PS, Koch-Henriksen N, Ravnborg M, et al. Immunomodulatory treatment of multiple sclerosis in denmark: a prospective nationwide survey. Mult Scler. Jun. 2006;12(3):253-64. [pmid: 16764337].
32 Trojano M, Paolicelli D, Zimatore GB, et al. The IFNbeta treatment of multiple sclerosis (MS) in clinical practice: the experience at the MS Center of Bari, Italy. Neurol Sci. Dec. Suppl 4. 2005;26:S179-82. [pmid: 16388354].
33 Trojano M, Pellegrini F, Fuiani A, et al. New natural history of interferon-beta-treated relapsing multiple sclerosis. Ann Neurol. Apr. 2007;61(4):300-6. [pmid: 17444502].
34 Trojano M, Pellegrini F, Paolicelli D, et al. Real-life impact of early interferon beta therapy in relapsing multiple sclerosis. Ann Neurol. Oct. 2009;66(4):513-20. [pmid: 19847899].
35 Tedeholm H, Lycke J, Skoog B, et al. Time to secondary progression in patients with multiple sclerosis who were treated with first generation immunomodulating drugs. Mult Scler. 2013;19(6):765-74. [pmid: 23124789].
36 Gold R, Rieckmann P, Chang P, et al. The long-term safety and tolerability of high-dose interferon beta-1a in relapsing-remitting multiple sclerosis: 4-year data from the PRISMS study. Eur J Neurol. Aug. 2005;12(8):649-56. [pmid: 16053475].
37 Uitdehaag B, Constantinescu C, Cornelisse P, et al. Impact of exposure to interferon beta-1a on outcomes in patients with relapsing-remitting multiple sclerosis: Exploratory analyses from the PRISMS long-term follow-up study. Therapeutic Advances in Neurological Disorders. 2011;4(1):3-14. [pmid: 21339904].
38 Prisms Study Group, the University of British Columbia MSMRIAG. PRISMS-4: Long-term efficacy of interferon-beta-1a in relapsing MS. [Erratum appears in Neurology 2001 Sep 25;57(6):1146]. Neurology. Jun. 26. 2001;56(12):1628-36. [pmid: 11425926].
39 Havla J, Tackenberg B, Hellwig K, et al. Fingolimod reduces recurrence of disease activity after natalizumab withdrawal in multiple sclerosis. Journal of Neurology. May. 2013;260(5):1382-7. [pmid: 23266894].
40 Havla J, Gerdes LA, Meinl I, et al. De-escalation from natalizumab in multiple sclerosis: recurrence of disease activity despite switching to glatiramer acetate. Journal of Neurology. Sep. 2011;258(9):1665-9. [pmid: 21431380].
41 Jokubaitis VG, Li V, Kalincik T, et al. Fingolimod after natalizumab and the risk of short-term relapse. Neurology. Apr. 8. 2014;82(14):1204-11. [pmid: 24610329].
42 Kaufman MD, Lee R, Norton HJ. Course of relapsing-remitting multiple sclerosis before, during and after natalizumab. Mult Scler. Apr. 2011;17(4):490-4. [pmid: 21135017].
43 Kerbrat A, Le Page E, Leray E, et al. Natalizumab and drug holiday in clinical practice: an observational study in very active relapsing remitting multiple sclerosis patients. J Neurol Sci. Sep. 15. 2011;308(1-2):98-102. [pmid: 21665227].
44 O'Connor PW, Goodman A, Kappos L, et al. Disease activity return during natalizumab treatment interruption in patients with multiple sclerosis. Neurology. May. 31. 2011;76(22):1858-65. [pmid: 21543733].
45 Rossi S, Motta C, Studer V, et al. Effect of glatiramer acetate on disease reactivation in MS patients discontinuing natalizumab. Eur J Neurol. Jan. 2013;20(1):87-94. [pmid: 22741530].
46 Sorensen PS, Koch-Henriksen N, Petersen T, et al. Recurrence or rebound of clinical relapses after discontinuation of natalizumab therapy in highly active MS patients. Journal of Neurology. 2014;261(6):1170-7. PMID. [pmid: 24728334].
47 Borriello G, Prosperini L, Mancinelli C, et al. Pulse monthly steroids during an elective interruption of natalizumab: a post-marketing study. Eur J Neurol. May. 2012;19(5):783-7. [pmid: 22054236].
48 Borriello G, Prosperini L, Marinelli F, et al. Observations during an elective interruption of natalizumab treatment: a post-marketing study. Mult Scler. Mar. 2011;17(3):372-5. [pmid: 21148264].
49 Miravalle A, Jensen R, Kinkel RP. Immune reconstitution inflammatory syndrome in patients with multiple sclerosis following cessation of natalizumab therapy. Archives of Neurology. Feb. 2011;68(2):186-91. [pmid: 20937940].
50 Sandberg-Wollheim M, Alteri E, Moraga MS, et al. Pregnancy outcomes in multiple sclerosis following subcutaneous interferon beta-1a therapy. Mult Scler. Apr. 2011;17(4):423-30. [pmid: 21220368].
51 Sandberg-Wollheim M, Frank D, Goodwin TM, et al. Pregnancy outcomes during treatment with interferon beta-1a in patients with multiple sclerosis. Neurology. Sep. 27. 2005;65(6):802-6. [pmid: 16093457].
52 Amato MP, Portaccio E, Ghezzi A, et al. Pregnancy and fetal outcomes after interferon-exposure in multiple sclerosis. Neurology. Nov. 16. 2010;75(20):1794-802. [pmid: 21079181].
53 Boskovic R, Wide R, Wolpin J, et al. The reproductive effects of beta interferon therapy in pregnancy: A longitudinal cohort. Neurology. 2005;65(6):807-11. [pmid: 16186517].
54 Patti F, Cavallaro T, Lo Fermo S, et al. Is in utero early-exposure to interferon beta a risk factor for pregnancy outcomes in multiple sclerosis?. Journal of Neurology. Aug. 2008;255(8):1250-3. [pmid: 18677640].
55 Fragoso YD, Boggild M, MacIas-Islas MA, et al. The effects of long-term exposure to disease-modifying drugs during pregnancy in multiple sclerosis. Clinical Neurology and Neurosurgery. 2013;115(2):154-9. [pmid: 22633835].
56 Hellwig K, Haghikia A, Rockhoff M, et al. Multiple sclerosis and pregnancy: experience from a nationwide database in Germany. Therapeutic advances in neurological disorders. 2012;5(5):247-53. [pmid: 22973421].
57 Finkelsztejn A, Fragoso YD, Ferreira ML, et al. The Brazilian database on pregnancy in multiple sclerosis. Clin Neurol Neurosurg. May. 2011;113(4):277-80. [pmid: 21159421].
58 Lu E, Dahlgren L, Sadovnick A, et al. Perinatal outcomes in women with multiple sclerosis exposed to disease-modifying drugs. Mult Scler. Apr. 2012;18(4):460-7. [pmid: 21914689].
59 Weber-Schoendorfer C, Schaefer C. Multiple sclerosis, immunomodulators, and pregnancy outcome: a prospective observational study. Mult Scler. Sep. 2009;15(9):1037-42. [pmid: 19692433].
60 Giannini M, Portaccio E, Ghezzi A, et al. Pregnancy and fetal outcomes after Glatiramer Acetate exposure in patients with multiple sclerosis: a prospective observational multicentric study. BMC Neurol. 2012;12:124. [pmid: 23088447].
61 Hellwig K, Haghikia A, Gold R. Pregnancy and natalizumab: results of an observational study in 35 accidental pregnancies during natalizumab treatment. Mult Scler. Aug. 2011;17(8):958-63. [pmid: 21613333].