# Excluded Studies

(reason for exclusion appears at the end of each reference)

1 Barbero P, Verdun E, Bergui M, et al. High-dose, frequently administered interferon beta therapy for relapsing-remitting multiple sclerosis must be maintained over the long term: the interferon beta dose-reduction study. Journal of the Neurological Sciences. Jul. 15. 2004;222(1-2):13-9. (timing). [pmid: 15240190].
2 Boz C, Oger J, Gibbs E, et al. Reduced effectiveness of long-term interferon-beta treatment on relapses in neutralizing antibody-positive multiple sclerosis patients: a Canadian multiple sclerosis clinic-based study. [Erratum appears in Mult Scler. 2008 May;14(4):575]. Multiple Sclerosis. Nov. 2007;13(9):1127-37. (outcomes). [pmid: 17967840].
3 Castillo-Trivino T, Mowry EM, Gajofatto A, et al. Switching multiple sclerosis patients with breakthrough disease to second-line therapy. PLoS ONE. [Electronic Resource]. 2011;6(2):e16664. (not on topic). [pmid: 21304907].
4 Chan KH, Tsang KL, Ho PW, et al. Clinical outcome of relapsing remitting multiple sclerosis among Hong Kong Chinese. Clinical Neurology & Neurosurgery. Oct. 2011;113(8):617-22. (outcomes). [pmid: 21621913].
5 Clanet M, Kappos L, Hartung HP, et al. Interferon beta-1a in relapsing multiple sclerosis: four-year extension of the European IFNbeta-1a Dose-Comparison Study. Multiple Sclerosis. Apr. 2004;10(2):139-44. (drug: non-US dose). [pmid: 15124757].
6 Coles AJ, Fox E, Vladic A, et al. Alemtuzumab more effective than interferon -1a at 5-year follow-up of CAMMS223 clinical trial. Neurology. Apr. 3. 2012;78(14):1069-78. (drug not included). [pmid: 22442431].
7 Coppola G, Lanzillo R, Florio C, et al. Long-term clinical experience with weekly interferon beta-1a in relapsing multiple sclerosis. European Journal of Neurology. Sep. 2006;13(9):1014-21. (timing). [pmid: 16930370].
8 De Las Heras V, De Andres C, Tellez N, et al. Pregnancy in multiple sclerosis patients treated with immunomodulators prior to or during part of the pregnancy: a descriptive study in the Spanish population. Multiple Sclerosis. Sep. 2007;13(8):981-4. (outcomes not by drug). [pmid: 17623725].
9 Dubois BD, Keenan E, Porter BE, et al. Interferon beta in multiple sclerosis: experience in a British specialist multiple sclerosis centre. Journal of Neurology, Neurosurgery & Psychiatry. Jul. 2003;74(7):946-9. (timing).
10 Ebers GC, Reder AT, Traboulsee A, et al. Long-term follow-up of the original interferon-beta1b trial in multiple sclerosis: design and lessons from a 16-year observational study. Clinical Therapeutics. Aug. 2009;31(8):1724-36. (design). [pmid: 19808131].
11 Fazekas F, Baumhackl U, Berger T, et al. Decision-making for and impact of early immunomodulatory treatment: the Austrian Clinically Isolated Syndrome Study (ACISS). European Journal of Neurology. Jun. 1. 2010;17(6):852-60. (not on topic). [pmid: 20100231].
12 Fernandez Liguori N, Klajn D, Acion L, et al. Epidemiological characteristics of pregnancy, delivery, and birth outcome in women with multiple sclerosis in Argentina (EMEMAR study). Multiple Sclerosis. May. 2009;15(5):555-62. (outcomes not by drug). [pmid: 19299437].
13 Fernández O, Oreja-Guevara C, Arroyo R, et al. Natalizumab treatment of multiple sclerosis in Spain: Results of an extensive observational study. Journal of Neurology. 2012;259(9):1814-23. (outcomes). [pmid: 22289966].
14 Fernandez-Fernandez O, Garcia-Trujillo L, Guerrero-Fernandez M, et al. The effectiveness of glatiramer acetate in clinical practice: an observational study. Revista de Neurologia. Jan. 1. 2012;54(1):1-9. (timing). [pmid: 22187206].
15 Flechter S, Vardi J, Pollak L, et al. Comparison of glatiramer acetate (Copaxone) and interferon beta-1b (Betaferon) in multiple sclerosis patients: an open-label 2-year follow-up. Journal of the Neurological Sciences. May. 15. 2002;197(1-2):51-5. (timing). [pmid: 11997066].
16 Giovannoni G, Rhoades RW. Individualizing treatment goals and interventions for people with MS. Current Opinion in Neurology. Feb. Suppl. 2012;25:S20-7. (not on topic). [pmid: 22398661].
17 Grimaldi LM, Prosperini L, Vitello G, et al. MRI-based analysis of the natalizumab therapeutic window in multiple sclerosis. Multiple Sclerosis. Sep. 2012;18(9):1337-9. (outcomes). [pmid: 22389413].
18 Grytten N, Aarseth J, Espeset K, et al. Health-related quality of life and disease-modifying treatment behaviour in relapsing-remitting multiple sclerosis-A multicentre cohort study. Acta Neurologica Scandinavica. Dec. 2012;126(Suppl 195):51-7. (design). [pmid: 23278657].
19 Hamann J, Mendel R, Reiter S, et al. Why do some patients with schizophrenia want to be engaged in medical decision making and others do not?. Journal of Clinical Psychiatry. Dec. 2011;72(12):1636-43. (not on topic). [pmid: 21367353].
20 Heesen C, Solari A, Giordano A, et al. Decisions on multiple sclerosis immunotherapy: new treatment complexities urge patient engagement. Journal of the Neurological Sciences. Jul. 15. 2011;306(1-2):192-7. (not on topic). [pmid: 20920815].
21 Hill S, Filippini G, Synnot A, et al. Presenting evidence-based health information for people with multiple sclerosis: the IN-DEEP project protocol. BMC Medical Informatics & Decision Making. 2012;12:20. (not on topic). [pmid: 22424304].
22 Holmen C, Piehl F, Hillert J, et al. A Swedish national post-marketing surveillance study of natalizumab treatment in multiple sclerosis. Multiple Sclerosis. Jun. 2011;17(6):708-19. (outcomes). [pmid: 21228027].
23 Horakova D, Kalincik T, Dolezal O, et al. Early predictors of non-response to interferon in multiple sclerosis. Acta Neurologica Scandinavica. Dec. 2012;126(6):390-7. (intervention unclear). [pmid: 22428845].
24 Isaksson AK, Ahlstrom G. Managing chronic sorrow: experiences of patients with multiple sclerosis. Journal of Neuroscience Nursing. Jun. 2008;40(3):180-91. (not on topic). [pmid: 18578277].
25 Janssens AC, van Doorn PA, de Boer JB, et al. Perception of prognostic risk in patients with multiple sclerosis: the relationship with anxiety, depression, and disease-related distress. Journal of Clinical Epidemiology. Feb. 2004;57(2):180-6. (not on topic). [pmid: 15125628].
26 Jokubaitis VG, Spelman T, Lechner-Scott J, et al. The Australian Multiple Sclerosis (MS) Immunotherapy Study: A Prospective, Multicentre Study of Drug Utilisation Using the MSBase Platform. PLoS ONE. 2013;8(3). (selective reporting of discontinuation).
27 Jordy SS, Tilbery CP, Fazzito MM. Immunomodulator therapy migration in relapsing remitting multiple sclerosis: a study of 152 cases. [Erratum appears in Arq Neuropsiquiatr. 2008 Jun;66(2A):292]. Arquivos de Neuro-Psiquiatria. Mar. 2008;66(1):11-4. (intervention unclear). [pmid: 18392406].
28 Kalincik T, Horakova D, Dolezal O, et al. Interferon, azathioprine and corticosteroids in multiple sclerosis: 6-year follow-up of the ASA cohort. Clinical Neurology & Neurosurgery. Sep. 2012;114(7):940-6. (intervention unclear). [pmid: 22402204].
29 Kasper J, Heesen C, Kopke S, et al. Patients' and observers' perceptions of involvement differ. Validation study on inter-relating measures for shared decision making. PLoS ONE. [Electronic Resource]. 2011;6(10):e26255. (not on topic). [pmid: 22043310].
30 Kopke S, Kasper J, Muhlhauser I, et al. Patient education program to enhance decision autonomy in multiple sclerosis relapse management: a randomized-controlled trial. Multiple Sclerosis. Jan. 2009;15(1):96-104. (not on topic). [pmid: 18845657].
31 Lebrun C, Debouverie M, Jeannin S, et al. Impact of disease-modifying treatments in North African migrants with multiple sclerosis in France. Multiple Sclerosis. Aug. 2008;14(7):933-9. (intervention unclear). [pmid: 18573824].
32 Lode K, Larsen JP, Bru E, et al. Patient information and coping styles in multiple sclerosis. Multiple Sclerosis. Jul. 2007;13(6):792-9. (not on topic). [pmid: 17613608].
33 Magraner MJ, Coret F, Navarre A, et al. Pulsed steroids followed by glatiramer acetate to prevent inflammatory activity after cessation of natalizumab therapy: a prospective, 6-month observational study. Journal of Neurology. Oct. 2011;258(10):1805-11. (design). [pmid: 21625938].
34 Mancardi GL, Amato MP, D'Alessandro R, et al. Natalizumab: a country-based surveillance program. Neurological Sciences. Sep. Suppl 2. 2008;29:S235-7. (outcomes). [pmid: 18690503].
35 Margolis JM, Fowler R, Johnson BH, et al. Disease-modifying drug initiation patterns in commercially insured multiple sclerosis patients: a retrospective cohort study. BMC Neurology. 2011;11:122. (timing). [pmid: 21974973].
36 Melin A, Outteryck O, Collongues N, et al. Effect of natalizumab on clinical and radiological disease activity in a French cohort of patients with relapsing-remitting multiple sclerosis. Journal of Neurology. Jun. 2012;259(6):1215-21. (not on topic). [pmid: 22160375].
37 Milanese C, La Mantia L, Palumbo R, et al. A post-marketing study on interferon beta 1b and 1a treatment in relapsing-remitting multiple sclerosis: different response in drop-outs and treated patients. Journal of Neurology, Neurosurgery & Psychiatry. Dec. 2003;74(12):1689-92. (timing).
38 Minden S, Hoaglin D, Jureidini S, et al. Disease-modifying agents in the Sonya Slifka Longitudinal Multiple Sclerosis Study. Multiple Sclerosis. Jun. 2008;14(5):640-55. (design). [pmid: 18566028].
39 O'Connor P, Devonshire V, Canadian Network of MSC. The use of disease-modifying agents in multiple sclerosis--by the Canadian Network of MS Clinics. Canadian Journal of Neurological Sciences. May. 2008;35(2):127-32. (design). [pmid: 18574923].
40 Oger J, Francis G, Chang P, et al. Prospective assessment of changing from placebo to IFN beta-1a in relapsing MS: the PRISMS study. Journal of the Neurological Sciences. Oct. 15. 2005;237(1-2):45-52. (timing). [pmid: 16026803].
41 Ollendorf DA, Castelli-Haley J, Oleen-Burkey M. Impact of co-prescribed glatiramer acetate and antihistamine therapy on the likelihood of relapse among patients with multiple sclerosis. Journal of Neuroscience Nursing. Oct. 2008;40(5):281-90. (timing). [pmid: 18856249].
42 Onesti E, Bagnato F, Tomassini V, et al. Interferon beta treatment of MS in the daily clinical setting: a 3-year post-marketing study. Neurological Sciences. Dec. 2003;24(5):340-5. (timing). [pmid: 14716530].
43 Panitch H, Goodin D, Francis G, et al. Benefits of high-dose, high-frequency interferon beta-1a in relapsing-remitting multiple sclerosis are sustained to 16 months: final comparative results of the EVIDENCE trial. Journal of the Neurological Sciences. Dec. 15. 2005;239(1):67-74. (timing). [pmid: 16169561].
44 Paolillo A, Pozzilli C, Giugni E, et al. A 6-year clinical and MRI follow-up study of patients with relapsing-remitting multiple sclerosis treated with Interferon-beta. European Journal of Neurology. Nov. 2002;9(6):645-55. (drug: non-US dose). [pmid: 12453081].
45 Pickin M, Cooper CL, Chater T, et al. The Multiple Sclerosis Risk Sharing Scheme Monitoring Study--early results and lessons for the future. BMC Neurology. 2009;9:1. (not on topic). [pmid: 19126193].
46 Portaccio E, Zipoli V, Siracusa G, et al. Switching to second-line therapies in interferon-beta-treated relapsing-remitting multiple sclerosis patients. European Neurology. 2009;61(3):177-82. (not on topic). [pmid: 19129705].
47 Pozzilli C, Prosperini L, Sbardella E, et al. Post-marketing survey on clinical response to interferon beta in relapsing multiple sclerosis: the Roman experience. Neurological Sciences. Dec. Suppl 4. 2005;26:S174-8. (design). [pmid: 16388353].
48 Prosperini L, Gianni C, Leonardi L, et al. Escalation to natalizumab or switching among immunomodulators in relapsing multiple sclerosis. Multiple Sclerosis. Jan. 2012;18(1):64-71. (outcomes). [pmid: 21828195].
49 Prunty M, Sharpe L, Butow P, et al. The motherhood choice: themes arising in the decision-making process for women with multiple sclerosis. Multiple Sclerosis. Jun. 2008;14(5):701-4. (not on topic). [pmid: 18566034].
50 Prunty MC, Sharpe L, Butow P, et al. The motherhood choice: a decision aid for women with multiple sclerosis. Patient Education & Counseling. Apr. 2008;71(1):108-15. (not on topic). [pmid: 18160245].
51 Putzki N, Yaldizli O, Maurer M, et al. Efficacy of natalizumab in second line therapy of relapsing-remitting multiple sclerosis: results from a multi-center study in German speaking countries. European Journal of Neurology. Jan. 2010;17(1):31-7. (design). [pmid: 19614963].
52 Reynolds MW, Stephen R, Seaman C, et al. Healthcare resource utilization following switch or discontinuation in multiple sclerosis patients on disease modifying drugs. Journal of Medical Economics. Mar. 2010;13(1):90-8. (timing). [pmid: 20078189].
53 Rinaldi F, Seppi D, Calabrese M, et al. Switching therapy from natalizumab to fingolimod in relapsing-remitting multiple sclerosis: Clinical and magnetic resonance imaging findings. Multiple Sclerosis. 2012;18(11):1640-3. (design). [pmid: 23100526].
54 Rovaris M, Comi G, Rocca MA, et al. Long-term follow-up of patients treated with glatiramer acetate: a multicentre, multinational extension of the European/Canadian double-blind, placebo-controlled, MRI-monitored trial. Multiple Sclerosis. May. 2007;13(4):502-8. (outcomes). [pmid: 17483532].
55 Rudick RA, Cutter GR, Baier M, et al. Estimating long-term effects of disease-modifying drug therapy in multiple sclerosis patients. Multiple Sclerosis. Dec. 2005;11(6):626-34. (outcomes). [pmid: 16323317].
56 Rudick RA, Lee JC, Cutter GR, et al. Disability progression in a clinical trial of relapsing-remitting multiple sclerosis: eight-year follow-up. Archives of Neurology. Nov. 2010;67(11):1329-35. (outcomes). [pmid: 20625068].
57 Ruggieri RM, Settipani N, Viviano L, et al. Long-term interferon-beta treatment for multiple sclerosis. Neurological Sciences. Dec. 2003;24(5):361-4. (timing). [pmid: 14716534].
58 Russo P, Paolillo A, Caprino L, et al. Effectiveness of interferon beta treatment in relapsing-remitting multiple sclerosis: an Italian cohort study. Journal of Evaluation in Clinical Practice. Nov. 2004;10(4):511-8. (timing). [pmid: 15482413].
59 Sangalli F, Moiola L, Bucello S, et al. Efficacy and tolerability of natalizumab in relapsing-remitting multiple sclerosis patients: a post-marketing observational study. Neurological Sciences. Jan. Suppl 3. 2011;31:299-302. (outcomes). [pmid: 20544247].
60 Schwartz CE, Coulthard-Morris M, Cole B, et al. The quality-of-life effects of interferon beta-1b in multiple sclerosis. An extended Q-TWiST analysis. Archives of Neurology. 1997;54:1475-80. (not on topic). [pmid: 9400356].
61 Schwartz CE, Sprangers MA, Oort FJ, et al. Response shift in patients with multiple sclerosis: an application of three statistical techniques. Quality of Life Research. Dec. 2011;20(10):1561-72. (not on topic). [pmid: 22081216].
62 Schwid SR, Goodman AD, Weinstein A, et al. Cognitive function in relapsing multiple sclerosis: minimal changes in a 10-year clinical trial. Journal of the Neurological Sciences. Apr. 15. 2007;255(1-2):57-63. (outcomes). [pmid: 17331542].
63 Siger M, Durko A, Nicpan A, et al. Discontinuation of interferon beta therapy in multiple sclerosis patients with high pre-treatment disease activity leads to prompt return to previous disease activity. Journal of the Neurological Sciences. Apr. 15. 2011;303(1-2):50-2. (timing). [pmid: 21333308].
64 Sindic CJ, Seeldrayers P, Vande Gaer L, et al. Long-term follow up of glatiramer acetate compassionate use in Belgium. Acta Neurologica Belgica. Jun. 2005;105(2):81-5. (design). [pmid: 16076061].
65 Smeltzer SC. Reproductive decision making in women with multiple sclerosis. Journal of Neuroscience Nursing. Jun. 2002;34(3):145-57. (not on topic). [pmid: 12080870].
66 Solari A, Ferrari G, Radice D. A longitudinal survey of self-assessed health trends in a community cohort of people with multiple sclerosis and their significant others. Journal of the Neurological Sciences. Apr. 15. 2006;243(1-2):13-20. (not on topic). [pmid: 16380136].
67 Somerset M, Campbell R, Sharp DJ, et al. What do people with MS want and expect from health-care services?. Health Expectations. Mar. 2001;4(1):29-37. (not on topic). [pmid: 11286597].
68 Stuve O, Cravens PD, Frohman EM, et al. Immunologic, clinical, and radiologic status 14 months after cessation of natalizumab therapy. Neurology. Feb. 3. 2009;72(5):396-401. (outcomes). [pmid: 18987352].
69 Tedeschi G, Amato MP, D'Alessandro R, et al. The pharmacovigilance program on natalizumab in Italy: 2 years of experience. Neurological Sciences. Oct. Suppl 2. 2009;30:S163-5. (outcomes). [pmid: 19882367].
70 Thorne S, Paterson B, Russell C. The structure of everyday self-care decision making in chronic illness. Qualitative Health Research. Dec. 2003;13(10):1337-52. (not on topic). [pmid: 14658350].
71 Tilbery CP, Mendes MF, Oliveira BE, et al. Immunomodulatory treatment in multiple sclerosis: experience at a Brazilian center with 390 patients. Arquivos de Neuro-Psiquiatria. Mar. 2006;64(1):51-4. (timing). [pmid: 16622553].
72 Tomassini V, Paolillo A, Russo P, et al. Predictors of long-term clinical response to interferon beta therapy in relapsing multiple sclerosis. Journal of Neurology. Mar. 2006;253(3):287-93. (drug: non-US dose). [pmid: 16151600].
73 Tremlett H, Oger J. Adherence from across the pond: Six years of experience with beta-interferons for multiple sclerosis. Pharmaceutical Journal. 2003;271(7274):649-53. (timing).
74 Tremlett HL, Oger J. Interrupted therapy: stopping and switching of the beta-interferons prescribed for MS. Neurology. Aug. 26. 2003;61(4):551-4. (timing). [pmid: 12939437].
75 Tur C, Tintore M, Vidal-Jordana A, et al. Natalizumab discontinuation after PML risk stratification: outcome from a shared and informed decision. Multiple Sclerosis. Aug. 2012;18(8):1193-6. (not on topic). [pmid: 22383232].
76 Twork S, Nippert I, Scherer P, et al. Immunomodulating drugs in multiple sclerosis: compliance, satisfaction and adverse effects evaluation in a German multiple sclerosis population. Current Medical Research & Opinion. Jun. 2007;23(6):1209-15. (design). [pmid: 17559722].
77 Vazirinejad R, Lilley JM, Ward CD. The ‘Impact on Participation and Autonomy’: acceptability of the English version in a multiple sclerosis outpatient setting. Multiple Sclerosis. Dec. 2003;9(6):612-5. (not on topic). [pmid: 14664475].
78 Veugelers PJ, Fisk JD, Brown MG, et al. Disease progression among multiple sclerosis patients before and during a disease-modifying drug program: a longitudinal population-based evaluation. Multiple Sclerosis. Nov. 2009;15(11):1286-94. (timing). [pmid: 19965558].
79 Vlahiotis A, Sedjo R, Cox ER, et al. Gender differences in self-reported symptom awareness and perceived ability to manage therapy with disease-modifying medication among commercially insured multiple sclerosis patients. Journal of Managed Care Pharmacy. Apr. 2010;16(3):206-16. (not on topic). [pmid: 20331325].
80 Werneck LC, Lorenzoni PJ, Radunz VA, et al. Influence of treatment in multiple sclerosis disability: an open, retrospective, non-randomized long-term analysis. Arquivos de Neuro-Psiquiatria. Aug. 2010;68(4):511-21. (intervention unclear). [pmid: 20730302].
81 West TW, Cree BA. Natalizumab dosage suspension: are we helping or hurting?. Annals of Neurology. Sep. 2010;68(3):395-9. (design). [pmid: 20818793].
82 Zwibel HL, Copolymer-1 Treatment Study Principal I. Glatiramer acetate in treatment-naive and prior interferon-beta-1b-treated multiple sclerosis patients. Acta Neurologica Scandinavica. Jun. 2006;113(6):378-86. (timing). [pmid: 16674604].