# Search Algorithms

For KQ1, we searched Medline via Ovid, Cochrane Libraries, and Scopus, modifying the Medline searches for the other databases.

KQ1. MS/Drug Holiday:

Database: Ovid MEDLINE

Search Strategy:

--------------------------------------------------

1. exp multiple sclerosis/dt, th, im
2. drug holiday$.mp.
3. discontinu$.mp.
4. halt$.mp.
5. cessat$.mp.
6. interrupt$.mp.
7. stop$.mp.
8. 2 or 3 or 4 or 5 or 6 or 7
9. 1 and 8

KQ1. MS/Immunomodulation:

Database: Ovid MEDLINE(R)

Search Strategy:

--------------------------------------------------

1. exp multiple sclerosis/dt, th, im (16589)
2. exp immunomodulation/ (229961)
3. exp immunosuppressive agents/ (235978)
4. exp immunologic techniques/ (1168203)
5. 1 and 2 (1184)
6. 1 and 3 (1831)
7. 1 and 4 (2881)
8. 6 or 7 or 8 (4864)

KQ1. MS/Drug Names:

Database: Ovid MEDLINE(R)

Search Strategy:

--------------------------------------------------

1. Multiple Sclerosis, Relapsing-Remitting/dt, im, th [Drug Therapy, Immunology, Therapy]
2. exp Interferon-beta/
3. interferon beta.mp.
4. glatiramer acetate.mp.
5. natalizumab.mp.
6. teriflunomide.mp.
7. 3 or 4 or 5 or 6
8. 1 and 7
9. limit 8 to (addresses or autobiography or bibliography or biography or classical article or comment or editorial or historical article or interactive tutorial or lectures or news or newspaper article or patient education handout)
10. 8 not 9
11. limit 10 to (english language and humans and yr=“1990 -Current”)

For KQ2, we searched Medline via Ovid, Cochrane Libraries, PsychiInfo, and CINAHL, modifying the Medline searches for the other databases.

KQ2. MS/Patient Preference:

Database: Ovid MEDLINE(R)

Search Strategy:

--------------------------------------------------

1. exp multiple sclerosis/dt, th, im
2. exp patient preference/
3. exp attitude to health/
4. exp physician-patient relations/
5. exp decision making/
6. exp choice behavior/
7. exp decision support techniques/
8. exp personal autonomy/
9. exp patient participation/
10. decision making.mp.
11. decision support.mp.
12. risk communication$.mp.
13. shared decision$.mp.
14. 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13
15. 1 and 14
16. exp health knowledge, attitudes, practice/
17. exp *multiple sclerosis/
18. 16 and 17
19. 15 or 18
20. exp multiple sclerosis/px
21. 14 and 20
22. 19 or 21