# Abbreviations

ARR: Annual relapse rate
BREMS: Bayesian risk estimate for MS
CENTRAL: Cochrane Central Register of Controlled Trials
CER: Comparative effectiveness review
CIS: Clinically isolated syndrome
DMT: Disease-modifying treatment
EDSS: Expanded Disability Status Scale
FAMS: Functional Assessment of Multiple Sclerosis
GEL: Gadolinium-enhancing lesion
HSRProj: Health Services Research Projects in Progress
ICTRP: International Controlled Trials Registry Platform
IFN: Interferon
KQ: Key Question
MRI: Magnetic resonance imaging
MS: Multiple sclerosis
MSQLI: Multiple Sclerosis Quality-of-Life Inventory
MSQOL: Multiple sclerosis quality of life
PICOTS: Population, intervention, comparator, outcomes, timing, setting
PML: Progressive multifocal leukoencephalopathy
PPMS: Primary progressive MS
PRMS: Primary relapsing MS
RCT: Randomized controlled trial
RRMS: Relapsing-remitting MS
SIP: Scientific information packet
SPMS: Secondary progressive MS
TEP: Technical Expert Panel
TOO: Task Order Officer