# Abbreviations

AAD | anti-arrhythmic Drug
ACE-I* | angiotensin converting enzyme inhibitor
AF | atrial fibrillation
AFL* | atrial flutter
ARB* | angiotensin II receptor blocker
AT | atrial tachyarrhythmia
BMI* | body mass index
bpm | beats per minute
CAD* | coronary artery disease
CFAE | complex fractionated atrial electrogram
CS | coronary sinus
CTI | cavotricuspid isthmus line
CVA* | cerebrovascular accident (stroke)
c/w* | consistent with
EF | left ventricular ejection fraction
EP | electrophysiology
HR | hazard ratio
HRS | Heart Rhythm Society
HTN | hypertension
ICE | intracardiac echocardiogram
LA | left atrium
LACA | left atrial circumferential (or catheter) ablation
LAD | left atrial diameter
LV* | left ventricle
LVD | Left ventricular diameter
MI | myocardial infarction
MIL | mitral isthmus line
nd* | no data (not described)
nonParox* | nonparoxysmal (atrial fibrillation)
NS* | (statistically) nonsignificant
PAF | paroxysmal atrial fibrillation
Parox* | paroxysmal (atrial fibrillation)
Perm* | permanent
Persist* | persistent (atrial fibrillation)
PV | pulmonary vein
PVAI | pulmonary vein antrum isolation
PVI | pulmonary vein isolation
QoL | quality of life
RCT | randomized controlled trial
RF | radiofrequency
RFA | radiofrequency ablation
RR | relative risk
SF-36 | the 36-Item Short-Form General health Survey
SR | sinus rhythm
TEE | transesophageal echocardiography
TEP | technical expert panel
TIA | transient ischemic attack
WACA | wide area circumferential ablation

* Used in tables only