# References

1 Calkins H, Brugada J, Packer DL, et al. HRS/EHRA/ECAS expert Consensus Statement on catheter and surgical ablation of atrial fibrillation: recommendations for personnel, policy, procedures and follow-up. A report of the Heart Rhythm Society (HRS) Task Force on catheter and surgical ablation of atrial fibrillation. Heart Rhythm. 2007;4:816-861. [pmid: 17556213].
2 Rosamond W, Flegal K, Furie K, et al. Heart disease and stroke statistics—2008 update: a report from the American Heart Association Statistics Committee and Stroke Statistics Subcommittee. Circulation. 2008;117:e25-146. [pmid: 18086926].
3 Fuster V, Ryden LE, Cannom DS, et al. ACC/AHA/ESC 2006 Guidelines for the Management of Patients with Atrial Fibrillation: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the European Society of Cardiology Committee for Practice Guidelines (Writing Committee to Revise the 2001 Guidelines for the Management of Patients With Atrial Fibrillation): developed in collaboration with the European Heart Rhythm Association and the Heart Rhythm Society. Circulation. 2006;114:e257-e354. [pmid: 16908781].
4 Miyasaka Y, Barnes ME, Gersh BJ, et al. Secular trends in incidence of atrial fibrillation in Olmsted County, Minnesota, 1980 to 2000, and implications on the projections for future prevalence. Circulation. 2006;114:119-125. [pmid: 16818816].
5 Hohnloser SH, Kuck KH, Lilienthal J. Rhythm or rate control in atrial fibrillation—Pharmacological Intervention in Atrial Fibrillation (PIAF): a randomised trial. Lancet. 2000;356:1789-1794. [pmid: 11117910].
6 Wyse DG, Waldo AL, DiMarco JP, et al. A comparison of rate control and rhythm control in patients with atrial fibrillation. N Engl J Med. 2002;347:1825-1833. [pmid: 12466506].
7 Carlsson J, Miketic S, Windeler J, et al. Randomized trial of rate-control versus rhythm-control in persistent atrial fibrillation: the Strategies of Treatment of Atrial Fibrillation (STAF) study. J Am Coll Cardiol. 2003;41:1690-1696. [pmid: 12767648].
8 Van Gelder I, Hagens VE, Bosker HA, et al. A comparison of rate control and rhythm control in patients with recurrent persistent atrial fibrillation. N Engl J Med. 2002;347:1834-1840. [pmid: 12466507].
9 Opolski G, Torbicki A, Kosior D, et al. Rhythm control versus rate control in patients with persistent atrial fibrillation. Results of the HOT CAFE Polish Study. Kardiol Pol. 2003;59:1-16. [pmid: 14560344].
10 Testa L, Biondi-Zoccai GG, Dello RA, et al. Rate-control vs. rhythm-control in patients with atrial fibrillation: a meta-analysis. Eur Heart J. 2005;26:2000-2006. [pmid: 15872032].
11 Corley SD, Epstein AE, DiMarco JP, et al. Relationships between sinus rhythm, treatment, and survival in the Atrial Fibrillation Follow-Up Investigation of Rhythm Management (AFFIRM) Study. Circulation. 2004;109:1509-1513. [pmid: 15007003].
12 Haissaguerre M, Jais P, Shah DC, et al. Spontaneous initiation of atrial fibrillation by ectopic beats originating in the pulmonary veins. N Engl J Med. 1998;339:659-666. [pmid: 9725923].
13 Nathan H, Eliakim M. The junction between the left atrium and the pulmonary veins. An anatomic study of human hearts. Circulation. 1966;34:412-422. [pmid: 5922708].
14 Zipes DP, Knope RF. Electrical properties of the thoracic veins. Am J Cardiol. 1972;29:372-376. [pmid: 5060810].
15 Ho SY, Sanchez-Quintana D, Cabrera JA, et al. Anatomy of the left atrium: implications for radiofrequency ablation of atrial fibrillation. J Cardiovasc Electrophysiol. 1999;10:1525-1533. [pmid: 10571372].
16 Weiss C, Gocht A, Willems S, et al. Impact of the distribution and structure of myocardium in the pulmonary veins for radiofrequency ablation of atrial fibrillation. Pacing Clin Electrophysiol. 2002;25:1352-1356. [pmid: 12380772].
17 Robbins IM, Colvin EV, Doyle TP, et al. Pulmonary vein stenosis after catheter ablation of atrial fibrillation. Circulation. 1998;98:1769-1775. [pmid: 9788832].
18 Pappone C, Rosanio S, Oreto G, et al. Circumferential radiofrequency ablation of pulmonary vein ostia: A new anatomic approach for curing atrial fibrillation. Circulation. 2000;102:2619-2628. [pmid: 11085966].
19 Nademanee K, McKenzie J, Kosar E, et al. A new approach for catheter ablation of atrial fibrillation: mapping of the electrophysiologic substrate. J Am Coll Cardiol. 2004;43:2044-2053. [pmid: 15172410].
20 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-188. [pmid: 3802833].
21 Friedrich JO, Adhikari NK, Beyene J. Inclusion of zero total event trials in meta-analyses maintains analytic consistency and incorporates all available data. BMC Med Res Methodol. 2007;7:5. [pmid: 17244367].
22 Greenland S, Salvan A. Bias in the one-step method for pooling study results. Stat Med. 1990;9:247-252. [pmid: 2343220].
23 Krittayaphong R, Raungrattanaamporn O, Bhuripanyo K, et al. A randomized clinical trial of the efficacy of radiofrequency catheter ablation and amiodarone in the treatment of symptomatic atrial fibrillation. Journal of the Medical Association of Thailand. 2003;86:Suppl-16.
24 Wazni OM, Marrouche NF, Martin DO, et al. Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of symptomatic atrial fibrillation: a randomized trial. JAMA. 2005;293:2634-2640. [pmid: 15928285].
25 Stabile G, Bertaglia E, Senatore G, et al. Catheter ablation treatment in patients with drug-refractory atrial fibrillation: a prospective, multi-centre, randomized, controlled study (Catheter Ablation For The Cure Of Atrial Fibrillation Study). European Heart Journal. 2006;27:216-221. [pmid: 16214831].
26 Oral H, Pappone C, Chugh A, et al. Circumferential pulmonary-vein ablation for chronic atrial fibrillation. New England Journal of Medicine. 2006;354:934-941. [pmid: 16510747].
27 Pappone C, Augello G, Sala S, et al. A randomized trial of circumferential pulmonary vein ablation versus antiarrhythmic drug therapy in paroxysmal atrial fibrillation: the APAF Study. Journal of the American College of Cardiology. 2006;48:2340-2347. [pmid: 17161267].
28 Jais P, Cauchemez B, MacLe L, et al. Catheter ablation versus antiarrhythmic drugs for atrial fibrillation: the A4 study. Circulation. 2008;118(24):2498-505. [pmid: 19029470].
29 Pappone C, Rosanio S, Augello G, et al. Mortality, morbidity, and quality of life after circumferential pulmonary vein ablation for atrial fibrillation: outcomes from a controlled nonrandomized long-term study. Journal of the American College of Cardiology. 2003;42:185-197. [pmid: 12875749].
30 Rossillo A, Bonso A, Themistoclakis S, et al. Role of anticoagulation therapy after pulmonary vein antrum isolation for atrial fibrillation treatment. Journal of Cardiovascular Medicine. 2008;9:51-55. [pmid: 18268419].
31 Themistoclakis S, Schweikert RA, Saliba WI, et al. Clinical predictors and relationship between early and late atrial tachyarrhythmias after pulmonary vein antrum isolation. Heart Rhythm. 2008;5:679-685. [pmid: 18325850].
32 Verma A, Wazni OM, Marrouche NF, et al. Pre-existent left atrial scarring in patients undergoing pulmonary vein antrum isolation: an independent predictor of procedural failure. Journal of the American College of Cardiology. 2005;45:285-292. [pmid: 15653029].
33 Pappone C, Manguso F, Vicedomini G, et al. Prevention of iatrogenic atrial tachycardia after ablation of atrial fibrillation: a prospective randomized study comparing circumferential pulmonary vein ablation with a modified approach. Circulation. 2004;110:3036-3042. [pmid: 15520310].
34 Cha YM, Friedman PA, Asirvatham SJ, et al. Catheter ablation for atrial fibrillation in patients with obesity. Circulation. 2008;117:2583-2590. [pmid: 18474813].
35 Chen MS, Marrouche NF, Khaykin Y, et al. Pulmonary vein isolation for the treatment of atrial fibrillation in patients with impaired systolic function. Journal of the American College of Cardiology. 2004;43:1004-1009. [pmid: 15028358].
36 Pappone C, Santinelli V, Manguso F, et al. Pulmonary vein denervation enhances long-term benefit after circumferential ablation for paroxysmal atrial fibrillation. Circulation. 2004;109:327-334. [pmid: 14707026].
37 Matiello M, Mont L, Tamborero D, et al. Cooled-tip vs. 8 mm-tip catheter for circumferential pulmonary vein ablation: comparison of efficacy, safety, and lesion extension. Europace. 2008;10:955-960. [pmid: 18515285].
38 Richter B, Gwechenberger M, Filzmoser P, et al. Is inducibility of atrial fibrillation after radio frequency ablation really a relevant prognostic factor?. European Heart Journal. 2006;27:2553-2559. [pmid: 17038349].
39 Della Bella P, Riva S, Fassini G, et al. Long-term follow-up after radiofrequency catheter ablation of atrial fibrillation: role of the acute procedure outcome and of the clinical presentation. Europace. 2005;7:95-103. [pmid: 15763523].
40 Cheema A, Vasamreddy CR, Dalal D, et al. Long-term single procedure efficacy of catheter ablation of atrial fibrillation. Journal of Interventional Cardiac Electrophysiology. 2006;15:145-155. [pmid: 17019636].
41 Oral H, Chugh A, Scharf C, et al. Pulmonary vein isolation for vagotonic, adrenergic, and random episodes of paroxysmal atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2004;15:402-406. [pmid: 15089987].
42 Al Chekakie MO, Akar JG, Wang F, et al. The effects of statins and renin-angiotensin system blockers on atrial fibrillation recurrence following antral pulmonary vein isolation. Journal of Cardiovascular Electrophysiology. 2007;18:942-946. [pmid: 17593228].
43 Berruezo A, Tamborero D, Mont L, et al. Pre-procedural predictors of atrial fibrillation recurrence after circumferential pulmonary vein ablation. European Heart Journal. 2007;28:836-841. [pmid: 17395676].
44 Dixit S, Gerstenfeld EP, Ratcliffe SJ, et al. Single procedure efficacy of isolating all versus arrhythmogenic pulmonary veins on long-term control of atrial fibrillation: a prospective randomized study. Heart Rhythm. 2008;5:174-181. [pmid: 18242535].
45 Essebag V, Baldessin F, Reynolds MR, et al. Non-inducibility post-pulmonary vein isolation achieving exit block predicts freedom from atrial fibrillation. European Heart Journal. 2005;26:2550-2555. [pmid: 16183686].
46 Nilsson B, Chen X, Pehrson S, et al. Recurrence of pulmonary vein conduction and atrial fibrillation after pulmonary vein isolation for atrial fibrillation: a randomized trial of the ostial versus the extraostial ablation strategy. American Heart Journal. 2006;152:537-538. [pmid: 16923426].
47 Jais P, Hocini M, Hsu LF, et al. Technique and results of linear ablation at the mitral isthmus. Circulation. 2004;110:2996-3002. [pmid: 15520313].
48 Liu X, Dong J, Mavrakis HE, et al. Achievement of pulmonary vein isolation in patients undergoing circumferential pulmonary vein ablation: a randomized comparison between two different isolation approaches. Journal of Cardiovascular Electrophysiology. 2006;17:1263-1270. [pmid: 17239094].
49 Dixit S, Gerstenfeld EP, Callans DJ, et al. Comparison of cool tip versus 8-mm tip catheter in achieving electrical isolation of pulmonary veins for long-term control of atrial fibrillation: a prospective randomized pilot study. Journal of Cardiovascular Electrophysiology. 2006;17:1074-1079. [pmid: 16879626].
50 Oral H, Scharf C, Chugh A, et al. Catheter ablation for paroxysmal atrial fibrillation: segmental pulmonary vein ostial ablation versus left atrial ablation. Circulation. 2003;108:2355-2360. [pmid: 14557355].
51 Calo L, Lamberti F, Loricchio ML, et al. Left atrial ablation versus biatrial ablation for persistent and permanent atrial fibrillation: a prospective and randomized study. Journal of the American College of Cardiology. 2006;47:2504-2512. [pmid: 16781381].
52 Arentz T, Weber R, Burkle G, et al. Small or large isolation areas around the pulmonary veins for the treatment of atrial fibrillation? Results from a prospective randomized study. Circulation. 2007;115:3057-3063. [pmid: 17562956].
53 Beukema WP, Elvan A, Sie HT, et al. Successful radiofrequency ablation in patients with previous atrial fibrillation results in a significant decrease in left atrial size. Circulation. 2005;112:2089-2095. [pmid: 16203925].
54 Bhargava M, Marrouche NF, Martin DO, et al. Impact of age on the outcome of pulmonary vein isolation for atrial fibrillation using circular mapping technique and cooled-tip ablation catheter. Journal of Cardiovascular Electrophysiology. 2004;15:8-13. [pmid: 15028066].
55 Chugh A, Oral H, Lemola K, et al. Prevalence, mechanisms, and clinical significance of macroreentrant atrial tachycardia during and following left atrial ablation for atrial fibrillation. Heart Rhythm. 2005;2:464-471. [pmid: 15840468].
56 Fassini G, Riva S, Chiodelli R, et al. Left mitral isthmus ablation associated with PV Isolation: long-term results of a prospective randomized study. Journal of Cardiovascular Electrophysiology. 2005;16:1150-1156. [pmid: 16302895].
57 Fiala M, Chovancik J, Nevralova R, et al. Termination of long-lasting persistent versus short-lasting persistent and paroxysmal atrial fibrillation by ablation. Pacing & Clinical Electrophysiology. 2008;31:985-997. [pmid: 18684255].
58 Kistler PM, Rajappan K, Jahngir M, et al. The impact of CT image integration into an electroanatomic mapping system on clinical outcomes of catheter ablation of atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2006;17:1093-1101. [pmid: 16989651].
59 Kottkamp H, Tanner H, Kobza R, et al. Time courses and quantitative analysis of atrial fibrillation episode number and duration after circular plus linear left atrial lesions: trigger elimination or substrate modification: early or delayed cure?. Journal of the American College of Cardiology. 2004;44:869-877. [pmid: 15312874].
60 Marsan NA, Tops LF, Holman ER, et al. Comparison of left atrial volumes and function by real-time three-dimensional echocardiography in patients having catheter ablation for atrial fibrillation with persistence of sinus rhythm versus recurrent atrial fibrillation three months later. American Journal of Cardiology. 2008;102(7):847-53. [pmid: 18805109].
61 Martinek M, Nesser HJ, Aichinger J, et al. Impact of integration of multislice computed tomography imaging into three-dimensional electroanatomic mapping on clinical outcomes, safety, and efficacy using radiofrequency ablation for atrial fibrillation. Pacing & Clinical Electrophysiology. 2007;30:1215-1223. [pmid: 17897124].
62 Miyazaki S, Kuwahara T, Takahashi A, et al. Effect of left atrial ablation on the quality of life in patients with atrial fibrillation. Circulation Journal. 2008;72:582-587. [pmid: 18362429].
63 Oral H, Chugh A, Ozaydin M, et al. Risk of thromboembolic events after percutaneous left atrial radiofrequency ablation of atrial fibrillation. Circulation. 2006;114:759-765. [pmid: 16908760].
64 Pappone C, Oreto G, Rosanio S, et al. Atrial electroanatomic remodeling after circumferential radiofrequency pulmonary vein ablation: efficacy of an anatomic approach in a large cohort of patients with atrial fibrillation. Circulation. 2001;104:2539-2544. [pmid: 11714647].
65 Proclemer A, Allocca G, Gregori D, et al. Radiofrequency ablation of drug-refractory atrial fibrillation: an observational study comparing ‘ablate and pace’ with pulmonary vein isolation. Europace. 2008;10:1085-1090. [pmid: 18667447].
66 Shimano M, Inden Y, Tsuji Y, et al. Circulating homocysteine levels in patients with radiofrequency catheter ablation for atrial fibrillation. Europace. 2008;10:961-966. [pmid: 18550508].
67 Sra J, Narayan G, Krum D, et al. Computed tomography-fluoroscopy image integration-guided catheter ablation of atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2007;18(4):409-14. [pmid: 17284262].
68 Tang RB, Dong JZ, Liu XP, et al. Safety and efficacy of catheter ablation of atrial fibrillation in patients with diabetes mellitus—single center experience. Journal of Interventional Cardiac Electrophysiology. 2006;17:41-46. [pmid: 17235682].
69 Tao H, Liu X, Dong J, et al. Predictors of very late recurrence of atrial fibrillation after circumferential pulmonary vein ablation.[erratum appears in Clin Cardiol 2008 Nov;31(11):559 Note: Tao, Hailong [added]]. Clinical Cardiology. 2008;31(10):463-8. [pmid: 18855350].
70 Verma A, Patel D, Famy T, et al. Efficacy of adjuvant anterior left atrial ablation during intracardiac echocardiography-guided pulmonary vein antrum isolation for atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2007;18:151-156. [pmid: 17338763].
71 Zhou JM, Liu SW, Lin JX, et al. Thromboembolic event rate in patients with persistent or paroxysmal atrial fibrillation post circumferential pulmonary vein isolation: a single center experience in China. Chinese Medical Journal. 2007;120:956-959. [pmid: 17624261].
72 Haissaguerre M, Sanders P, Hocini M, et al. Changes in atrial fibrillation cycle length and inducibility during catheter ablation and their relation to outcome. Circulation. 2004;109:3007-3013. [pmid: 15184286].
73 Hocini M, Jais P, Sanders P, et al. Techniques, evaluation, and consequences of linear block at the left atrial roof in paroxysmal atrial fibrillation: a prospective randomized study. Circulation. 2005;112:3688-3696. [pmid: 16344401].
74 Karch MR, Zrenner B, Deisenhofer I, et al. Freedom from atrial tachyarrhythmias after catheter ablation of atrial fibrillation: a randomized comparison between 2 current ablation strategies. Circulation. 2005;111:2875-2880. [pmid: 15927974].
75 Liu X, Long D, Dong J, et al. Is circumferential pulmonary vein isolation preferable to stepwise segmental pulmonary vein isolation for patients with paroxysmal atrial fibrillation?. Circulation Journal. 2006;70:1392-1397. [pmid: 17062959].
76 Oral H, Chugh A, Lemola K, et al. Noninducibility of atrial fibrillation as an end point of left atrial circumferential ablation for paroxysmal atrial fibrillation: a randomized study. Circulation. 2004;110:2797-2801. [pmid: 15505091].
77 Oral H, Chugh A, Good E, et al. Randomized comparison of encircling and nonencircling left atrial ablation for chronic atrial fibrillation. Heart Rhythm. 2005;2:1165-1172. [pmid: 16253904].
78 Sheikh I, Krum D, Cooley R, et al. Pulmonary vein isolation and linear lesions in atrial fibrillation ablation. Journal of Interventional Cardiac Electrophysiology. 2006;17:103-109. [pmid: 17318445].
79 Wazni O, Marrouche NF, Martin DO, et al. Randomized study comparing combined pulmonary vein-left atrial junction disconnection and cavotricuspid isthmus ablation versus pulmonary vein-left atrial junction disconnection alone in patients presenting with typical atrial flutter and atrial fibrillation. Circulation. 2003;108:2479-2483. [pmid: 14610012].
80 Willems S, Klemm H, Rostock T, et al. Substrate modification combined with pulmonary vein isolation improves outcome of catheter ablation in patients with persistent atrial fibrillation: a prospective randomized comparison. European Heart Journal. 2006;27:2871-2878. [pmid: 16782716].
81 Wang XH, Liu X, Sun YM, et al. Pulmonary vein isolation combined with superior vena cava isolation for atrial fibrillation ablation: a prospective randomized study. Europace. 2008;10:600-605. [pmid: 18442966].
82 Mantovan R, Verlato R, Calzolari V, et al. Comparison between anatomical and integrated approaches to atrial fibrillation ablation: adjunctive role of electrical pulmonary vein disconnection. Journal of Cardiovascular Electrophysiology. 2005;16:1293-1297. [pmid: 16403059].
83 Pak HN, Kim JS, Shin SY, et al. Is empirical four pulmonary vein isolation necessary for focally triggered paroxysmal atrial fibrillation? Comparison of selective pulmonary vein isolation versus empirical four pulmonary vein isolation. Journal of Cardiovascular Electrophysiology. 2008;19:473-479. [pmid: 18284506].
84 Arruda M, Mlcochova H, Prasad SK, et al. Electrical isolation of the superior vena cava: an adjunctive strategy to pulmonary vein antrum isolation improving the outcome of AF ablation. Journal of Cardiovascular Electrophysiology. 2007;18:1261-1266. [pmid: 17850288].
85 Shah DC, Sunthorn H, Burri H, et al. Evaluation of an individualized strategy of cavotricuspid isthmus ablation as an adjunct to atrial fibrillation ablation. Journal of Cardiovascular Electrophysiology. 2007;18:926-930. [pmid: 17655668].
86 Dong JZ, Liu XP, Long DY, et al. Impact of different ablation strategies on the delayed cure after trans-catheter ablation for treating patients with atrial fibrillation. Chinese Medical Journal. 2005;118:1150-1155. [pmid: 16117858].
87 Hachiya H, Hirao K, Takahashi A, et al. Clinical implications of reconnection between the left atrium and isolated pulmonary veins provoked by adenosine triphosphate after extensive encircling pulmonary vein isolation. Journal of Cardiovascular Electrophysiology. 2007;18:392-398. [pmid: 17286569].
88 Lemola K, Ting M, Gupta P, et al. Effects of two different catheter ablation techniques on spectral characteristics of atrial fibrillation. Journal of the American College of Cardiology. 2006;48:340-348. [pmid: 16843185].
89 Mansour M, Ruskin J, Keane D. Efficacy and safety of segmental ostial versus circumferential extra-ostial pulmonary vein isolation for atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2004;15:532-537. [pmid: 15149421].
90 Matsuo S, Yamane T, Date T, et al. Reduction of AF recurrence after pulmonary vein isolation by eliminating ATP-induced transient venous re-conduction. Journal of Cardiovascular Electrophysiology. 2007;18:704-708. [pmid: 17506857].
91 Okada T, Yamada T, Murakami Y, et al. Prevalence and severity of left atrial edema detected by electron beam tomography early after pulmonary vein ablation. Journal of the American College of Cardiology. 2007;49:1436-1442. [pmid: 17397672].
92 Schwartzman D, Bazaz R, Nosbisch J. Catheter ablation to suppress atrial fibrillation: evolution of technique at a single center. Journal of Interventional Cardiac Electrophysiology. 2003;9:295-300. [pmid: 14574043].
93 Tamborero D, Mont L, Nava S, et al. Incidence of pulmonary vein stenosis in patients submitted to atrial fibrillation ablation: a comparison of the Selective Segmental Ostial Ablation vs the Circumferential Pulmonary Veins Ablation. Journal of Interventional Cardiac Electrophysiology. 2005;14:21-25. [pmid: 16311935].
94 Walczak F, Szumowski L, Urbanek P, et al. Selective ablation or isolation of all pulmonary veins in atrial fibrillation—when and for whom?. Kardiologia Polska. 2006;64:26-35. [pmid: 16444625].
95 Yamane T, Date T, Kanzaki Y, et al. Segmental pulmonary vein antrum isolation using the "large-size" lasso catheter in patients with atrial fibrillation. Circulation Journal. 2007;71:753-760. [pmid: 17457004].
96 Richter B, Gwechenberger M, Socas A, et al. Frequency of recurrence of atrial fibrillation within 48 hours after ablation and its impact on long-term outcome. American Journal of Cardiology. 2008;101:843-847. [pmid: 18328850].
97 Katritsis D, Ellenbogen KA, Giazitzoglou E, et al. Clinical outcome of left atrial ablation for paroxysmal atrial fibrillation is related to the extent of radiofrequency ablation. Journal of Interventional Cardiac Electrophysiology. 2008;22:31-37. [pmid: 18363086].
98 Kettering K, Weig HJ, Busch M, et al. Segmental pulmonary vein ablation: success rates with and without exclusion of areas adjacent to the esophagus. Pacing & Clinical Electrophysiology. 2008;31:652-659. [pmid: 18507536].
99 Kanj MH, Wazni O, Fahmy T, et al. Pulmonary vein antral isolation using an open irrigation ablation catheter for the treatment of atrial fibrillation: a randomized pilot study. Journal of the American College of Cardiology. 2007;49:1634-1641. [pmid: 17433955].
100 Kistler PM, Rajappan K, Harris S, et al. The impact of image integration on catheter ablation of atrial fibrillation using electroanatomic mapping: a prospective randomized study. European Heart Journal. 2008;29(24):3029-36. [pmid: 18931059].
101 Marrouche NF, Guenther J, Segerson NM, et al. Randomized comparison between open irrigation technology and intracardiac-echo-guided energy delivery for pulmonary vein antrum isolation: procedural parameters, outcomes, and the effect on esophageal injury. Journal of Cardiovascular Electrophysiology. 2007;18:583-588. [pmid: 17490437].
102 Rotter M, Takahashi Y, Sanders P, et al. Reduction of fluoroscopy exposure and procedure duration during ablation of atrial fibrillation using a novel anatomical navigation system. European Heart Journal. 2005;26(14):1415-21. [pmid: 15741228].
103 Tondo C, Mantica M, Russo G, et al. A new nonfluoroscopic navigation system to guide pulmonary vein isolation. Pacing & Clinical Electrophysiology. 2005;28:Suppl-5.
104 Wang XH, Liu X, Sun YM, et al. Early identification and treatment of PV re-connections: role of observation time and impact on clinical results of atrial fibrillation ablation. Europace. 2007;9:481-486. [pmid: 17522081].
105 Piorkowski C, Kottkamp H, Gerds-Li JH, et al. Steerable sheath catheter navigation for ablation of atrial fibrillation: a case-control study. Pacing & Clinical Electrophysiology. 2008;31:863-873. [pmid: 18684284].
106 Estner HL, Deisenhofer I, Luik A, et al. Electrical isolation of pulmonary veins in patients with atrial fibrillation: reduction of fluoroscopy exposure and procedure duration by the use of a non-fluoroscopic navigation system (NavX). Europace. 2006;8:583-587. [pmid: 16831837].
107 Nilsson B, Chen X, Pehrson S, et al. The effectiveness of a high output/short duration radiofrequency current application technique in segmental pulmonary vein isolation for atrial fibrillation. Europace. 2006;8:962-965. [pmid: 17043070].
108 Marrouche NF, Martin DO, Wazni O, et al. Phased-array intracardiac echocardiography monitoring during pulmonary vein isolation in patients with atrial fibrillation: impact on outcome and complications. Circulation. 2003;107:2710-2716. [pmid: 12756153].
109 Saad EB, Marrouche NF, Saad CP, et al. Pulmonary vein stenosis after catheter ablation of atrial fibrillation: emergence of a new clinical syndrome[see comment][summary for patients in Ann Intern Med 2003 Apr 15;138(8):1; PMID: 12693916]. Annals of Internal Medicine. 2003;138:634-638. [pmid: 12693885].
110 Yamada T, Murakami Y, Okada T, et al. Can segmental pulmonary vein ablation reduce the recurrence of atrial fibrillation when using a higher RF power, larger tip electrode catheter, and additional RF deliveries?: the limitations of point-by-point RF ablation. International Heart Journal. 2006;47:219-228. [pmid: 16607049].
111 Yamane T, Shah DC, Jais P, et al. Electrogram polarity reversal as an additional indicator of breakthroughs from the left atrium to the pulmonary veins. Journal of the American College of Cardiology. 2002;39:1337-1344. [pmid: 11955852].
112 Wang XH, Shi HF, Sun YM, et al. Circumferential pulmonary vein isolation: the role of key target sites. Europace. 2008;10:197-204. [pmid: 18256124].
113 Khaykin Y, Marrouche NF, Saliba W, et al. Pulmonary vein antrum isolation for treatment of atrial fibrillation in patients with valvular heart disease or prior open heart surgery. Heart Rhythm. 2004;1:33-39. [pmid: 15851113].
114 Forleo GB, Tondo C, De LL, et al. Gender-related differences in catheter ablation of atrial fibrillation. Europace. 2007;9:613-620. [pmid: 17636302].
115 Rotter M, Jais P, Garrigue S, et al. Clinical predictors of noninducibility of sustained atrial fibrillation after pulmonary vein isolation. Journal of Cardiovascular Electrophysiology. 2005;16:1298-1303. [pmid: 16403060].
116 Bertaglia E, Stabile G, Senatore G, et al. Predictive value of early atrial tachyarrhythmias recurrence after circumferential anatomical pulmonary vein ablation. Pacing & Clinical Electrophysiology. 2005;28:366-371. [pmid: 15869666].
117 Liu XP, Long DY, Dong JZ, et al. Recurrent atrial tachycardia and atrial fibrillation after circumferential pulmonary vein ablation: what's the difference?. Chinese Medical Journal. 2005;118:1773-1778. [pmid: 16336813].
118 Turco P, De SA, La RV, et al. Antiarrhythmic drug therapy after radiofrequency catheter ablation in patients with atrial fibrillation.[erratum appears in Pacing Clin Electrophysiol 2007 Nov;30(11):1424]. Pacing & Clinical Electrophysiology. 2007;30(Suppl 1):S112-5. [pmid: 17302684].
119 Ma J, Tang K, Ma FS, et al. Linear ablation of left atrium for the treatment of atrial fibrillation guided by double Lasso catheters and three dimensional electroanatomical mapping. Chinese Medical Journal. 2006;119:2042-2048. [pmid: 17199954].
120 Tondo C, Mantica M, Russo G, et al. Pulmonary vein vestibule ablation for the control of atrial fibrillation in patients with impaired left ventricular function. Pacing & Clinical Electrophysiology. 2006;29:962-970. [pmid: 16981920].
121 Kistler PM, Ho SY, Rajappan K, et al. Electrophysiologic and anatomic characterization of sites resistant to electrical isolation during circumferential pulmonary vein ablation for atrial fibrillation: a prospective study. Journal of Cardiovascular Electrophysiology. 2007;18:1282-1288. [pmid: 17916142].
122 Tang K, Ma J, Zhang S, et al. A randomized prospective comparison of CartoMerge and CartoXP to guide circumferential pulmonary vein isolation for the treatment of paroxysmal atrial fibrillation. Chinese Medical Journal. 2008;121:508-512. [pmid: 18364135].
123 Kilicaslan F, Verma A, Yamaji H, et al. The need for atrial flutter ablation following pulmonary vein antrum isolation in patients with and without previous cardiac surgery. Journal of the American College of Cardiology. 2005;45:690-696. [pmid: 15734612].
124 Wazni OM, Beheiry S, Fahmy T, et al. Atrial fibrillation ablation in patients with therapeutic international normalized ratio: comparison of strategies of anticoagulation management in the periprocedural period. Circulation. 2007;116:2531-2534. [pmid: 17998456].
125 Kilicaslan F, Verma A, Saad E, et al. Transcranial Doppler detection of microembolic signals during pulmonary vein antrum isolation: implications for titration of radiofrequency energy. Journal of Cardiovascular Electrophysiology. 2006;17:495-501. [pmid: 16684021].
126 Corrado A, Patel D, Riedlbauchova L, et al. Efficacy, safety, and outcome of atrial fibrillation ablation in septuagenarians. Journal of Cardiovascular Electrophysiology. 2008;19:807-811. [pmid: 18363688].
127 Lakkireddy D, Patel D, Ryschon K, et al. Safety and efficacy of radiofrequency energy catheter ablation of atrial fibrillation in patients with pacemakers and implantable cardiac defibrillators. Heart Rhythm. 2005;2:1309-1316. [pmid: 16360082].
128 Li XP, Dong JZ, Liu XP, et al. Predictive value of early recurrence and delayed cure after catheter ablation for patients with chronic atrial fibrillation. Circulation Journal. 2008;72:1125-1129. [pmid: 18577822].
129 Hsu LF, Jais P, Hocini M, et al. Incidence and prevention of cardiac tamponade complicating ablation for atrial fibrillation. Pacing & Clinical Electrophysiology. 2005;28:Suppl-9.
130 MacLe L, Jais P, Weerasooriya R, et al. Irrigated-tip catheter ablation of pulmonary veins for treatment of atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2002;13:1067-1073. [pmid: 12475093].
131 Hsu LF, Jais P, Sanders P, et al. Catheter ablation for atrial fibrillation in congestive heart failure. New England Journal of Medicine. 2004;351:2373-2383. [pmid: 15575053].
132 Berkowitsch A, Neumann T, Ekinci O, et al. A decrease in pulmonary vein diameter after radiofrequency ablation predicts the development of severe stenosis. Pacing & Clinical Electrophysiology. 2005;28:Suppl-5.
133 Thomas L, Thomas SP, Hoy M, et al. Comparison of left atrial volume and function after linear ablation and after cardioversion for chronic atrial fibrillation. American Journal of Cardiology. 2004;93:165-170. [pmid: 14715341].
134 Zado E, Callans DJ, Riley M, et al. Long-term clinical efficacy and risk of catheter ablation for atrial fibrillation in the elderly. Journal of Cardiovascular Electrophysiology. 2008;19:621-626. [pmid: 18462325].
135 Sauer WH, Alonso C, Zado E, et al. Atrioventricular nodal reentrant tachycardia in patients referred for atrial fibrillation ablation: response to ablation that incorporates slow-pathway modification. Circulation. 2006;114:191-195. [pmid: 16831982].
136 Gerstenfeld EP, Sauer W, Callans DJ, et al. Predictors of success after selective pulmonary vein isolation of arrhythmogenic pulmonary veins for treatment of atrial fibrillation. Heart Rhythm. 2006;3:165-170. [pmid: 16443531].
137 Oral H, Chugh A, Good E, et al. A tailored approach to catheter ablation of paroxysmal atrial fibrillation. Circulation. 2006;113:1824-1831. [pmid: 16606789].
138 Bertaglia E, Zoppo F, Tondo C, et al. Early complications of pulmonary vein catheter ablation for atrial fibrillation: a multicenter prospective registry on procedural safety. Heart Rhythm. 2007;4:1265-1271. [pmid: 17905330].
139 Gerstenfeld EP, Callans D, Dixit S, et al. Characteristics of patients undergoing atrial fibrillation ablation: trends over a seven-year period 1999-2005. Journal of Cardiovascular Electrophysiology. 2007;18:23-28. [pmid: 17081205].
140 Spragg DD, Dalal D, Cheema A, et al. Complications of catheter ablation for atrial fibrillation: incidence and predictors. Journal of Cardiovascular Electrophysiology. 2008;19:627-631. [pmid: 18462327].
141 Oral H, Chugh A, Good E, et al. Radiofrequency catheter ablation of chronic atrial fibrillation guided by complex electrograms. Circulation. 2007;115:2606-2612. [pmid: 17502567].
142 Noheria A, Kumar A, Wylie JV Jr, et al. Catheter ablation vs antiarrhythmic drug therapy for atrial fibrillation: a systematic review. Arch Intern Med. 2008;168:581-586. [pmid: 18362249].