# Acknowledgments

The Evidence-based Practice Center thanks Audrey Mahoney for her assistance with article retrieval and final preparations of this report.

## Technical Expert Panel

Hugh Calkins, M.D., Johns Hopkins Hospital, Baltimore, MD

Kenneth Ellenbogen, M.D., Virginia Commonwealth University, Richmond, VA

Mark A. Hlatky, M.D., Stanford University, Palo Alto, CA

Francis E. Marchlinski, M.D., Hospital of the University of Pennsylvania, Philadelphia, PN

Douglas A. Packer, M.D., Mayo Clinic, Rochester, MN

Albert L. Waldo, M.D., Case Western Reserve University, Cleveland, OH

## EPC Program Director

Joseph Lau, M.D.

Tufts Medical Center

## AHRQ Contacts

- Beth A. Collins Sharp, Ph.D., R.N.
- Director
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD

- Artyom Sedrakyan, M.D. Ph.D.
- Task Order Officer
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD

- Elise Berliner, Ph.D.
- Task Order Officer
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD