# Discussion

A summary of the studies reviewed for this report is given in Table 22.

Table 22 Summary of reviewed studies: radiofrequency catheter ablation for atrial fibrillation

Comparisons | Study type | Studies, n (references) | Number of studies by quality^a^ | | | Number of patients
Good | Fair | Poor
Radiofrequency ablation vs. open surgical procedures
| Any | 0
Radiofrequency ablation vs. antiarrhythmic drugs
First-line therapy | RCT | 1 | | 1 | | 70
Second-line therapy | RCT | 5 | | 4 | 1 | 623
| Non-RCS | 2 | | | 2 | 1,341
Comparison of various radiofrequency ablation techniques
PVI vs. WACA | RCT | 5 | | 4 | 1 | 500
RFA with or without additional left-sided ablation lines | RCT | 6 | | 4 | 2 | 1,069
PVI vs. PVI with right-sided lines | RCT | 2 | | 1 | 1 | 214
8 mm vs. closed irrigated tip catheter | RCT | 2 | 2 | | | 91
8 mm vs. open irrigated tip catheter | RCT | 2 | | 2 | | 233
| nonRCS | 1 | | | 1 | 221
Different imaging modalities | RCT | 5 | | 3 | 2 | 340
| nonRCS | 3 | | | 3 | 330
Miscellaneous comparisons | RCT, nonRCS, cohort | 33 | | 4 | 29 | 4,854
Predictors of recurrence of atrial fibrillation
Multivariable analyses | Any | 25 | 3 | 9 | 13 | 6,747
Atrial fibrillation type (univariable analyses) | Any | 31 | 2 | 6 | 23 | 7,412
Adverse events
| ^b^Cohort | 100 | Quality not rated | | | ^c^≤20,000

a Quality ratings:

- Good Studies that have the least bias and results that are considered valid. Studies that mostly adhere to the commonly held concepts of high quality including the following: a formal randomized controlled design; clear description of the sample, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; < 20% dropout rate; clear reporting of dropouts; and no obvious bias. Studies rated “good” must have reported the atrial fibrillation recurrence rate off anti-arrhythmic drugs after the initial radiofrequency catheter ablation. Only randomized controlled trials could receive a “good” grade.
- Fair Studies are susceptible to some bias that is not sufficient to invalidate the results. They do not meet all the criteria in the “good” category because they have some deficiencies, but none likely to cause major bias. The studies may be missing information, making it difficult to assess limitations and potential problems.
- Poor Studies have significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting. All retrospective studies were graded “poor.”

b The radiofrequency catheter ablation groups in 6 randomized controlled trials and 2 nonrandomized comparative studies comparing catheter ablation with medical treatment were analyzed as cohorts.

c It is likely that some patients were included in multiple studies from the same centers.

Abbreviations: non-RCS=nonrandomized comparative study; PVI=pulmonary vein isolation; RCT=randomized controlled trial; RFA=radiofrequency catheter ablation; WACA, wide area circumferential ablation.

## Key Question 1: Medical Treatment Versus Radiofrequency Ablation (RFA)

There is a moderate level of evidence to show that patients who received RFA as a second-line therapy (i.e., in patients who did not respond to medical therapy) had a higher chance of maintaining sinus rhythm compared to those treated with medical therapy alone (relative risk (RR) 3.46, 95% CI 1.97–6.09) at 12 months postprocedure. This finding is in general agreement with a previously published metaanalysis. ^142^ We did not find a statistically significant difference in the risk of cerebrovascular events in patients who were treated with RFA compared to those treated with medical therapy. However, clinically meaningful differences could not be excluded because the event rates were small and studies were not powered to detect such small differences.

There were insufficient data to draw meaningful conclusions concerning RFA use as a first-line therapy for rhythm control (i.e., in patients who have never been treated with antiarrhythmic drugs (AADs)).

## Key Question 2: Patient- and Intervention-Level Characteristics Associated with Rhythm Control

There is low level of evidence to show that atrial fibrillation (AF) type, namely nonparoxysmal AF, is predictive of a higher rate of AF recurrence. Although metaanalyses of univariable analyses support an association (RR about 1.6 suggesting more recurrence with nonparoxysmal AF), the studies were clinically and statistically heterogeneous, and more importantly, only six of 17 multivariable analyses bear this out, with hazard ratios ranging from 1.1 to 22 (favoring paroxysmal AF).

There is a moderate level of evidence to show that among patients with approximately normal ejection fraction (EF) or left atrial diameter (LAD), these parameters are not independent predictors of AF recurrence; however, there is insufficient evidence to estimate the predictive value of abnormal EF or LAD on recurrence rates. There is a high level of evidence to show that sex, AF duration, and the presence of structural heart disease are not associated with AF recurrence. Among patients between approximately 40 and 70 years of age, there is a high level of evidence to show that age is not associated with AF recurrence; however, the evidence is insufficient to estimate the predictive value of young or very old age. There is insufficient evidence for other potential predictors of AF recurrence.

## Key Question 3: Approaches and Technical Issues Concerning RFA

### Approaches to RFA

There is a moderate level of evidence to show that wide-area circumferential ablation (WACA) resulted in a higher rate of freedom from AF recurrence compared to ostial pulmonary vein isolation (PVI) (absolute difference: ~20%) in patients with either paroxysmal AF or persistent AF.

It is unclear whether the addition of left sided ablation lines to PVI increases the freedom from AF recurrence compared to PVI alone. Three studies found that the addition of left sided lines in RFA increased the freedom from AF recurrence compared to RFA alone, and two studies did not find significant differences. The heterogeneity of the different types of additional left sided ablation lines may have precluded meaningful comparisons among the studies.

One study found that adding a cavotricuspid isthmus ablation line to PVI in patients with persistent or permanent AF and a history of atrial flutter did not result in a significantly lower recurrence of AF. The limited evidence does not allow us to draw definitive conclusions.

Retrospective studies have limitations in the comparability among groups. The majority of the studies used historical (non-concurrent) controls. The proportions of patients with different types of AF were different between groups in many comparisons. None of the studies adjusted for potential confounders. It is not possible to draw conclusions from this group of studies.

### Technical Issues Related to RFA

There is a moderate level of evidence suggesting no differences in using the 8 mm tip catheter or an irrigated tip catheter for RFA in long-term rhythm control in patients with AF. Furthermore, there is a low level of evidence suggesting no differences in rhythm control in patients with drug refractory AF comparing different imaging modalities used during RFA.

There were insufficient data to draw conclusions regarding the outcomes of PVI for AF comparing different energy outputs, mapping techniques, or ablation times.

## Key Question 4: Adverse Events Associated with RFA

There is a low level of evidence suggesting major adverse events associated with RFA are relatively uncommon. The level of evidence was rated low because the studies reviewed employed nonuniform definitions and assessments of adverse events, with sample sizes generally less than 100, and incomplete reporting. While there is no doubt that certain adverse events are uniquely associated with the use of RFA (e.g., atrioesophageal fistula), the limitations cited precluded accurate estimates of those adverse event rates. Asymptomatic PV stenosis, cardiac tamponade, and cerebrovascular events were reported at rates of 4% or less in the majority of the studies. Symptomatic PV stenosis was reported at rates of 1% or less. Four studies reported rates of atrioesophageal fistula ranging from 0.1% to 0.9%. A total of five deaths were reported in all the studies reviewed (one patient died from a pulmonary infection, one died from anaphylaxis after the procedure, and three died from atrioesophageal fistulas (three publications from the same group of investigators each reported one death from atrioesophageal fistula). However, it is difficult to compare the rates of adverse events across studies as the descriptions of the various adverse events were not always comparable. For example, even though the presence of PV stenosis was generally evaluated at around 3 months post-RFA, severe and moderate PV stenoses were defined differently across studies. Some clearly reported stroke as periprocedural, and some reported stroke without stating a time of occurrence. Also, it was not always made clear whether the lack of information on a particular adverse event meant zero events (i.e., the researchers systematically ascertained for it and found none) or it was simply not spontaneously reported. In addition, the sample sizes in most RCTs and comparative studies were generally small, precluding reliable risk estimates of the adverse events. Furthermore, many of the studies had a mean followup of no more than 12 months, any long term events like late AF recurrence or mortality or delayed adverse effects from radiation exposure could not be properly assessed from this group of studies.