# Results

The MEDLINE^®^ and Cochrane Central database search yielded 2,169 citations. We identified 390 of these as potentially relevant and retrieved the full-text articles for further evaluation. Of these, 270 did not meet eligibility criteria. A total of 120 studies were included in our analyses. (Figure 2)

Figure 2. Literature flow diagram

RFA, radiofrequency ablation.

*There are overlaps of studies between key questions

**See Appendix B for detailed rejection reasons

## Key Question 1. What is the effect of RFA on short-term (6 to 12 months) and long-term (>12 months) rhythm control, rates of congestive heart failure, left atrial and ventricular size changes, rates of stroke, quality of life, avoiding anticoagulation, and readmissions for persistent, paroxysmal, and longstanding persistent (chronic) atrial fibrillation?

### RFA Versus Open Surgical Procedures

No study compared RFA with an open surgical procedure.

### RFA Versus Medical Therapy (Table 1)

Randomized controlled trials (RCTs). Six RCTs enrolling a total of 693 patients with atrial fibrillation (AF) compared radiofrequency ablation (RFA) with medical therapy. ^23^ – ^28^ Sample sizes ranged from 30 to 198. One trial compared RFA as first line therapy to antiarrhythmic drugs (AADs), ^24^ while the other four trials included patients who had failed at least one AAD. One study ^27^ included only patients with symptomatic paroxysmal AF (PAF) and one study ^26^ focused only on patients with chronic AF. ^b^ The other three RCTs included patients with PAF and those with persistent AF (patients with PAF ranged from 67% to 96%).

b Chronic AF was defined as AF that had been present for more than six months without intervening spontaneous episodes of sinus rhythm and that recurred within one week after cardioversion.

Table 1 Characteristics of comparative studies of RFA vs. AAD

Author Year Country UI | Intervention(s) | Ancillary Ablations | Catheter Tip | PVI (yes/no) | Checked inducibility (yes/no) | N enrolled | Enrollment Years | % PAF | Mean Age, yr | Male, % | Mean LAD, cm | Mean LVEF, % | Mean Symptom Duration, yr
Randomized controlled trials
First-line therapy
Wazni 2005 ^24^ Germany & Italy 15928285 | AAD (flecainide, sotalol, or propafenone)^a^ | | | | | 37 | 2001-2002 | 96 | 54 | nd | nd | 54 | 0.4
RFA (PVI) | None | 8 mm | Yes | No | 33
Second-line therapy
Krittayaphong 2003 ^23^ Thailand 12866763 | Amiodarone^b^ | | | | | 15 | nd | 67 | 52 | 63 | 3.9 | 63 | 4.7
RFA (WACA)^c^ | - WACA + mitral line (LA); - Cavotricuspid isthmus line, SVC-IVC, and mid RA horizontal line (RA) | 8 mm | No | No | 15
Stabile 2006 ^25^ Italy 16214831 | AAD (amiodarone, flecainide, propafenone, or etc.)^d^ | | | | | 69 | 2002-2003 | 67 | 62 | 57 | 4.6 | 58 | 6.1
RFA (CPVA) plus AAD^e^ | - Circumferential lines around each PV and mitral isthmus line (LA); - Cavotricuspid isthmus line (RA)^f^ | 8 mm or 3.5 mm cooled^g^ | Yes | No | 68
Oral 2006 ^26^ US & Italy 16510747 | Amiodarone^h^ | | | | | 69 | 2002-2004 | 0^i^ | 56 | 65 | 4.5 | 55 | 4.5
RFA (LACA)^j^ | - Encircling lesions of PVs, Roof line, and mitral isthmus line (LA); - Cavotricuspid isthmus line (RA)^k^ | 8 mm | Yes | No | 77
Pappone 2006 ^27^ Italy 17161267 | AAD (Flecainide, sotalol, or amiodarone)^l^ | | | | | 99 | 2005 | 100 | 56 | 67 | 3.9 | 61 | 6
RFA (CPVA)^m^ | - Circumferential lines around each PV (LA); - Cavotricuspid isthmus line (RA) | 8 mm or 3.5 mm irrigated^n^ | No | No | 99
Jais 2008 ^28^ France, US, & Canada 19029470 | AAD (Amiodarone, quinidine, disopyramide, or etc.)^o^ | | | | | 53 | nd | 100 | 51 | 84 | 4.0 | 64 | 5.5 (median)
RFA (CPVA)^p^ | - Roof and Mitral isthmus lines (LA); - Cavo-Tricuspid Isthmus line (RA); - Targeted Foci | 3.5- or 5-mm irrigated | Yes | No | 59
Nonrandomized comparative trials
Second-line therapy
Pappone 2003 ^29^ Italy 12875749 | AAD | | | | | 582 | 1998-2001 | 70 | 65 | 58 | 4.6 | 54 | 4.6^q^
RFA (CPVA)^r^ | nd | nd | Yes | No | 589
Rossillo 2008 ^30^ Italy 18268419 | AAD | | | | | 85 | 2002-2004 | 16^s^ | 62 | 84 | 4.3 | 57 | 8^t^
RFA (PVI) | - SVC isolation (RA) | 8 mm | Yes | No | 85

AAD, anti-arrhythmic drug; CPVA, Circumferential pulmonary vein ablation; IVC, inferior vena cava; LA, LACA, left atrial catheter ablation; left atrium; LAD, left atrial diameter; LVEF, left ventricular ejection fraction; nd, no data; PAF, paroxysmal atrial fibrillation; PV, pulmonary vein; PVI, pulmonary vein isolation; RA, right atrium; RFA, radiofrequency ablation; SVC, superior vena cava; WACA, wide area circumferential ablation

a Maximum tolerable dose was set as follows: flecainide 100–150 mg, sotalol 120–160 mg bid, and propafeonone 225–300 mg tid.

b Loading dose: 1200 mg everyday for 1 week and then 600 mg everyday for 2 weeks. Maintenance dose: 200 mg everyday.

c Amiodarone 200mg everyday was prescribed for 3 months after the procedure.

d Amiodarone. A class IC anti-arrhythmic was used if patients had a history of side effects or intolerance to amiodarone. Dosing schedule not provided in detail; mean daily dose was as follows: amiodarone 209 mg, flecainide 191 mg, propafenone 750mg, sotalol 184 mg, and disopyramide 500mg.

e AAD was prescribed concurrently and continued during the entire study period as combined modality therapy.

f Only if the conduction in this region was detected.

g 8 mm tip catheter was used in the first 17 patients, and was replaced with 3.5 mm cooled-tip catheter in the remaining patients.

h Amiodarone 200 mg everyday was terminated at 3 months.

i All patients had chronic AF, which was defined as AF that had been present for more than six months without intervening spontaneous episodes of sinus rhythm and that recurred within one week after cardioversion.

j Amiodarone 200 mg everyday was prescribed for 3 mos after the procedure.

k Performed in 55 patients at the discretion of the operators.

l Flecainide 100 mg bid; sotalol 80 mg tid; or amiodarone 200 mg/day (maintenance dose)

m AAD was prescribed for 6 weeks after the procedure.

n 8 mm tip catheter was used in the first 50 patients, and was replaced with 3.5 mm cooled-tip catheter in the remaining patients.

o Amiodarone, quinidine, disopyramide, flecainide, propafenone, cibenzoline, dofetilide, and sotalol. Up to 3 attempts for alterations or modifications of pharmacologic therapy were allowed until 90 days from randomization.

p Up to 2 repeat ablations were allowed until 90 days from randomization. Also, additional ablations were performed at the discretion of the treating physicians: roof line (17%), mitral isthmus line (30%), cavo-tricuspid Isthmus line (64%), and targeted foci (23%).

q 5.5 years for RFA group and 3.6 years for AAD group (P<0.001).

r AAD was prescribed for 3 months in 115 patients (20%) who had in-hospital AF and/or needed cardioversion to terminate AF after the procedure.

s No patients in AAD group had paroxysmal AF.

t No data available for AAD group.

Although techniques employed for RFA varied across studies, all studies targeted the pulmonary veins (PVs). Post-RFA AAD use varied both within and between studies. One RCT ^24^ compared patients who had RFA with patients who had taken AADs continuously as a first-line therapy. Three second-line therapy trials ^23,^ ^27,^ ^28^ compared patients treated with RFA followed by up to 3 months postprocedure AADs to patients who had taken AADs continuously. In another second-line therapy RCT, ^25^ comparison was made between patients who underwent RFA and then received AADs continuously throughout the study period with patients who had taken AADs continuously. One study permitted reablations within 3 months postprocedure in the RFA arm and modifications of AADs in the medical therapy arm. ^28^ One second-line trial ^26^ compared patients treated with amiodarone for 3 months after RFA to those treated with 3 months of amiodarone alone. This study also permitted reablation beyond the 3-month period in the RFA arm and crossover salvage ablation in the medical therapy arm.

The methodological quality of five studies was rated fair and one study was rated poor. Common reasons for downgrading the quality ratings in these studies were suboptimal reporting (e.g., unclear descriptions on the conduct of a trial or discrepancies in reporting of results) or failure to report the rates of AF recurrence after a single ablation while off AADs (i.e., only rates of AF recurrence after multiple ablations and/or remaining on AADs were reported).

Retrospective studies. Two retrospective cohorts ^29,^ ^30^ reported comparisons between RFA and medical treatments in a total of 1,341 patients with AF refractory to at least one AAD. Patients who underwent RFA also received AAD for the first 3 months after the procedure. Methodological quality of these two studies were rated poor. ^29,^ ^30^

### Rhythm Control (Study Duration 6 Months or Greater) (Table 2)

Rhythm control, typically reported as freedom from recurrence of AF or atrial arrhythmias, was described as a primary outcome in all the RCTs and observational studies.

Table 2 Rhythm control in patients who received RFA vs. AAD

Study Year UI | Description | | No. Analyzed | | Outcome | Metric/Units | Results | | | Quality
Interv | Cont | Interv | Cont | Interv | Cont | P Between
Randomized controlled trials
First-line therapy
Wazni 2005 ^24^ Germany & Italy 15928285 | RFA (PVI) | AAD | 32^a^ | 35^b^ | Freedom from AF recurrence at 12 mo | Crude % | 88 | 37 | <0.001 (χ^2^) | Fair
Second-line therapy
Krittayaphong 2003 ^23^ Thailand 12866763 | RFA (WACA) | Amiodarone | 14^c^ | 15 | Freedom from AF recurrence at 12 mo | KM % | 79 | 40 | 0.018 (Log-rank) | Poor
Stabile 2006 ^25^ Italy 16214831 | RFA (CPVA) plus AAD | AAD | 68 | 69 | Freedom from atrial arrhythmias recurrence at 12 mo | Crude % | 56 | 9 | <0.001 (Fisher) | Fair
Stabile 2006 ^25^ Italy 16214831 | RFA (CPVA) plus AAD | AAD | 68 | 69 | Atrial arrhythmias-free survival | KM | nd | nd | <0.001 | Fair
Adj HR | 3.2^d^ | | <0.05
Oral 2006 ^26^ US & Italy 16510747 | RFA (LACA) | Amiodarone | 77 | 69 | Maintaining sinus rhythm at 12 mo^e^ | Crude % | 74 | 4^f^ | <0.001 (χ^2^) | Fair
58^g^ | 0.05 (χ^2^)
Pappone 2006 ^27^ Italy 17161267 | RFA (CPVA) | AAD | 99 | 99 | Atrial tachyarrhythmias-free survival at 12 mo | KM % | 86 | 22 | <0.001 (Log-rank) | Fair
Jais 2008 ^28^ France, US, & Canada 19029470 | RFA (CPVA) | AAD | 52^h^ | 55 | Freedom from AF recurrence beyond d 90 until 12 mo | KM % | 89 | 23 | <0.0001 (Log-rank) | Fair
Retrospective
Second-line therapy
Pappone 2003 ^29^ Italy 12875749 | RFA (CPVA) | AAD | 589 | 582 | AF-free survival at 12 mo | KM % | 84 | 61 | <0.001 (Log-rank) | Poor
Pappone 2003 ^29^ Italy 12875749 | RFA (CPVA) | AAD | 589 | 582 | AF-free survival at 24 mo | KM % | 79 | 47 | <0.001 (Log-rank) | Poor
Pappone 2003 ^29^ Italy 12875749 | RFA (CPVA) | AAD | 589 | 582 | | | | | | Poor
AF-free survival at 36 mo | 78 | 37
AF-free survival | HR | 0.30^i^ | | <0.05
Rossillo 2008 ^30^ Italy 18268419 | RFA (PVI) | AAD | 85 | 85 | Stable sinus rhythm^j^ | Crude % | 82 | 40 | nd | Poor

a One patient was excluded from analysis due to lost to follow-up.

b Two patients were excluded from analysis due to lost to follow-up.

c One patient was excluded from analysis due to procedure-related adverse effects.

d 95%CI, 2.0–5.1.

e Patients who maintained sinus rhythm at 12 months regardless of relapse until this time point.

f For only patients who did not resume AAD or cross over to RFA.

g For patients allocated to AAD (i.e., intention-to-treat analysis).

h These patients underwent a mean of 1.8 (standard deviation of 0.8) procedures (1 to 3; median, 2).

i 95% CI, 0.24–0.37

j At last follow-up: 15 mo for PVI group and 16 mo for AAD group.

AAD, anti-arrhythmic drug; Adj, adjusted; AF, atrial fibrillation; CI, confidence interval; CPVA, circumferential pulmonary vein ablation; HR, hazard ratio; KM, Kaplan-Meier; LACA, left atrial catheter ablation; nd, no data; PVI, pulmonary vein isolation; RFA, radiofrequency ablation; WACA, wide area circumferential ablation

Six RCTs consistently reported statistically significant improved rhythm control at 12 months post-RFA compared to medical therapy. We performed metaanalysis on four RCTs (one first-line and three second-line therapy) involving a total of 431 patients (Figure 3). ^23^ – ^25,^ ^27^ One RCT ^26^ was excluded because it reported the participants' rhythm status only at 12 months postprocedure irrespective of recurrence during the entire followup period. Another RCT ^28^ was also excluded because up to two additional ablations were allowed if patients had AF recurrence during the 3 months postprocedure blanking period. Overall, patients who underwent RFA (either as a first- or second-line therapy) had about a 3-fold higher chance of maintaining sinus rhythm at 12 months compared to those treated with medical therapy (relative risk (RR) 3.09, 95% confidence interval (CI) 2.02–4.73). In a subgroup analysis including three studies that used RFA as a second-line therapy, it was similarly superior to medical treatment (RR 3.46, 95% CI 1.97–6.09). There was no evidence of statistical heterogeneity in treatment effect between first-line and second-line therapy.

Figure 3. Metaanalysis of RR of rhythm control, RFA vs. medical treatment

Legends: Random effects model meta-analyses of relative risk in maintaining sinus rhythm comparing patients who received RFA with patients treated with medical treatment. Diamonds display summary results centered on combined estimates and extending to 95% confidence interval (CI). Squares and lines indicate estimates of means and 95% CI for individual studies. The size of the closed squares is proportional to the weight of each study in the overall Metaanalysis. Studies are ordered by presence of previous therapeutic interventions (i.e., first-line therapy or second-line therapy), then sample size.

AAD, antiarrhythmic drug; RFA, radiofrequency ablation

Rhythm control was also reported in two retrospective studies. ^29,^ ^30^ One found a statistically significant improved AF-free survival for RFA (n=589) compared to medical treatment (n=582) with a mean followup of 30 months (hazard ratio (HR) 0.30, 95% CI 0.24–0.37, P<0.001). ^29^ The other study also found that patients who underwent RFA had improved rhythm control (82%) compared to patients who were on medical treatment (40%) (P value not reported). ^30^

### Rates of Congestive Heart Failure (Table 3)

No RCT examined the incidence of congestive heart failure in RFA versus medical treatment of AF.

Table 3 Congestive heart failure in patients who received RFA vs. AAD

Study Year UI | Description | | No. Analyzed | | Outcome | Metric/Units | Results | | | Quality
Interv | Cont | Interv | Cont | Interv | Cont | P Between
Retrospective
Second-line therapy
Pappone 2003 ^29^ Italy 12875749 | RFA (CPVA) | AAD | 589 | 582 | Developing CHF | Crude %a | 5 | 10 | nd | Poor

AAD, anti-arrhythmic drug; CHF, congestive heart failure; CPVA, circumferential pulmonary vein ablation; RFA, radiofrequency ablation

a The number of patients who developed CHF was originally reported in the literature.

One retrospective study evaluated congestive heart failure as part of adverse events during followup (mean, 30 months) in patients who had RFA compared to patients who had medical treatment. This study found that congestive heart failure developed in 5% of patients who had RFA compared to 10% of patients who had medical treatment although no formal statistical test was performed. ^29^

### Left Atrial and Ventricular Size Changes (Table 4)

One RCT ^28^ evaluated changes in left atrial diameter (LAD), left ventricular end-diastolic diameter (LVED), and left ventricular ejection fraction (EF) in patients with AF treated with RFA versus medical therapy. No statistically significant differences in changes in LAD, LVED, or EF were observed at 1 year followup between RFA and medical treatment.

Table 4 Change in LAD or LVD or LV function in patients who received RFA vs. AAD

Study Year UI | Description | | No. Analyzed | | Outcome | Metric/Units | Results | | | Quality
Interv | Cont | Interv | Cont | Interv | Cont | P Between
Randomized controlled trials
Second-line therapy
Jais 2008 ^28^ France, US, & Canada 19029470 | RFA (CPVA) | AAD | 53 | 59 | LAD at 12 mo | cm | 3.9 | 3.9 | 0.92^a^ (t-test) | Fair
Jais 2008 ^28^ France, US, & Canada 19029470 | RFA (CPVA) | AAD | 53 | 59 | LVED at 12 mo | cm | 5.0 | 5.1 | 0.35^a^ (t-test) | Fair
Jais 2008 ^28^ France, US, & Canada 19029470 | RFA (CPVA) | AAD | 53 | 59 | LVEF at 12 mo | % | 65 | 65 | 0.99^b^ (t-test) | Fair
Retrospective
Second-line therapy
Pappone, 2003 ^29^ Italy 12875749 | RFA (CPVA) | AAD | nd^c^ | nd^c^ | Change in LAD | cm | -0.5 | -0.2 | nd | Poor
nd^d^ | nd^d^ | -1.1 | -0.3

AAD, anti-arrhythmic drug; AF, atrial fibrillation; CPVA, circumferential pulmonary vein ablation; LACA, left atrial catheter ablation; LAD, left atrial diameter; LVD, left ventricular diameter; LVED, left ventricular end-diastolic diameter; LVEF, left ventricular ejection fraction; nd, no data; RFA, radiofrequency ablation

a Difference in size between groups at 12 months was considered. Not net difference between before procedure (baseline) and after 12 months (final) between groups.

b Difference in % between groups at 12 months was considered. Not net difference between before procedure (baseline) and after 12 months (final) between groups.

c Only patients with recurrent AF.

d Only patients without recurrent AF.

A retrospective study reported improvement in LAD in patients who had undergone RFA according to subsequent recurrence following the procedure (no recurrence: -1.1 cm (P<0.01); recurrence: -0.5 cm (P value not reported)) and in patients who had received medical treatment (no recurrence: -0.3 cm (P<0.01); recurrence: -0.2 cm (P value not reported)). ^29^ However, direct statistical comparison between RFA and medical treatment was not performed.

### Rates of Stroke (Table 5)

All six RCTs evaluated stroke as an adverse event. We performed a metaanalysis on the six RCTs (Figure 4). ^23^ – ^27^ Two RCTs ^26,^ ^28^ allowed multiple ablations for patients who relapsed after the first procedure. In our metaanalysis, we considered each patient who underwent at least one RFA (regardless of multiple procedures) to be the unit of analysis. There were no statistically significant differences in stroke rates at 12 months between RFA and medical treatment (range: 0 to +7.1%). All three stroke events in the RFA arm occurred during or just after the procedure. Three studies observed no strokes in both arms. ^24,^ ^26,^ ^28^ The summary risk difference of stroke was 0.6% (95% CI -1.2 to 2.3%; favoring AAD); the RCTs had statistically homogeneous results. The summary risk difference was similar in subgroup analyses of four studies that used RFA as a second-line therapy: 0.7% (95% CI -1.1 to 2.4%; favoring AAD). There was no statistical heterogeneity in risk difference of stroke between first- and second-line therapy. The results were similar when three RCTs with no events in both arms were excluded in sensitivity analysis (Peto odds ratio (OR) 2.80, 95% CI 0.39–19.9; favoring AAD).

Figure 4. Metaanalysis of risk difference of stroke events, RFA vs. medical treatment

Legends: Fixed effects model meta-analyses of risk difference in cerebrovascular events comparing patients who received RFA with patients treated with medical treatment. Diamonds display summary results centered on combined estimates and extending to 95% confidence interval (CI). Squares and lines indicate estimates of means and 95% CI for individual studies. The size of the closed squares is proportional to the weight of each study in the overall Metaanalysis. Studies are ordered by presence of previous therapeutic interventions (i.e., first-line therapy or second-line therapy), then sample size.

AAD, antiarrhythmic drug; RFA, radiofrequency ablation

Table 5 Stroke in patients who received RFA vs. AAD

Study Year UI | Description | | No. Analyzed | | Outcome | Metric/Units | Results | | | Quality
Interv | Cont | Interv | Cont | Interv | Cont | P Between
Randomized controlled trials
First-line therapy
Wazni 2005 ^24^ Germany & Italy 15928285 | RFA (PVI) | AAD | 32^a^ | 35^b^ | Stroke | Crude % | 0 | 0 | nd | Fair
Second-line therapy
Krittayaphong 2003 ^23^ Thailand 12866763 | RFA (WACA) | Amiodarone | 14^c^ | 15 | Stroke | Crude % | 7 | 0 | nd | Poor
Stabile 2006 ^25^ Italy 16214831 | RFA (CPVA) plus AAD | AAD | 68 | 69 | Stroke | Crude % | 1 | 1 | nd | Fair
Oral 2006 ^26^ US & Italy 16510747 | RFA (LACA) | Amiodarone | 77 | 69 | Stroke | Crude % | 0 | 0 | nd | Fair
Pappone 2006 ^27^ Italy 17161267 | RFA (CPVA) | AAD | 99 | 99 | Stroke | Crude % | 1 | 0 | nd | Fair
Jais 2008 ^28^ France, US, & Canada 19029470 | RFA (CPVA) | AAD | 53^d^ | 59 | Stroke | Crude % | 0 | 0 | nd | Fair
Retrospective
Second-line therapy
Pappone 2003 ^29^ Italy 12875749 | RFA (CPVA) | AAD | 589 | 582 | Stroke | Crude % | 2 | 8 | nd | Poor
Rossillo 2008 ^30^ Italy 18268419 | RFA (PVI) | AAD | 85 | 85 | Stroke | Crude % | 1 | 6 | 0.059 (Fisher) | Poor

AAD, anti-arrhythmic drug;CPVA, circumferential pulmonary vein ablation; LACA, left atrial catheter ablation; nd, no data; PVI, pulmonary vein isolation; RFA, radiofrequency ablation; WACA, wide area circumferential ablation

a One patient was excluded from analysis due to lost to follow-up.

b Two patients were excluded from analysis due to lost to follow-up.

c One patient was excluded from analysis due to procedure-related adverse effects.

d These patients underwent a mean of 1.8 (standard deviation of 0.8) procedures (1 to 3; median, 2).

Two observational studies reported higher stroke rates in medical treatment than RFA. During the 30 month followup in one study, 14 patients (2%) in the RFA arm versus 49 patients (8%) in the AAD arm developed stroke (statistical test not performed). ^29^ Similarly, Rossillo et al. found a lower stroke rate in patients who underwent RFA than in patients who had medical treatment (1% vs. 6%, P=0.09) at 16 months. ^30^ Neither study explored the impact of anticoagulation therapy on stroke events.

### Quality of Life (Table 6)

Three RCTs measured quality of life (QoL) using the 36-Item Short-Form General Health Survey (SF-36), which has a range of scores from 0 (worst) to 100 (best). One study found that patients treated with RFA as a second-line therapy had a statistically significant improvement in general health score at 6 and 12 months (+15 and +20, respectively) compared to medical treatment (+6 and +3 respectively, P=0.048). ^23^ It also found a statistically nonsignificant improvement in physical fitness score at 6 and 12 months (+11 and +23, respectively) in the RFA arm compared to the medical treatment arm (+2 and -2 respectively). The RCT that used RFA as a first-line treatment also found that patients in the RFA arm had a statistically significant improvement in general health functioning score and physical functioning score at 6 months (+22 and +26, respectively) compared to patients in the medical treatment arm (+11 and +6, P<0.001 and P=0.001, respectively) while no statistically significant improvement was reported in mental health score. ^24^ Another RCT that used RFA as a second-line therapy also reported patients treated with RFA had better physical component score at 12 months than patients who had medical treatment (within-subject improvement from baseline, +7.2 vs. +6.0, P=0.015), whereas improvement was not significantly different in mental component score between RFA and medical treatment (within-subject improvement from baseline, +9.7 and +9.1, respectively, P=0.09). ^28^

Table 6 Quality of life in patients who received RFA vs. AAD

Study Year UI | Description | | No. Analyzed | | Outcome | Metric/Units | Results | | | Quality
Interv | Cont | Interv | Cont | Interv | Cont | P Between
Randomized controlled trials
First-line therapy
Wazni 2005 ^24^ Germany & Italy 15928285 | RFA (PVI) | AAD | 32^a^ | 35^b^ | SF-36 general health functioning score at 6 mo | ΔScore^b^ | NetΔ = 11 | | <0.001 (ANOVA) | Fair
Wazni 2005 ^24^ Germany & Italy 15928285 | RFA (PVI) | AAD | 32^a^ | 35^b^ | +22 | ΔScore^b^ | +11 | | | Fair
Wazni 2005 ^24^ Germany & Italy 15928285 | RFA (PVI) | AAD | 32^a^ | 35^b^ | SF-36 physical functioning score at 6 mo | ΔScore^b^ | NetΔ = 20 | | 0.001 (ANOVA) | Fair
Wazni 2005 ^24^ Germany & Italy 15928285 | RFA (PVI) | AAD | 32^a^ | 35^b^ | +26 | ΔScore^b^ | +6 | | | Fair
Wazni 2005 ^24^ Germany & Italy 15928285 | RFA (PVI) | AAD | 32^a^ | 35^b^ | SF-36 mental health score at 6 mo | ΔScore^b^ | NetΔ = -4 | | 0.62 (ANOVA) | Fair
0 | +4
Second-line therapy
Krittayaphong 2003 ^23^ Thailand 12866763 | RFA (WACA) | Amiodarone | 14^c^ | 15 | SF-36, general health score at 6 mo | ΔScore^d^ | +15 | +6 | 0.048 (ANOVA) | Poor
Krittayaphong 2003 ^23^ Thailand 12866763 | RFA (WACA) | Amiodarone | 14^c^ | 15 | SF-36, general health score at 12 mo | ΔScore^d^ | +20 | +3 | | Poor
Krittayaphong 2003 ^23^ Thailand 12866763 | RFA (WACA) | Amiodarone | 14^c^ | 15 | SF-36, physical fitness score at 6 mo | ΔScore^d^ | +11 | +2 | 0.69 (ANOVA) | Poor
SF-36, physical fitness score at 12 mo | +23 | -2
Jais 2008 ^28^ France, US, & Canada 19029470 | RFA (CPVA) | AAD | 53 | 59 | SF36 physical component summary at 12 mo | ΔScore^d^ | +7.2 | +5.9 | 0.01 (t-test)^e^ | Fair
Jais 2008 ^28^ France, US, & Canada 19029470 | RFA (CPVA) | AAD | 53 | 59 | ΔScore^f^ | +7.2 | +6.0 | 0.015 (GLM) | | Fair
Jais 2008 ^28^ France, US, & Canada 19029470 | RFA (CPVA) | AAD | 53 | 59 | SF36 mental component summary at 12 mo | ΔScore^d^ | +10.5 | +7.9 | 0.01 (t-test)^e^ | Fair
ΔScore^f^ | +9.7 | +9.1 | 0.09 (GLM)
Retrospective
Second-line therapy
Pappone 2003 ^29^ Italy 12875749 | RFA (CPVA) | AAD | 589 | 582 | SF-36, physical component summary score at 6 mo | ΔScore^b^ | +9 | +1 | nd | Poor
Pappone 2003 ^29^ Italy 12875749 | RFA (CPVA) | AAD | 589 | 582 | SF-36, physical component summary score at 12 mo | ΔScore^b^ | +10 | +1 | | Poor
Pappone 2003 ^29^ Italy 12875749 | RFA (CPVA) | AAD | 589 | 582 | SF-36, mental component summary score at 6 mo | ΔScore^b^ | +8 | +1 | nd | Poor
SF-36, mental component summary score at 12 mo | +8 | +1

AAD, anti-arrhythmic drug; ANOVA, analysis of variance; CPVA, circumferential pulmonary vein ablation; GLM, generalized linear models; nd, no data; PVI, pulmonary vein isolation; RFA, radiofrequency ablation; SF-36, the 36-Item Short-Form General health Survey; WACA, wide area circumferential ablation

a One patient was excluded from analysis due to lost to follow-up.

b Two patients were excluded from analysis due to lost to follow-up.

c One patient was excluded from analysis due to failure to complete the procedure.

d Difference of the mean score between baseline and at the particular point.

e The mean summary scores at 12 mo were compared.

f Within-subject increase based-on repeated measures were presented.

Improvement in both physical and mental component summary score at 12 months was larger in patients who had RFA (+10 and +8) compared to patients who had medical treatment (+1 and +1) in one retrospective study, but no statistical comparisons were provided. ^29^

Avoiding anticoagulation. One study evaluated the rates of avoiding anticoagulation between RFA and medical treatment. Jais et al. ^28^ found a higher proportion of patients reported freedom from anticoagulation at 12 months, comparing RFA with medical therapy (60% vs. 34%, P=0.02).

### Readmissions (Table 7)

Two RCTs evaluated readmission. One found that patients treated with RFA as a first-line treatment had a statistically significant lower readmission rate during the 12 months of followup (9%) compared to medical treatment (54%, P<0.001). ^24^ The other reported a statistically nonsignificant lower median number of readmissions in the RFA arm compared to the medical treatment arm (1 vs. 2 readmissions, respectively). ^25^ None of the studies provided the specific reasons for readmissions.

Table 7 Readmission in patients who received RFA vs. AAD

Study Year UI | Description | | No. Analyzed | | Outcome | Metric/Units | Results | | | Quality
Interv | Cont | Interv | Cont | Interv | Cont | P Between
Randomized controlled trials
First-line therapy
Wazni 2005 ^24^ Germany & Italy 15928285 | RFA (PVI) | AAD | 32 | 35^a^ | Re-admission | Crude %^b^ | 9 | 54 | <0.001 (Fisher) | Fair
Second-line therapy
Stabile 2006 ^25^ Italy 16214831 | RFA (CPVA) plus AAD | AAD | 68 | 69 | Re-admission | Time/patient-year | 1^c^ | 2^c^ | 0.34 (t-test) | Fair
Retrospective
Second-line therapy
Pappone 2003 ^29^ Italy 12875749 | RFA (CPVA) | AAD | nd^d^ | nd^d^ | Change in re-admission^e^ | Time/patient-year | -0.7 | +0.5 | nd | Poor
nd^f^ | nd^f^ | -1.8 | -1.2

AAD, anti-arrhythmic drug; CPVA, circumferential pulmonary vein ablation; PVI, pulmonary vein isolation; RFA, radiofrequency ablation

a Two patient s were excluded due to lost to follow-up.

b The number of patients who needed re-admission was originally reported.

c Median

d Only patients with recurrent AF.

e Change in hospitalization from 2 years prior to the entry of the study.

f Only patients without recurrent AF.

A retrospective study reported mean change in readmission rates in patients treated by RFA according to subsequent recurrence following the procedure (no recurrence: -1.8 times/year (P<0.001), recurrence: -0.7 times/year (P=0.04)) and in those patients who had received medical treatment (no recurrence: -1.2 times/year (P=0.01), recurrence: +0.5 times/year (P=0.43)). ^29^ However, comparison between RFA and medical treatment was not performed. The patients were readmitted mostly due to drug-related side effects.

## Key Question 2. What are the patient-level and intervention-level characteristics associated with RFA effect on rhythm control?

For this question, we evaluated only direct comparisons within studies. We did not attempt to make indirect, cross-study comparisons (such as comparing a study of patients with PAF only to a study of patients with persistent AF only). Patient-level characteristics are those that describe a patient's pre-procedure physical characteristics, AF characteristics, cardiac status, and other comorbid conditions. Intervention-level characteristics are those that describe the setting and the features of the team performing the RFA. Differences specific to the intervention (e.g., catheter tip, ablation technique) are evaluated in Key Question 3.

As described in the Methods chapter, for most patient-level characteristics, we included only studies that reported multivariable analyses. These studies are presented first. For the association between pre-procedure AF type and rhythm control during followup, AF recurrence, we also included studies that reported AF recurrence rates for subgroups of patients with different types of AF (paroxysmal, persistent, chronic/permanent, or nonparoxysmal). We also included any information we found regarding intervention-level characteristics.

### Patient-Level Characteristics: Multivariable Analyses

Twenty-five studies reported multivariable analyses of the association between patient-level characteristics and AF recurrence. ^25,^ ^27^ – ^29,^ ^31^ – ^51^ The studies were highly heterogeneous in terms of study design, patient population, RFA technique used, and definition of AF recurrence. Table 8 (parts A and B) presents a summary of the findings for each of the studies, with the summarized associations between predictors and AF recurrence in part A and the reported details in part B. The studies are ordered by sample size.

Table 8A Predictors of AF recurrence in multivariable analyses

Study Year | Time, mo | AF Type | N | Association with Outcome, HR (95% CI), P value | | | | | | | | | | Comments
AF Type | ↑AF Duration | ↓EF | ↑LAD | Male | ↑Age | Structural Disease | HTN | Other
Themistoclakis 2008 ^31^ | 41 | Mixed | 1298 | ++ Persist 2.2 Chronic 2.3 | ++ 1.03/yr | | 0 | | | 0 | ++ 1.7 | | | Model included early tachyarrhythmia and SVC isolation
Verma 2005 ^32^ | 16 | Mixed | 700 | 0 | 0 | 0 | 0 | | 0 | 0
Pappone 2003 ^29^ | 30 | Mixed | 589 | 0 | 0 | 0 | ++ 2.1 | 0 | 0 | | 0 | CAD | 0
Pappone 2003 ^29^ | 30 | Mixed | 589 | 0 | 0 | 0 | ++ 2.1 | 0 | 0 | | 0 | LV mass | 0
CVA / TIA | 0
Pappone 2004 ^33^ | 12 | Parox Chronic | 560 | ++ Chronic 22 | | | | 0 | 0 | 0
Cha 2008 ^34^ | 12 | Mixed | 432 | 0 | ++ 1.04/yr | ++ 1.02 | 0 | 0 | - - 0.97 | 0 | 0 | BMI | 0 | Similar model at 24 months
Cha 2008 ^34^ | 12 | Mixed | 432 | 0 | ++ 1.04/yr | ++ 1.02 | 0 | 0 | - - 0.97 | 0 | 0 | AAD treatment failure | 0 | Similar model at 24 months
Cha 2008 ^34^ | 12 | Mixed | 432 | 0 | ++ 1.04/yr | ++ 1.02 | 0 | 0 | - - 0.97 | 0 | 0 | DM | 0 | Similar model at 24 months
Sleep apnea | 0
Chen 2004 ^35^ | 14 | Mixed | 377 | | 0 | ++ nd | 0 | 0 | 0 | | | No. of AAD | 0 | Model included PV ostial size
Pappone 2004 ^36^ | 12 | Parox | 297 | | 0 | 0 | 0 | 0 | 0 | 0
Matiello 2008 ^37^ | 14 | Mixed | 247 | 0?^†^ | | | ++ 1.1 | 0?^†^ | 0?^†^ | 0?^†^ | 0?^†^ | | | Model included catheter type
Richter 2006 ^38^ | 6 | Parox Persist | 234 | ++ Persist 1.8 | | 0 | 0 | 0 | 0 | 0 | | BMI | 0 | Model included AF inducibility
Della Bella 2005 ^39^ | 12 | Parox Persist | 234 | | | | | 0 | 0 | 0 | 0
Cheema 2006 ^40^ | 26 | Mixed | 200 | ++ NonParox 2.8 | 0 | 0 | 0 | 0 | 0 | 0
Pappone 2006 ^27^ | 12 | Parox | 198 | | 0 | 0 | 0 | 0 | 0 | 0 | 0
Oral 2004 ^41^ | 15 | Parox | 188 | | + nd | 0 | 0 | 0 | 0 | 0 | | Vagotonic AF | ++ nd
Frequency of AF episodes | 0
Al Chekakie 2007 ^42^ | 14 | Mixed | 177 | 0 | 0 | ++ 2.7 | 0 | 0 | 0 | 0 | 0 | ACE-I, ARB, or statins (individually / collectively) | 0
Berruezo 2007 ^43^ | 13 | Mixed | 148 | 0 | 0 | 0 | ++ 1.1 | 0 | 0 | 0 | ++ 2.8 | Other echo parameters | 0
Dixit 2008 ^44^ | 12 | Mixed | 103 | 0 | | | | 0 | | | | | | Model included early AF recurrence
Essebag 2005 ^45^ | 6/12* | Mixed | 102 | ++ / ++* NonParox 3.2/4.8 | | | | 0 | 0 | ++ / 0* 4.0 / NS | 0 | | | Model included AF inducibility
Nilsson 2006 ^46^ | 12 | Parox Persist | 100 | 0 | 0 | | 0 | 0 | 0 | ++ 2.05
Jais 2004 ^47^ | 12 | Parox | 100 | | 0?^†^ | 0?^†^ | 0?^†^ | 0?^†^ | 0?^†^ | 0
Liu 2006 ^48^ | 13 | Mixed | 100 | 0 | 0 | 0 | 0 | 0 | 0 | + 2.4 | | Typical AFlutter | 0
Other echo parameters | 0
Dixit 2006 ^49^ | 6 | Mixed | 82 | ++ NonParox nd | | | | 0 | | | 0 | Comorbidities | 0
Oral 2003 ^50^ | 6 | Parox | 80 | | 0 | 0 | ++ nd | 0 | 0 | 0 | | Frequency of AF episodes | 0
Calò 2006 ^51^ | 14 | Persist Perm | 80 | 0?^‡^ | | ++ 5.2 | 0?^‡^ | 0?^‡^ | 0?^‡^ | 0?^‡^ | | | | Model included continuation of AAD
Stabile 2006 ^25^ | 12 | Parox Persist | 68 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | Heart disease | 0
Various drugs | 0
Jais 2008 ^28^ | 12 | Parox | 53 | | | ++ 1.1 | 0?^§^ | 0?^§^ | 0?^§^ | 0?^§^ | 0?^§^ | Duration of AF episodes | 0
Jais 2008 ^28^ | 12 | Parox | 53 | | | ++ 1.1 | 0?^§^ | 0?^§^ | 0?^§^ | 0?^§^ | 0?^§^ | Number of cardioversions | 0
Jais 2008 ^28^ | 12 | Parox | 53 | | | ++ 1.1 | 0?^§^ | 0?^§^ | 0?^§^ | 0?^§^ | 0?^§^ | DM | 0?^§^
Other echo parameters | 0?^§^

0, no statistically significant association (P>.1 if adequate data are available to estimate P value or reported as nonsignificant)

+, “trend” for positive association between predictor and (poor) outcome, .05<P≤.10

++, positive association between predictor and (poor) outcome, P<.05

- -, negative association between predictor and (poor) outcome (predicts better outcome), P<.05

* 6 months/12 months.

† Unclear if this variable was tested in the multivariable model.

‡ Adjusted for in model. Unclear if these variables were nonsignificant.

§ Article implied that this variable was not statistically significant by univariable analysis and thus was not tested in multivariable model.

Table 8B Details of multivariable models predicting AF recurrence

Study, Year | Predictor Association with Outcome, HR (95% CI)
Themistoclakis 2008 ^31^ | Persistent AF 2.17 (1.33–3.53); Permanent AF 2.28 (1.51–3.46); AF duration 1.03 (1.00–1.06) per year; LAD >4 cm 1.39 (0.90–2.15); Hypertension 1.65 (1.14–2.39); Structural heart disease 1.09 (0.747–1.65).
Verma 2005 ^32^ | Nonparoxysmal AF 1.6 (0.80, 2.7); AF duration 1.0 (0.9, 1.2; estimated from figure); EF 1.3 (0.7, 2.3; estimated from figure), per 10% decrease; LA size 0.96 (0.50, 1.8; estimated from figure), per cm; Age 1.3 (0.86, 2.1), per decade; Structural heart disease 1.7 (0.7, 3.6, estimated from figure).
Pappone 2003 ^29^ | Chronic AF 1.2 (0.8, 1.5); AF duration >2 years 1.0 (0.7, 1.5); EF <45% 0.9 (0.5, 1.3); LA size >4.5 cm 2.1 (1.8, 2.7); Male 1.0 (0.8, 1.3); Age >65 years 1.0 (0.8, 1.4); HTN 1.2 (0.8, 1.9); Prior stroke or TIA 1.1 (0.7, 1.6); LV mass >125 g/m^2^ 1.0 (0.2, 1.6); CAD 0.9 (0.4, 1.4). Values estimated from figure.
Pappone 2004A ^33^ | Chronic AF (vs paroxysmal) 22 (6.7, 74); Age, Sex, and Heart disease were nonsignificant.
Cha 2008 ^34^ | AF duration 1.04 (1.01, 1.08); higher EF 0.98 (0.96, 1.00); older age 0.97 (0.95, 0.99); HTN NS.
Chen 2004 ^35^ | AF duration, LA size, Age, Gender, Number of AAD were not predictive. EF was. No further data.
Pappone 2004B ^36^ | AF duration 0.92 (0.78, 1.07), implied per year; EF 1.04 (0.94, 1.14), implied per % decrease; LAD 1.11 (0.98, 1.27), implied per mm; Male 0.93 (0.44, 1.97); Age 1.04 (0.98, 1.10), implied per year; Structural heart disease 0.61 (0.27, 1.37).
Matiello 2008 ^37^ | Anteroposterior atrial diameter 1.105 (1.05–1.19), implied per mm. Other analyzed variables not an “independent predictor”. Variables taken from Table 1 patient characteristics.
Richter 2006 ^38^ | Persistent AF (vs. paroxysmal) 1.77 (1.17, 2.7) for AF recurrence. Other predictors not significant in multivariable analysis that also included inducibility of AF exceeding 1 minute of duration. [Other predictors not explicitly defined.]
Della Bella 2005 ^39^ | Sex, Age >50 years, structural heart disease, mitral valve disease, and HTN not predictive.
Cheema 2006 ^40^ | Non-paroxysmal AF 2.83 (1.23, 6.0); AF duration 1.02 (0.94, 1.10); EF 0.97 (0.92, 1.02); LA size 1.2 (0.74, 1.9); Gender 1.6 (0.68, 3.7); Age 1.02 (0.97, 1.04); Structural heart disease 1.03 (0.51, 3.1). [Individual predictors not explicitly defined. Implied that predictors were analyzed as continuous variables, when possible.]
Pappone 2006 ^27^ | No independent predictors of AF recurrences were found in the ablation group. [Individual predictors not explicitly defined. Implied that predictors were analyzed as continuous variables, when possible.]
Oral 2004 ^41^ | AF duration P=.05; Age, Gender, EF, LAD, Structural heart disease, and Frequency of episodes of AF were nonsignificant (P>.1); Vagotonic AF P=.03. Hazard ratios not reported.
Al Chekakie 2007 ^42^ | Persistent AF 1.1 (0.55, 2.2); AF duration 0.95 (0.89, 1.02), per year; EF <50% 2.7 (1.13, 6.5); LAD >4.2 cm 0.87 (0.47, 1.6); Male 1.25 (0.63, 2.5); Age >65 years 1.4 (0.72, 2.8); Structural heart disease 0.91 (0.45, 1.9); HTN 1.8 (0.87, 3.8); ACE-I 1.3 (0.57, 2.9); ARB 0.17 (0.02, 1.3); Statins 1.10 (0.55, 2.3); ACE-I or ARB 0.94 (0.46, 1.9); ACE-I or ARB and statins 1.02 (0.54, 1.9).
Berruezo 2007 ^43^ | Final model included only LAD (mm) 1.1 (1.06, 1.2), per mm; HTN 2.8 (1.5, 5.4). [Definitions of other analyzed parameters included: Permanent AF, AF duration, per month; EF, per percentage point.
Dixit 2008 ^44^ | No variables (of interest) that were tested in univariable analysis significantly affected long term AF control.
Essebag 2005 ^45^ | At 12 months: Nonparoxysmal AF (vs. paroxysmal) 4.8 (1.42, 16) for AF recurrence; moderate to severe valve regurgitation or stenosis nonsignificant. At 6 months: Nonparoxysmal AF 3.2 (1.05, 10); Valvular heart disease 4.0 (1.00, 16). Noninducibility after ablation included in both models. Sex, age and hypertension tested but not included in final models.
Nilsson 2006 ^46^ | Structural heart disease 2.05 (1.18, 3.6). Other predictors nonsignificant. Only LAD variable defined, >4.0 cm.
Jais 2004 ^47^ | Structural heart disease was analyzed in univariable analysis. Variables (of interest) were not significant on multivariable analysis. No list of included variables was provided.
Liu 2006 ^48^ | Among the variables analyzed, RR reported only for Structural heart disease 2.39 (0.90, 6.3), P=.08; LAD 1.06 (0.97, 1.17), implicitly on a continuous scale.
Dixit 2006 ^49^ | Presence of paroxysmal AF was the only variable that affected (complete freedom from AF at 6 months off AADs])
Oral 2003 ^50^ | Among included variables, only LAD was an independent predictor or recurrent paroxysmal AF, P<.01. No other data. Definitions of variables not reported.
Calò 2006 ^51^ | After adjustment for age, gender, LAD, structural heart disease, type of AF (persistent vs. permanent) and continuation of AAD after 6 months, EF <45% 5.2 (2.0, 13).
Stabile 2006 ^25^ | None of the clinical factors was significant. No other data reported.
Jais 2008 ^28^ | Higher baseline EF only independent predictor of lack of recurrent AF after ablation OR 1.10 (1.01, 1.19).

Atrial fibrillation type. Seventeen studies tested AF type (paroxysmal versus nonparoxysmal, persistent, or chronic). ^25,^ ^29,^ ^31^ – ^34,^ ^37,^ ^38,^ ^40,^ ^42^ – ^46,^ ^48,^ ^49,^ ^51^ Eleven of these reported (or implied) no statistically significant association between AF type and AF recurrence. Only three of the nonsignificant studies reported HRs for AF type, with HRs for persistent, chronic, or nonparoxysmal AF that ranged from 1.1 to 1.6 for AF recurrence, suggesting higher recurrence rates with nonparoxysmal AF. ^29,^ ^32,^ ^42^ Six studies found that nonparoxysmal (i.e., chronic or persistent) AF statistically significantly independently predicted higher rates of recurrent AF, ^31,^ ^33,^ ^38,^ ^40,^ ^45,^ ^49^ with HR ranging from 1.8 to 22 (among the five studies that reported data), favoring PAF. There were no obvious features that differentiated the studies that found significant or nonsignificant associations.

Ejection fraction (EF). Among the studies, 17 evaluated EF in multivariable analysis for AF recurrence. ^25,^ ^27^ – ^29,^ ^32,^ ^34^ – ^36,^ ^38,^ ^40^ – ^43,^ ^47,^ ^48,^ ^50,^ ^51^ Across these studies there was a variable range of EFs among patients receiving RFA. The mean EFs ranged from 50% to 70% with standard deviations (approximately one-quarter of the size of the distribution) ranging from 4% to 13%. Most studies did not report excluding potential participants due to low EF, though four studies excluded patients with EFs less than 35% ^25,^ ^27,^ ^48^ or 45%. ^36^ Thus, overall, the majority (and often the large majority) of included patients had normal EFs. The reported data suggest that very few patients in any study had EFs below about 40%. Furthermore, the majority of studies failed to define how the EF variable was parameterized (as a continuous variable or dichotomized at a particular threshold); this was particularly true for studies that found no significant association. Among the 17 studies, only five ^28,^ ^34,^ ^35,^ ^42,^ ^51^ reported statistically significant independent associations between lower EF and AF recurrence. Only eight of the studies reported estimates of the association between EF and recurrence; these ranged from 0.90 to 5.2 (with a median value of 1.07), favoring an association between lower EF and more frequent AF recurrence. There were no obvious features that differentiated the studies that found significant or nonsignificant associations.

Left atrial diameter (LAD). Twenty studies analyzed LAD as a predictor of AF recurrence in multivariable models. ^25,^ ^27^ – ^29,^ ^31,^ ^32,^ ^34^ – ^38,^ ^40^ – ^43,^ ^46^ – ^48,^ ^50,^ ^51^ Across studies (that reported data) the mean LAD ranged from 39 to 51 mm with standard deviations ranging from 4 to 9 mm. Most studies did not report excluding potential participants due to large LADs, though five studies excluded patients with LADs greater than 55 mm, ^43,^ ^46,^ ^48^ 60 mm, ^25^ or 65 mm. ^27^ Thus, overall, the majority (and often the large majority) of included patients had LADs less than 55 mm. The reported data suggest that very few patients in any study had LADs above about 60 mm. Furthermore, the majority of studies failed to define how the LAD variable was parameterized (as a continuous variable or dichotomized at a particular threshold). Among the 20 studies, only four found statistically significant independent associations between larger LAD and AF recurrence. ^29,^ ^37,^ ^43,^ ^50^ Only nine of the studies reported estimates of the association between larger LAD and more frequent recurrence; these ranged from 0.87 to 2.1 (with a median value of 1.11) There were no obvious features that differentiated the studies that found significant or nonsignificant associations.

Structural heart disease. Among 21 studies that evaluated the presence of structural (or valvular) heart disease as a predictor of AF recurrence in multivariable models, ^25,^ ^27,^ ^28,^ ^31^ – ^34,^ ^36^ – ^43,^ ^45^ – ^48,^ ^50,^ ^51^ one reported a statistically significant association at 12 months (HR 2.05, 95% CI 1.18–3.6), ^46^ one reported a statistically significant association at 6 months (HR 4.0, 95% CI 1.0–16) but no association at 12 months (no data), ^45^ and one reported a trend (HR 2.4, 95% CI 0.9–6.3, P=.08). ^48^ Among the remaining studies that found no association, six reported HRs ranging from 0.6 to 2.4. There were no obvious features that differentiated the studies that found significant or nonsignificant associations.

AF duration. Sixteen studies evaluated AF duration as a predictor of AF recurrence. ^25,^ ^27,^ ^29,^ ^31,^ ^32,^ ^34^ – ^36,^ ^40^ – ^43,^ ^46^ – ^48,^ ^50^ Only three studies found a statistically significant independent association between AF duration and recurrence. Themistoclakis et al. and Cha et al. reported similar associations between longer duration and recurrence (HR 1.03, 95% CI 1.00–1.06, per additional year; and 1.04, 95% CI 1.01–1.08, per additional year; respectively); Oral et al (2004) reported only that AF duration was significantly associated with recurrence. ^31,^ ^34,^ ^41^ There were no obvious features that differentiated the studies that found significant or nonsignificant associations.

Hypertension. Eleven studies evaluated hypertension as a predictor, ^25,^ ^27^ – ^29,^ ^31,^ ^34,^ ^37,^ ^39,^ ^42,^ ^43,^ ^45^ two of which found independent associations with AF recurrence. Themistoclakis et al. reported a HR of 1.65 (95% CI 1.14–2.39) ^31^ and Berruezo et al. reported a HR of 2.8 (95% CI 1.5–5.4). ^43^ Two studies reported nonsignificant HRs of 1.2 and 1.8 for recurrence, favoring more frequent recurrence in patients with hypertension. There were no obvious features that differentiated the studies that found significant or nonsignificant associations.

Age and sex. Almost all the studies evaluated age and sex. Three studies did not evaluate age, two studies did not evaluate sex. Mean ages ranged from 49 to 65 years with standard deviations ranging from 7 to 13 years. Six studies excluded older patients (over 70 years, ^27,^ ^33^ 75 years, ^37,^ ^43^ or 80 years ^25,^ ^48^ ). It is likely that there were relatively few patients under age 40 or over age 70. Furthermore, the majority of studies failed to define how the age variable was parameterized (as a continuous variable or dichotomized at a particular threshold). Only one of 22 studies found a statistically significant independent association between age and recurrence; older age was associated with lower rates of AF recurrence (HR 0.97, 95% CI 0.95–0.99). ^34^ All of 23 studies found no independent association between sex and recurrence rate.

Other potential predictors. In two studies, frequency of AF episodes pre-procedure was not associated with rate of recurrence. ^41,^ ^50^ Duration of AF episodes was also no associated with recurrence in one study. ^28^ Other echocardiographic parameters (left ventricular end diastolic and end systolic diameters, interventricular septal thickness, and left ventricular posterior wall thickness) were not associated with recurrence in three studies. ^28,^ ^43,^ ^48^ History of coronary artery or cardiac disease were not associated with recurrence in two studies. ^25,^ ^29^ Use of a variety of pre-procedure medications, including AAD did not predict recurrence in three studies. ^25,^ ^35,^ ^42^ Two studies reported no association with body mass index. ^34,^ ^38^ Two other studies found no association with diabetes history ^28,^ ^34^ One study each reported no association between AF recurrence and left ventricular mass, stroke or TIA history, typical atrial flutter, AAD treatment failure, number of cardioversions, sleep apnea, or other comorbidities. One study reported a statistically significant association between AF recurrence and pre-procedure vagal-mediated AF. ^41^

### Atrial Fibrillation Type: Unadjusted, Univariable Analyses

Thirty-one studies (Table 9, Figures 5–7) reported rates of AF recurrence for different subgroups of patients based on their type of AF (paroxysmal, persistent, chronic, or nonparoxysmal). ^31,^ ^32,^ ^34,^ ^38^ – ^40,^ ^44^ – ^46,^ ^48,^ ^49,^ ^52^ – ^71^ The studies were highly heterogeneous in terms of study design, patient population, RFA technique used, and definition of AF recurrence. While acknowledging the clinical heterogeneity, we performed meta-analyses (using random effects model of RR) to explore the associations between AF types and AF recurrence. Separate meta-analyses were performed for the three comparisons reported in the studies: persistent versus paroxysmal AF; chronic versus paroxysmal AF; and nonparoxysmal versus paroxysmal (combined persistent and chronic). We calculated RRs for all studies based on the data provided and estimated P values of these RRs, regardless of how the data were analyzed in the original studies.

Figure 5. Metaanalysis of RR of recurrence, persistent vs. paroxysmal AF

Figure 7. Metaanalysis of RR of recurrence, nonparoxysmal vs. paroxysmal AF

Table 9 Association between types of AF and recurrence of AF in univariable (unadjusted) analyses

Study | Time, mo | Total N | Paroxysmal, % n/N | | Persistent, % n/N | | Chronic* % n/N | | Comparison | OR (95% CI) | P value
Themistoclakis 2008 ^31^ | 41 | 1298 | 37% | 107/699 | 22% | 65/230 | 41% | 120/369 | Persist vs Parox | 1.85 (1.41, 2.42) | <.001 (c/w multivariable)
Themistoclakis 2008 ^31^ | 41 | 1298 | 37% | 107/699 | 22% | 65/230 | 41% | 120/369 | Chronic vs Parox | 2.12 (1.69, 2.67) | <.001 (c/w multivariable)
Nonparox vs Parox | 2.02 (1.64, 2.50) | <.001
Bhargava 2004 ^54^ | 15 | 323 | 13% | 22/174 | 20% | 7/35 | 22% | 25/114 | Persist vs Parox | 1.58 (0.73, 3.41) | NS
Bhargava 2004 ^54^ | 15 | 323 | 13% | 22/174 | 20% | 7/35 | 22% | 25/114 | Chronic vs Parox | 1.04 (0.56, 1.92) | NS
Nonparox vs Parox | 1.17 (0.67, 2.02) | NS
Tao 2008 ^69^ | 18 | 249 | 33% | 58/175 | 30% | 22/74 | | | Persist vs Parox | 0.85 (0.47, 4.54) | NS
Della Bella 2005 ^39^ | 13 | 234 | 24% | 49/204 | 42% | 25/59 | | | Persist vs Parox | 1.76 (1.20, 2.59) | .004
Richter 2006 ^38^ | 6 | 234 | 33% | 54/165 | 52% | 36/69 | | | Persist vs Parox | 1.59 (1.16, 2.18) | .004 (c/w multivariable)
Fiala 2008 ^57^ | 28 | 194 | 34% | 20/59 | 47% | 63/135 | | | Persist vs Parox | 1.38 (0.92, 2.05) | NS
Fassini 2005 ^56^ | 12 | 187 | ~31% | ~39/126 | ~44% | ~27/61 | | | Persist vs Parox | 1.43 (0.97, 2.10) | .07
Zhou 2007 ^71^ | 7 | 148 | 5% | 4/84 | 11% | 7/64 | | | Persist vs Parox | 2.30 (0.70, 7.51) | NS
Arentz 2007 ^52^ | 15 | 110 | 37% | 25/67 | 49% | 21/43 | | | Persist vs Parox | 1.31 (0.85, 2.02) | NS
Beukema 2005 ^53^ | 15 | 105 | 25% | 13/52 | 40% | 21/53 | | | Persist vs Parox | 1.58 (0.89, 2.82) | NS
Nilsson 2006 ^46^ | 12 | 100 | ~73% | ~37/51 | ~92% | ~45/49 | | | Persist vs Parox | 1.27 (1.05, 1.53) | .01 (NS multivariable)
Kottkamp 2004 ^59^ | 12 | 100 | 26% | ~21/80 | 78% | ~16/20 | | | Persist vs Parox | 3.05 (1.99, 4.67) | <.001
Kistler 2006 ^58^ | 6 | 94 | 39% | 18/46 | 48% | 23/48 | | | Persist vs Parox | 1.22 (0.77, 1.95) | NS
Shimano 2008 ^66^ | 25 | 62 | 21% | 9/43 | 32% | 6/19 | | | Persist vs Parox | 1.51 (0.63, 3.64) | NS
Marsan 2008 ^60^ | 8 | 57 | 24% | 11/45 | 67% | 8/12 | | | Persist vs Parox | 2.73 (1.42, 5.23) | .003
Sra 2007 ^67^ | 9 | 50 | 22% | 7/32 | 33% | 6/18 | | | Persist vs Parox | 1.52 (0.60, 3.84) | NS
Metaanalysis | | 3545 | | | | | | | Persist vs Parox | 1.55 (1.35, 1.79) heterogeneous | <.001
Oral 2006 ^63^ | 24 | 755 | 23% | ~113/490 | | | 32% | ~85/265 | Chronic vs Parox | 1.39 (1.10, 1.77) | .007
Pappone 2001 ^64^ | 10 | 251 | 15% | 27/179 | | | 32% | 23/72 | Chronic vs Parox | 2.12 (1.30, 3.44) | .002
Miyazaki 2008 ^62^ | 6 | 86 | 21% | 13/61 | | | 40% | 10/25 | Chronic vs Parox | 1.88 (0.95, 3.71) | .07
Metaanalysis | | 2448 | | | | | | | Chronic vs Parox | 1.69 (1.29, 2.21) heterogeneous | <.001
Verma 2005 ^32^ | 16 | 700 | 14% | 38/274 | | 27% | 114/426 | | Nonparox vs Parox | 1.93 (1.38, 2.70) | <.001 (NS multivariable)
Cha 2008 ^34^ | 12 | 432 | 26% | 65/247 | | 30% | 56/185 | | Nonparox vs Parox | 1.15 (0.85, 1.56) | NS (c/w multivariable)
Chugh 2005 ^55^ | 13 | 349 | 13% | 30/227 | | 25% | 31/122 | | Nonparox vs Parox | 1.92 (1.22, 3.02) | .005
Tang 2006 ^68^ | 13 | 263 | 23% | 45/199 | | 27% | 17/64 | | Nonparox vs Parox | 1.17 (0.73, 1.90) | NS
Cheema 2006 ^40^ | 26 | 200 | 63% | 58/92 | | 80% | 86/108 | | Nonparox vs Parox | 1.26 (1.05, 1.52) | .01 (c/w multivariable)
Verma 2007 ^70^ | 12 | 200 | 14% | 17/120 | | 23% | 18/80 | | Nonparox vs Parox | 1.59 (0.87, 2.89) | NS
Proclemer 2008 ^65^ | 25 | 144 | 13% | 12/93 | | 37% | 19/51 | | Nonparox vs Parox | 2.89 (1.53, 5.46) | .001
Dixit 2008 ^44^ | 12 | 103 | 21% | 16/75 | | 43% | 12/28 | | Nonparox vs Parox | 2.01 (1.09, 3.70) | .02 (NS multivariable)
Essebag 2005 ^45^ | 12 | 102 | 26% | ~16/60 | | 55% | ~23/42 | | Nonparox vs Parox | 2.05 (1.24, 3.39) | .005 (c/w multivariable)
Martinek 2007 ^61^ | 6 | 100 | 31% | 18/59 | | 49% | 20/41 | | Nonparox vs Parox | 1.60 (0.97, 2.63) | .06
Liu 2006 ^48^ | 13 | 100 | 31% | 23/75 | | 28% | 7/25 | | Nonparox vs Parox | 0.91 (0.45, 1.87) | NS (c/w multivariable)
Dixit 2006 ^49^ | 6 | 82 | 34% | 20/58 | | 70% | 16/23 | | Nonparox vs Parox | 2.02 (1.29, 3.15) | .002 (c/w multivariable)
Metaanalysis | | 4394 | | | | | | | Nonparox vs Parox | 1.59 (1.38, 1.82) heterogeneous | <.001

* or permanent

Paroxysmal versus persistent atrial fibrillation. Sixteen studies with 3,545 patients reported AF recurrence rates for both patients with paroxysmal and persistent AF. ^31,^ ^38,^ ^39,^ ^46,^ ^52^ – ^54,^ ^56^ – ^60,^ ^66,^ ^67,^ ^69,^ ^71^ The 16 studies included 21 cohorts of patients (based on specific RFA intervention), as shown in Figure 5. Among patients with PAF, most studies reported PAF recurrence rates between 13% and 39%. Compared to other eligible studies, Zhou et al. reported an atypically low recurrence rate of 5% ^71^ and Nilsson et al. reported a particularly high recurrence rate of about 73%. ^46^ The range of RRs for AF recurrence (paroxysmal versus persistent AF) was 0.90 to 3.05, with a median value of 1.50. Eight of the associations were statistically significant. Only three of the studies also included AF type in a multivariable analysis. Themistoclakis et al. and Richter et al. found that PAF was associated with a lower risk of recurrence in both univariable and multivariable analyses. ^31,^ ^38^ In contrast, Nilsson et al. found that AF type was associated with recurrence in a univariable analysis, but not in a multivariable analysis. ^46^ In addition to the clinical heterogeneity across the studies, including a variety of RFA techniques used and a wide range of rates of AF recurrence, the studies were statistically heterogeneous. The summary RR was 1.55 (95% CI 1.35–2.79, P<.001), suggesting that patients with persistent AF were about twice as likely to have recurrence as patients with PAF.

Chronic versus paroxysmal atrial fibrillation. Five studies with 2,448 patients reported AF recurrence rates for both patients with paroxysmal and chronic AF (Figure 6). ^31,^ ^54,^ ^62^ – ^64^ PAF recurrence rates ranged from 13% to 37%. The RRs for AF recurrence (chronic versus paroxysmal AF) varied from 1.04 to 2.19, with a median value of 1.88; three of the studies found a statistically significant difference. The one study that also performed multivariable analysis found statistical significance in both analyses. ^31^ By metaanalysis, the five studies had statistically heterogeneous results. The summary RR was 1.69 (95% CI 1.29–2.21, P<.001), suggesting that patients with chronic AF had a 69% increased risk of recurrent AF as patients with PAF.

Figure 6. Metaanalysis of RR of recurrence, chronic vs. paroxysmal AF

Nonparoxysmal versus paroxysmal atrial fibrillation. Fourteen studies with 4,394 patients reported AF recurrence rates for both patients with paroxysmal and nonparoxysmal (both persistent and chronic) AF. ^31,^ ^32,^ ^34,^ ^40,^ ^44,^ ^45,^ ^48,^ ^49,^ ^54,^ ^55,^ ^61,^ ^65,^ ^68,^ ^70^ The 14 studies included 17 cohorts of patients (based on specific RFA intervention), as shown in Figure 7. Most studies reported PAF recurrence rates between 13% and 37%. Compared to the other eligible studies, Cheema et al. reported an atypically high recurrence rate of 63%. ^40^ The range of RRs for AF recurrence (paroxysmal versus nonparoxysmal AF) varied from 0.91 to 2.9, with a median value of 1.76. Nine of the 17 associations were statistically significant. Three studies found that recurrence was significantly less common in patients with PAF than nonparoxysmal AF in both unadjusted and multivariable analyses; ^40,^ ^45,^ ^49^ two found that the association was statistically significant by univariable analysis, but not in a multivariable model; ^32,^ ^44^ and two studies found that there was no significant association between AF type and recurrence in both univariable and multivariable models. ^34,^ ^48^ By metaanalysis, the studies had statistically heterogeneous results. The summary RR was 1.59 (95% CI 1.38–1.82, P<.001), suggesting that patients with nonparoxysmal AF were 59% more likely to have AF recurrence than patients with PAF.

Heterogeneity. Across the studies that analyzed AF type as a predictor of AF recurrence by either univariable or multivariable analysis, there was no clear factor that explained any heterogeneity in results.

### Intervention-Level Characteristics

We found no studies that reported analyses of operator or center (“intervention-level”) characteristics as predictors of AF recurrence.

## Key Question 3. How does the effect of RFA on short- and long-term rhythm control differ among the various techniques or approaches used?

### Approaches to RFA (Tables 10 and 11)

There are a number of different approaches to catheter-based RFA for AF. One major approach is based on the technique developed by Haissaguerre et al. to electrically isolate the PVs. ^12^ This involved the identification and ablation of triggering potentials in the PV myocardial sleeves. Studies that employed this technique have used the term segmental, focal, or ostial pulmonary vein isolation (PVI). For simplicity, all such studies were classified as ostial PVI in this review. After recognizing PV stenosis as a complication from this technique, other ablation approaches were developed to deliver lesions outside the PV itself. These include antral PVI (ablation within the PV antrum, not the ostium) and continuous circumferential ablation encircling the right and left PVs (wide-area circumferential ablation (WACA)). Additional techniques have also been employed to target the substrate thought responsible for the propagation of AF (substrate modification) by creating linear ablation lines in the left atrium (LA) (e.g., a roof line connecting the superior aspect of the PV encircling lesions, a posterior line connecting the posterior aspect of the encircling lesions (posterior LA line), a mitral line from the left inferior pulmonary vein or a septal line from the right inferior pulmonary vein to the mitral isthmus line (MIL), or a linear lesion at the inferior aspect of the left atrium which runs parallel to the coronary sinus). In patients with a history of atrial flutter, a cavotricuspid isthmus ablation line (CTI) is also recommended. ^1^

Table 10 Study characteristics of approaches to RFA

Author Year Country UI | Group 1 | Group 2 | Catheter Tip | PVI (yes/no) | Checked inducibility (yes/no) | Total N_enrolled_ | Enrollment Years | % PAF | Mean Age, yr | Male, % | Mean LAD, cm | Mean LVEF, % | Symptom duration, year
Randomized controlled trials
Arentz 2007 ^52^ Germany 17562956 | PVI (ostia) | WACA | irrigated | yes | no | 110 | 2004-2006 | 61 | 56 | 75 | 4.0 | nd | 5.5
Oral 2003 ^50^ US 14557355 | PVI (ostia) | WACA + MIL + posterior line | 4 or 8 mm | yes | no | 80 | nd | 100 | 52 | 78 | 4.0 | 56 | 7
Nilsson 2006 ^46^ Denmark 16923426 | PVI (ostia) | WACA | 5 mm irrigated (ostia); 3.5 mm irrigated (WACA) | yes | yes | 100 | 2002-2004 | 51 | 56 | 71 | nd | nd | 4.1
Karch 2005 ^74^ Germany 15927974 | PVI (ostia) | WACA | 4 mm cooled; 8 mm; irrigated | yes (not in WACA) | no | 100 | 2002-2003 | 89 | 60 | 64 | 4.7 | 63 | 4.5
Liu 2006 China 17062959 ^75^ | Stepwise PVI (add roof line if inducible; then add MIL if inducible) | WACA | Both irrigated: 4 mm in stepwise; 3.5 mm in WACA | yes | yes in stepwise | 110 | nd | 100 | 58 | 66 | 3.8 | 64 | 5
Willems 2006 ^80^ Germany 16782716 | PVI (antrum?) + CTI | PVI (antrum?) + CTI + LA linear lines | open irrigated | yes | no | 62 | nd | 0 | 59 | nd | 4.8 | ≥40 | 6
Pappone 2004 ^33^ Italy 15520310 | WACA | WACA + posterior LA lines + MIL | 8 mm | yes (?) | no | 560 | 2002-2003 | 63 | 56 | 52 | 3.95 | nd | 7.2
Fassini 2005 ^56^ Italy 1630289 | PVI | PVI + mitral isthmus line (MIL) | irrigated | yes | no | 187 | nd | 67 | 55 | 80 | 4.26 | 56 | nd
Haissaguerre 2004 ^72^ France 15184286 | PVI + (CTI) | PVI + CTI + MIL | 4 mm irrigated | yes | yes | 70 | nd | nd | 53 | 74 | 4.3 | 67 | 5.1
Sheikh 2006 ^78^ US 17318445 | PVI (ostia) | PVI + superior PV line + LIPV to MV annulus line | nd | yes | no | 100 | nd | 100 | 59 | 63 | 4.1 | 54 | nd
Hocini 2005 ^73^ France 16344401 | PVI (antrum) + Cavotricuspid isthmus ablation (CTI) | PVI (antrum) + CTI + roof line | 4 mm irrigated | yes | yes | 90 | 2003 | 100 | 55 | 79 | 4.1 | 67 | 5.25
Wazni 2003 ^79^ US; Germany; Italy 14610012 | PVI (ostia-antrum) | PVI (ostia-antrum) + CTI | 4 mm cooled | yes | no | 108 | 2000-2002 | 59 (must have had 1 AFL episode) | 55 | 81 | 4.2 | 53 | 5.5
Wang 2008 ^81^ China 18442966 | WACA | WACA + SVC | 3.5 mm irrigated | yes | no | 106 | 2006 | 100 | 66 | 55 | 3.7 | 54 | 3.6
Liu 2006 ^48^ China 17239094 | WACA, then closing gaps in pts with residual PV conduction (aggressive) | WACA, then PVI inside circular lines in pts with residual PV conduction (modified) | 3.5 mm irrigated | yes | no | 100 | 2004-2005 | 75 | 57 | 69 | 3.9 | 65 | 6.7
Oral 2004 ^76^ US 15505091 | WACA + posterior LA lines + MIL | WACA + posterior LA lines + MIL + additional lines | 8 mm | yes | yes | 60 | nd | 100 (AF not terminated or inducible after WACA + posterior LA lines + MIL) | 55 | 83 | 4.3 | 59 | 7
Oral 2005 ^77^ US 16253904 | WACA + posterior LA (or roof line) + MIL + within the circles but outside the PV | non-encircling LA roof, septum, anterior wall, MIL | 8 mm | yes in WACA | yes | 80 | nd | 0 | 54 | 84 | 4.8 | 53 | 4.5
Non-randomized comparative trials
Mantovan 2005 ^82^ Italy 16403059 | PV antrum ablation (PVI not checked) | PV antrum ablation + assessment of PVI with further ablation for residual potentials | 3.5 mm irrigated | see previous cells | no | 60 | nd | 65 | 54 | 85 | 4.3 | 60 | 4.2
Pak 2008 ^83^ Korea 18284506 | Selective PVI (in PV with triggering AF) | 4-PV PVI | 5 mm | yes | yes | 77 | nd | 100 | 52 | 74 | 3.9 | 57 | 5
Prospective cohorts
Arruda, 2007 ^84^ US 17850288 | PVI (antrum) or PVI (antrum) + SVC isolation | | 4 mm, 8 mm or irrigated | yes | yes | 407 | nd | 51 | 55 | 79 | nd | nd | 6
Shah 2007 ^85^ Switzerland 17655668 | PVI (ostia) + posterior LA line and/or MIL as needed (persistent or permanent AF; failed PVI) | techniques in group 2 + CTI as needed in pts with hx of AFL or AFL during ablation | irrigated | yes | no | 188 | nd | 72 | 56 | 81 | 4.2 | nd | 6
Retrospective cohorts
Okada 2007 ^91^ Japan 17397672 | PVI (ostia) | circumferential PV antrum ablation | 8 mm | yes | yes | 77 | nd | 100 | 58 | 84 | 3.41 | 67 | 5
Schwartzman 2003 ^92^ US 14574043 | PVI (ostia) | PVI (antrum); WACA | nd | yes | yes | 112 | nd | 100 | 55 | 81 | 4.0 | 56 | nd
Yamane 2007 ^95^ Japan 17457004 | PVI (ostia) | PVI (antrum) | 8 mm | yes | yes | 187 | nd | 66 | 53 | 77 | 3.9 | nd | nd
Richter 2008 ^96^ 2006 ^38^ Austria 18328850 17038349 | PVI | WACA | 8 mm; 4 mm | yes | yes | 234 | 2002-04 (group 1); 2004 (group 2) | 70 | 57 | 72 | 4.5 | 61 | 6.1
Cheema 2006 ^40^ USA 17019636 | PVI (ostia) + Cavotricuspid isthmus ablation (CTI) | WACA+ CTI + mitral isthmus line + posterior LA line + “figure of 8” | irrigated 4 mm (ostia); 8 mm (WACA) | yes in ostial PVI | no | 200 | nd | 46 | 56 | 66 | 4.4 | 59 | 6.4
Dong 2005 ^86^ China 16117858 | PVI (ostia) | WACA | irrigated tip in WACA | yes | no | 151 | nd | 86 | 57 | 72 | 3.78 | 67 | 6.9
Mansour, 2004 ^89^ USA 15149421 | PVI (ostia) | WACA | nd | yes | no | 80 | 2000-2002 | 81 | 54 | 85 | 4.0 | nd | nd
Tamborero 2005 ^93^ Spain 16311935 | PVI (ostia) | WACA | 4 mm in PVI; 8 mm in CPVA | yes in PVI | no | 73 | nd | 74 | 51 | 78 | 4.0 | 55 | 5.6
Katritsis 2008 ^97^ Greece 18363086 | PVI (ostia or antrum) | WACA | 4 mm in PVI; irrigated in WACA | yes | no | 90 | nd | 100 | 55 | 83 | 4.1 | nd | nd
Jais 2004 ^47^ France 15520313 | PVI (ostia) + CTI | PVI (ostia) + CTI+MIL | 4 mm irrigated | yes | no | 200 | 2001 (group 1); 2002 (group 2) | 100 | 55 | 87 | 4.6 | 71 | 6
Verma 2007 ^70^ USA 17338763 | PVI (antrum) + SVC isolation | PVI (antrum)+ SVC isolation + CFAE ablation in anterior LA/septum | 8 mm | yes | yes | 200 | nd | 40 | 57 | 63 | 4.3 | 53 | 5.2
Lemola 2006 ^88^ US 16843185 | WACA+ roof line + MIL | CFAE ablation | 8 mm | no | yes in CFAE ablation | 84 | nd | 58 | 57 | 83 | 4.3 | 57 | 6.5
Hachiya 2007 ^87^ Japan 17286569 | WACA | WACA + ablation of adenosine induced potentials | 8 mm | yes | yes | 252 | 2003-2005 | 78 | 55 | 83 | 4.14 | nd | nd
Matsuo 2007 ^90^ Japan 17506857 | PVI (ostia or antrum) | PVI + ablation of adenosine induced potentials | 8 mm | yes | yes | 148 | 2003-2006 | 65 | 53 | 86 | 3.8 | 66 | 4.7
Walczak 2006 ^94^ Poland 16444625 | Selective PVI (0–3 PVs) | non-selective PVI (4 or 5 PVs) | nd | yes | yes | 80 | nd | 70 | 48 | 64 | 3.8 | 64 | nd
Pappone 2004 ^36^ Italy 14707026 | WACA + posterior LA lines + MIL | WACA + posterior LA lines + MIL + vagal denervation | nd | nd | nd | 297 | 1999-2002 | 100 | 49 | nd | 3.9 | 58 | 7.0
Kettering 2008 ^98^ Germany 18507536 | PVI | PVI (exclude areas near esophagus) | 3.5 mm irrigated | yes | no | 43 | 2004-2007 | 100 | 62 | 65 | nd | 59 | nd

* WACA, CFAE, other lines, ganglionic plexi, etc.

Table 11 Outcomes comparing different ablation approaches and study quality

Author Year Country UI | Group 1 | Group 2 | N Analyzed Group 1 | N Analyzed Group 2 | Outcome | Followup | Results Group 1 | Results Group 2 | P Between | Quality
Randomized controlled trials
Arentz 2007 ^52^ Germany 17562956 | PVI (ostia) | WACA | 55 | 55 | freedom from AF (no AAD, after 1 ablation) | 15 mo | 49% | 67% | ≤0.05 | Fair
Oral 2003 ^50^ US 14557355 | PVI (ostia) | WACA + MIL + posterior line | 40 | 40 | absence of symptomatic AF off AAD (no repeat procedure) | 6 mo | 67% | 88% | 0.02 (log rank) | Fair
repeat ablation | | 17.5% | 0% | nd
Nilsson 2006 ^46^ Denmark 16923426 | PVI (ostia) | WACA | 54 | 46 | freedom from symptomatic AF or left AT (not on AADs; 74 pts had 1 reablation) | 12 mo | 31% | 57% | 0.02 | Fair
Karch 2005 ^74^ Germany 15927974 | PVI (ostia) | WACA | 50 | 50 | freedom from atrial tachyarrhythmia (AT) (no repeat procedure) | 6 mo | 54% | 34% | nd | Fair
Karch 2005 ^74^ Germany 15927974 | PVI (ostia) | WACA | 50 | 50 | freedom from AT (with repeat procedure) | 6 mo | 66% | 42% | 0.02 | Fair
repeat ablation procedure within | 6 mo | 16% | 24% | NS
Liu 2006 China 17062959 ^75^ | Stepwise PVI (add roof line if inducible; then add MIL if inducible) | WACA | 55 | 55 | no AT 3–9 mo after the last procedure (no AADs) | 9 mo | 78% | 84% | 0.63 | Poor
repeat ablation | 3–5 mo of initial procedure | 13% | 9% | nd
Willems 2006 ^80^ Germany 16782716 | PVI (antrum) + CTI | PVI (antrum) + CTI + LA linear lines | 30 | 32 | SR (Lack of any symptomatic or asymptomatic AF episode (>30 s); some pts on AADs(?)) | 17 mo | 20% | 69% | 0.0001 | Fair
Pappone 2004 ^33^ Italy 15520310 | WACA | WACA + posterior LA lines + MIL | 280 | 280 | freedom from symptomatic incessant AT (39 pts had reablation for AT) | 12 mo | 90% | 96% | 0.005 | Fair
freedom from recurrent AF (3 pts had reablation for AF) | 12 mo | 87% (est.) | 88% (est.) | 0.57
Fassini 2005 ^56^ Italy 1630289 | PVI | PVI + mitral isthmus line (MIL) | 92 | 95 | stable SR (after this procedure) | 12 mo | 53 ± 5% | 71 ± 5% | 0.01 | Fair
continual use of AAD | 12 mo | 56% | 50% | NS
Haissaguerre 2004 ^72^ France 15184286 | PVI + CTI | PVI + CTI + MIL | 35 | 35 | freedom from AF or flutter (no AAD; included reablation) | 7 mo | 74% | 83% | nd | Fair
Sheikh 2006 ^78^ US 17318445 | PVI (ostia) | PVI + superior PV line + LIPV to MV annulus line | 50 | 50 | SR (no AAD; 3 had AFL ablation) | 9 mo | 28% | 28% | NS | Poor
Hocini 2005 ^73^ France 16344401 | PVI (antrum) + Cavotricuspid isthmus ablation (CTI) | PVI (antrum) + Cavotricuspid isthmus ablation (CTI) + roof line | 45 | 45 | no atrial arrhythmia and off AAD | 14 mo | 69% | 87% | 0.04 | Poor
Wazni 2003 ^79^ US; Germany; Italy 14610012 | PVI (ostia-antrum) | PVI (ostia-antrum) + CTI | 59 | 49 | no AF recurrence | >8 wk | 90% | 86% | NS | Fair
53 | 42 | no AF recurrence (9% had repeat procedure; 3% on AADs) | 12 mo | 100% | 100% | NS
Wang 2008 China 18442966 | WACA | WACA + SVC | 54 | 52 | freedom from recurrent AT (after 1 procedure; ? some on AADs) | 4.6 mo (12 mo?) | 78% | 81% | 0.75 | Poor
54 | 52 | freedom from recurrent AT (included reablation; some on AADs) | 12 mo | 93% | 94% | 0.73
Liu 2006 ^48^ China 17239094 | WACA, then closing gaps in pts with residual PV conduction (aggressive) | WACA, then PVI inside circular lines in pts with residual PV conduction (modified) | 50 | 50 | no AT beyond 3 mo after initial procedure (no AADs) | 13 mo (?) | 82% | 58% | 0.01 | Fair
Oral 2004 ^76^ US 15505091 | WACA + posterior LA lines + MIL | WACA + posterior LA lines + MIL + additional lines | 30 | 30 | freedom from AF (no AADs; no additional reablation) | 6 mo | 67% | 86% | 0.05 | Fair
Oral 2005 ^77^ US 16253904 | WACA + posterior LA (or roof line) + MIL + ablation of amplitude >0.2 mv within the circles but outside the PV | non-encircling LA roof, septum, anterior wall, mitral isthmus and annulus lines | 40 | 40 | freedom from AF or AFL, no AAD, single procedure | 10 mo | 48% | 33% | 0.20 | Poor
Nonrandomized comparative trials
Mantovan 2005 ^82^ Italy 16403059 | PV antrum ablation (PVI not checked) | PV antrum ablation + assessment of PVI with further ablation for residual potentials | 30 | 30 | stable SR | 15.4 mo | 57% | 83% | 0.024 | Poor
SR (no AADs; 8 pts had reablation) | 15.4 mo | 13% | 53% | 0.002
Pak 2008 Korea 18284506 | Selective PVI (in PV with triggering AF) | 4-PV PVI | 42 | 35 | freedom from recurrent AF (after 1 ablation, not on AAD?) | 39 mo | 62% | 74% | NS | Poor
42 | 35 | reablation | 31% | 23% | nd
Prospective cohort
Arruda, 2007 ^84^ US 17850288 | PVI (antrum) or PVI (antrum) + SVC isolation | | 407 | | AF recurrence | 14.8 mo | 16% | | | Poor
Shah 2007 ^85^ Switzerland 17655668 | PVI (ostia) + posterior LA line and/or MIL as needed (persistent or permanent AF; failed PVI) | techniques in group 2 + CTI as needed in pts with hx of AFL or AFL during ablation | 113 | 75 | stable SR, no AF or AFL, no AAD; 62 pts had reablation for AF or AFL | 30 | 79% | 82% | NS | Poor
Retrospective cohort
Okada 2007 ^91^ Japan 17397672 | PVI (ostia) | circumferential PV antrum ablation | 50 | 27 | AF free (no AAD) | 6 mo | 50% | 89% | <0.001 | Poor
Schwartzman 2003 ^92^ US 14574043 | PVI (ostia) | PVI (antrum); WACA | 47 | 42; 23 | no detectable AF (not on type 1 or III AAD) | 6 mo | 47% | 69%; 87% | <0.05 | Poor
Yamane 2007 ^95^ Japan 17457004 | PVI (ostia) | PVI (antrum) | 44 | 80 | freedom from AF after 3 mo in pts with PAF after initial procedure (? on AADs) | 2.8 yes (ostia); 1.8 yes (antrum) | 58.7% | 61.4% | NS | Poor
Yamane 2007 ^95^ Japan 17457004 | PVI (ostia) | PVI (antrum) | 26 | 37 | freedom from AF after 3 mo in pts with persistent AF after initial procedure | 2.8 yes; 1.8 yes | 32.4% | 36.2% | NS | Poor
Yamane 2007 ^95^ Japan 17457004 | PVI (ostia) | PVI (antrum) | 44 | 80 | freedom from AF after 3 mo in pts with PAF after final procedure | 2.8 yes; 1.8 yes | 76% | 93% | 0.015 | Poor
26 | 37 | freedom from AF after 3 mo in pts with persistent AF after final procedure | 2.8 yes; 1.8 yes | 48% | 78% | 0.032
Richter 2008 ^96^ 2006 ^38^ Austria 18328850 17038349 | PVI | WACA ± CTI (?) | 83 | 151 | freedom from AF (?AADs) | 6 mo (median) | 64% | 60% | nd | Poor
Cheema 2006 ^40^ USA 17019636 | PVI (ostia) + (CTI) | WACA+ CTI + other lines | 87 | 113 | no symptomatic AF 6 mo prior to last f/u, exclude 3 mo of blanking period (single procedure; no AAD) | 26 mo | 22% | 32% | nd | Poor
Dong 2005 ^86^ China 16117858 | PVI (ostia) | WACA | 68 | 83 | stable SR (no AAD) | 12.7 mo (ostia); 7.2 mo (WACA) | 60% | 82% | <0.001 | Poor
Mansour, 2004 ^89^ USA 15149421 | PVI (ostia) | WACA | 40 | 40 | freedom from AF at 21 mo (PVI group) and 11 mo (CPVA group) | | 60% | 75% | | Poor
40 | 40 | repeat ablation | | 15% | 10%
Tamborero 2005 ^93^ Spain 16311935 | PVI (ostia) | WACA | 32 | 41 | freedom from AF recurrence | 15 mo | 72% | 76% | NS | Poor
Katritsis 2008 Greece 18363086 | PVI (ostia or antrum) | WACA | 41 | 49 | Freedom from AF; symptom improvement | 12 mo | 61% | 67% | 0.5 | Poor
Jais 2004 ^47^ France 15520313 | PVI (ostia) + CTI | PVI (ostia) + CTI+MIL | 100 | 100 | arrhythmia free, no AAD (included pts with repeat ablations) | 12 mo | 69% | 87% | 0.002 | Poor
Verma 2007 ^70^ USA 17338763 | PVI (antrum) + SVC isolation | PVI (antrum)+ SVC isolation + CFAE ablation in anterior LA/septum | 100 | 100 | no AF or atypical AFL 2 mo post procedure (no AAD) | 12 mo | 80% | 85% | 0.054 | Poor
Lemola 2006 ^88^ US 16843185 | WACA+ roof line + MIL | CFAE ablation | 42 | 42 | no AF (no AAD, single ablation) | 9 mo | 67% | 71% | 0.6 | Poor
Hachiya 2007 ^87^ Japan 17286569 | WACA | WACA + ablation of potentials induced by adenosine | 170 | 82 | no AF (no AAD) | 6 mo | 60% | 73% | 0.04 | Poor
Matsuo 2007 ^90^ Japan 17506857 | PVI (ostia or antrum) | PVI + ablation of potentials induced by adenosine | 94 | 54 | freedom from AF after single procedure (no AAD) | 20 mo | 60% | 80% | <0.05 | Poor
Matsuo 2007 ^90^ Japan 17506857 | PVI (ostia or antrum) | PVI + ablation of potentials induced by adenosine | 94 | 54 | maintenance of NSR (no AAD) after last procedure | 20 mo (?) | 90% | 91% | | Poor
94 | 54 | repeat ablation | 5.6 mo | 38% | 17% | <0.05
Walczak 2006 ^94^ Poland 16444625 | Selective PVI (0–3 PVs) | non-selective PVI (4 or 5 PVs) | 60 | 20 | effective rhythm control (no AT lasting >30 s) (31 on AADs) | 17 mo | 90% | 80% | nd | Poor
Pappone 2004 ^36^ Italy 14707026 | WACA + posterior LA lines + MIL | WACA + posterior LA lines + MIL + vagal denervation | 195 | 102 | freedom from recurrent AF | 12 mo | 85% | 99% | <0.001 | Poor
Kettering 2008 Germany 18507536 | PVI | PVI (exclude areas near esophagus) | 21 | 22 | freedom from recurrent AF | 6 mo | 81% | 82% | 1.00 | Poor

Sixteen RCTs, ^33,^ ^46,^ ^48,^ ^50,^ ^52,^ ^56,^ ^72^ – ^81^ two nonrandomized comparative trials, ^82,^ ^83^ two prospective cohort, ^84,^ ^85^ and seventeen retrospective cohort studies ^36,^ ^38,^ ^40,^ ^47,^ ^70,^ ^86^ – ^98^ reported outcomes of RFA for AF using different techniques. Sample size in these studies ranged from 43 to 560. Eleven RCTs compared PVI within and around the PV ostia with either WACA or additional ablation lines (CTI, MIL, roof line, posterior LA line or WACA) with respect to AF recurrence. One nonrandomized comparative trial compared PVI using antral ablation with versus without additional ablation dependent on residual potentials. Two RCTs excluded patients with PAF. ^77,^ ^80^ Six RCTs included only patients with PAF. ^48,^ ^50,^ ^73,^ ^76,^ ^78,^ ^81^ The rest of the RCTs included a mixture of patients with either paroxysmal or persistent/permanent AF. The comparisons in retrospective studies were similarly diverse. Methodological quality of eleven RCTs was rated fair. The rest of the studies were rated poor.

#### Randomized Controlled Trials

PVI versus WACA. Five RCTs compared the efficacy of ostial PVI to WACA with or without additional ablation lines in maintaining sinus rhythm, randomizing a total of 500 patients with followup ranging from 6 to 15 months. ^46,^ ^50,^ ^52,^ ^74,^ ^75^ The proportion of patients with PAF in the studies ranged from 51% to 100%. Only two studies reported results after one procedure and off AADs. Both found that patients who had WACA had a higher rate of success (freedom from AF recurrence) than patients who had ostial PVI (67% vs. 49%, P≤0.05; ^52^ 88% vs. 67%, P=0.02; ^50^ ). Two ^46,^ ^75^ of three studies ^46,^ ^74,^ ^75^ that included patients who had reablation during followup also reported similar findings.

RFA with or without additional left sided ablation lines. Six RCTs (total enrolled 1,069, followup ranging from 7 to 17 months) directly compared the efficacy of one RFA technique with versus without the addition of left-sided ablation lines (e.g., mitral-isthmus, roof or posterior LA lines). ^33,^ ^56,^ ^72,^ ^73,^ ^78,^ ^80^ One study included only patients with persistent AF. ^80^ The proportion of patients with PAF in the rest of the studies ranged from 63% to 100%. The majority of the studies reported AF recurrence rates including patients who had reablation or were continued on AADs. The one study that included only patients with persistent AF found that the addition of LA linear lines to PVI and CTI improved the rate of freedom from AF (69% vs. 20%, P=0.0001). Three of five studies of patients with PAF or nonparoxysmal AF found that patients who had additional left sided ablation lines had less AF or atrial arrhythmia recurrence at followup than patients who did not (MIL: 71% vs. 53%, P=0.01; ^56^ roof line: 87% vs. 69%, P=0.04; ^73^ MIL: 74% vs. 83%, no P value; ^72^ Two studies did not find a significant difference in AF recurrence with the addition of left-sided ablation lines. ^33,^ ^78^

PVI versus PVI with right sided lines. While several RCTs (as described above) included CTI in all randomized patients, only one directly examined the incremental benefit of adding CTI in patients undergoing RFA for AF. ^79^ This study of 108 patients with AF (59% PAF) and at least one episode of atrial flutter found no significant difference in AF recurrence between the group that had ostial-antral PVI and the group that had ostial-antral PVI with CTI ablation at 12 months followup. This finding included some patients who had repeat procedure and some who were on AADs. It should be noted that at 2 months postprocedure, no patients in the CTI group had atrial flutter, while 5% of the patients in the group without CTI had recurrent sustained atrial flutter.

Another RCT compared WACA with versus without superior vena cava ablation. ^81^ This study of 106 patients with PAF found no significant difference in recurrence of atrial tachyarrhythmia between the patients who had WACA with superior vena cava ablation and the patients who only had WACA at 12 months followup.

Miscellaneous comparisons. One study randomized 100 patients with AF (75% PAF) to either modified WACA (WACA, then PVI inside circular lines in patients with residual PV conduction) or aggressive WACA (WACA, then closure of gaps in patients with residual intraoperative PV conduction). ^48^ At 13 months followup, 58% of patients in the former versus 82% in the latter had no atrial tachyarrhythmia after the initial procedure and did not need AADs (P=0.01).

One study randomized 60 patients whose AF were not terminated or inducible after WACA and MIL and posterior lines into either no further treatment or additional ablation on the LA septum and roof and posterior mitral annulus and/or anterior wall based on fractionated or rapid atrial activity. ^76^ At 6 months, 67% of patients in the former compared to 86% in the latter were free of AF without AADs (P=0.05). There were no additional reablations in these patients during followup.

One study randomized 80 patients with chronic AF (present for ≥6 months without SR and recurred within 1 month after cardioversion) to either WACA and posterior LA (or roof line) and MIL or nonencircling LA roof, septum, anterior wall, mitral isthmus and annulus lines. ^77^ At 10 months followup, 48% of patients in the former versus 33% in the latter had no AF or atrial flutter after the initial procedure and did not need AADs (P=0.20).

#### Nonrandomized Comparative Trial

PV ablation with or without assessment of electrical isolation. One study assigned 60 patients to either antral PV ablation without checking for electrical isolation or antral PV ablation with assessment of electrical isolation and additional ablation for residual potentials. ^82^ At 15 months followup, 13% of patients in the former versus 53% in the latter had stable sinus rhythm and did not need AADs (P=0.002). This analysis included patients who had repeat procedures (13%).

Selective PVI versus PVI in all 4 PVs. One study on patients with PAF compared 42 subjects who had selective PVI (only in PVs with triggering AF) with 35 subjects who had PVI in all 4 PVs. ^83^ Followup duration was 39 months; there was no significant difference in AF recurrence between the two groups (62% vs. 74%). It was unclear how the patients were assigned to the respective study group.

#### Prospective Cohort

PVI with or without superior vena cava isolation. One study followed 407 patients who had either antral PVI or antral PVI with superior vena cava isolation. ^84^ No overall comparative data between the two groups were provided. Sixty-six patients had recurrence of AF at a mean followup of 15 months. A repeat ablation procedure was performed in 25 of the 66 patients who had recurrent AF. Five of these 25 patients (20%) were found to have AF initiated by superior vena cava triggers, of whom four were in the group that had only antral PVI (4/190, 2%) and one was from the group that had antral PVI with superior vena cava isolation (1/217; 0.4%), P<0.05.

PVI with or without additional right sided ablation lines. One study compared 113 patients who had ostial PVI and additional posterior LA line and/or MIL when required (in patients who failed PVI or had persistent or permanent AF) to 75 patients who also had additional CTI (these patients had either a history of atrial flutter or atrial flutter during ablation). There was no significant difference in the rate of stable sinus rhythm at 30 months followup (79% vs. 82%, respectively). ^85^

#### Retrospective Cohort

Retrospective studies compared many different approaches to RFA. These observational studies have limitations in the comparability between groups. Historical controls were used in half of the studies. In some of the studies, proportions of patients with different types of AF were different between groups, and followup results from different time points were compared between groups. None of the studies adjusted for potential confounders. It is difficult to draw conclusions from this group of studies.

Ostial versus antral PVI. Three studies compared ostial versus antral PVI. ^91,^ ^92,^ ^95^ Sample size ranged from 77 to 187. Followup ranged from 6 months to 2.8 years. Two of three studies found that patients who had antral PVI had less AF recurrence than patients who had ostial PVI (89% vs. 50%, P<0.001; ^91^ 69% vs. 47%, P<0.05 ^c^ ; ^92^ ). One study did not find a difference in AF recurrence rates between the two groups, although the recurrence rates were measured at different time intervals between the two groups. ^95^

c P value from three way comparison of ostial vs. antral vs. WACA (Bonferroni)

Ostial PVI versus WACA. Seven studies compared ostial PVI with WACA. ^38,^ ^40,^ ^86,^ ^89,^ ^92,^ ^93,^ ^96,^ ^97^ Sample sizes ranged from 73 to 234. Followup ranged from 6 to 26 months. While four ^40,^ ^86,^ ^89,^ ^92^ of six studies reported that patients who had WACA had less AF recurrence than patients who had ostial PVI, only one of them provided a statistical comparison (87% vs. 47%, P<0.05 ^d^ ; ^92^ ). Three studies did not report significant differences in AF recurrence rates between the two groups. ^38,^ ^93,^ ^96,^ ^97^

d P value from three way comparison of ostial vs. antral vs. WACA (Bonferroni)

PVI with or without additional left sided ablation lines. One study compared 100 patients who had ostial PVI, CTI, and MIL with a historical cohort of 100 patients who had PVI and CTI. ^47^ All patients had PAF. At 12 months followup, freedom from atrial arrhythmia without the use of AADs was 87% in the former versus 69% in the latter (P=0.002).

RFA with or without ablations of complex fractionated atrial electrograms (CFAE). Two studies compared RFA with or without CFAE ablations. ^70,^ ^88^ The sample size was 84 ^88^ and 200, ^70^ respectively. Followup were at 9 ^88^ and 12 months, ^70^ respectively. The studies did not find a significant difference in freedom from AF between those who did and those who did not have CFAE ablations (71% vs. 67%; ^88^ 85% vs. 80%; ^70^ ). One study compared the subgroup of patients with persistent/permanent AF with additional CFAE ablations to the subgroup without additional CFAE ablations and found that the freedom from AF recurrence was 82% versus 72% (P=0.047), respectively. ^70^

RFA with or without adenosine infusion. Two studies compared RFA with or without ablation of adenosine-induced potentials. ^87,^ ^90^ Both studies used historical cohorts for comparisons. Sample size was 202; ^90^ and 252; ^87^ respectively. Followup were at 20; ^90^ and 6 months; ^87^ respectively. Both studies found that patients who had additional ablation of adenosine-induced potentials had less AF recurrence than patients who did not (80% vs. 60%, P<0.05; ^90^ 73% vs. 60%, P=0.04; ^87^ ).

Miscellaneous comparisons. One study compared 102 patients who had RFA with additional ablation at sites that induced vagal reflexes ^e^ to 195 patients who had RFA only. ^36^ At 12 months followup, freedom from AF was 99% in the former compared to 85% in the latter (P<0.001).

e RF energy was delivered for up to 30 seconds or until vagal reflexes were abolished); vagal reflexes were defined as sinus bradycardia (40 bpm), asystole, AV block, or hypotension that occurred within a few seconds of the onset of RF application (P<0.001).

One study compared 60 patients who had ablations of 0 to 3 PVs (i.e., single focal isolations elsewhere besides the PV were counted as zero PV ablation) with 20 patients who had ablations of 4 to 5 PVs. ^94^ At 17 months followup, 90% of patients in the former versus 80% in the latter were free from atrial tachyarrhythmia (no P value reported).

One study compared 21 patients with segmental PVI with 22 patients who had segmental PVI with exclusion of sites adjacent to the esophagus if such sites were identified (16/22 patients had this modified procedure). ^98^ At 6 months followup, 81% of patients in the former versus 82% in the latter were free from recurrent AF (P=1.0).

### Technical Issues Related to RFA (Tables 12 and 13)

In this section, we evaluated only findings from direct comparisons. We did not make indirect comparisons across studies (such as comparing a study of PVI via an 8 mm tip catheter with a different study of PVI via an irrigated-tip catheter).

Table 12 Study characteristics of technical issues related to RFA

Author Year Country UI | Group 1 | Group 2 | Additional RFA | Checked inducibility (yes/no) | Total N_enrolled_ | Enrollment Years | % PAF | Mean Age, yr | Male, % | Mean LAD, cm | Mean LVEF, % | Symptom duration, year
Randomized controlled trials
Dixit 2006 ^49^ 16879626 | PVI - 8 mm | PVI - Closed irrigated tip | No | yes | 82 | 2003-2005 | 72 | 57 | 73 | nd | nd | 5.2
Dixit 2008 US ^44^ ^a^ 18242535 | PVI - 8 mm | PVI - Closed irrigated tip | Simulation protocol to elicit non-PV triggers, which also were targeted | yes | 91 | 2003-2005 | 73 | 57 | 72 | nd | nd | 5.2
Marrouche 2007 ^101^ Germany 17490437 | PVI - 8 mm with ICE and monitoring of microbubbles | PVI - Open irrigated tip with ICE and monitoring of microbubbles | Electrical isolation of the SVC | no | 53 | nd | 62 | 54 | 75 | 4.3 | nd | 5.0
Kanj 2007 ^99^ USA and Italy 17433955 | PVI - 8 mm | Group 2: PVI - Open irrigated tip 30–50 W Group 3: PVI - Open irrigated tip 10–35 W | Electrical isolation of the SVC | no | 180 | nd | nd | 60 | 81 | 4.2 | 54 | 6.0
Wang, 2007 ^104^ China 17522081 | PVI - no intraoperative post procedure observation (Obs) time | Group 2: PVI - 30 min Obs time Group 3: PVI - 60 min Obs time | Circumferential RFA of PV antra | no | 90 | 2006 | 100 | 56 | 57 | 3.8 | nd | 4.2
Rotter 2005 ^102^ France 15741228 | PVI guided by 3D electroanatomic mapping | PVI guided by conventional fluoroscopy | Roof-line (LA) if persistent or inducible sustained AF | yes | 72 | nd | nd | 52 | 88 | 4.3 | 66 | nd
Tondo, 2005 ^103^ Italy 15683472 | PVI guided by 3D electroanatomic mapping | PVI guided by conventional fluoroscopy | WACA; CTI | no | 60 | nd | 63 | 56 | 52 | 4.0 | 57 | nd
Kistler 2008 ^100^ UK 18931059 | PVI guided by a 3D electroanatomic mapping + CT integration | PVI guided by fluoroscopy + CT registration | WACA | no | 80 | 2006 | 59 | 56 | nd | nd | nd | 6.3
Tang 2008 ^122^ China 18364135 | PVI guided by a 3D electroanatomic mapping + CT integration | PVI guided by a 3D electroanatomic mapping | Linear ablation of the cavotricuspid isthmus | no | 81 | nd | 100 | 59.8 | 67 | 3.8 | 61 | 3.1
Sra 2007 ^67^ US 17284262 | PVI guided by fluoroscopy + CT registration | PVI guided by conventional fluoroscopy | WACA | no | 50 | nd | 64 | 55 | 82 | 4.5 | 47 | 3.5
Nonrandomized comparative trials
Matiello 2008 ^37^ Spain 18515285 | Group 1: PVI - 8 mm | Group 2: PVI - Closed irrigated tip (30 W) Group 3: PVI - Closed irrigated tip (40 W) | Mitral isthmus ablation | no | 221 | nd | 62 | 52 | 76 | 4.1 | nd | nd
Nilsson 2006 ^107^ Denmark 17043070 | PVI - 5mm Open irrigated tip 45 W | PVI - 5mm Open irrigated tip 30 W | No | no | 90 | nd | 57 (45 W) vs. 71 (30 W) | 55 (45 W) vs. 51 (30 W) | 67 (45 W) vs. 80 (30 W) | nd | nd^c^ | 4.6 (45 W) vs. 6.4 (30 W)
Martinek 2007 ^61^ Austria 17897124 | PVI - conventional electro-anatomic mapping | PVI - multislice CT integration with electroanatomic mapping | WACA or RFA of CFAEs | no | 100 | 2005 | 59 | 56 | 85 | 4.8 | 55 | 6.5
Estner 2006 ^106^ Germany 16831837 | PVI guided by conventional fluoroscopy | PVI guided by 3D electroanatomic mapping (without 3D geometric reconstruction) | No | no | 64 | nd | 94 (PVI) vs. 88 | 59 | 75 | 4.7 | 33 | 5.6
Piorkowski 2008 ^105^ Germany 18684284 | PVI using a manually controlled steerable sheath | PVI using a conventional nonsteerable transseptal sheath | Roof line and mitral line | no | 166 | Group 1: Jan 2006 and October 2006 Group 2: October 2004 and December 2005 | 80 | 55 | 73 | 3.7 | 61 | 4.4
Retrospective cohorts
Yamada, 2006 ^110^ Japan 16607049 | PVI - 8 mm | PVI - 4 mm (nd) | Gaps between peri-ostial ablation sites (only for 8 mm catheter) | no | 108 | nd | 100 | 57 | 90 | 3.5 | 66 | 4.0
Marrouche, 2003 ^108^ USA 12756153 | PVI with no ICE | Group 2: PVI with ICE but no monitoring of micro-bubble Group 3: PVI with ICE and monitoring of micro-bubble | No | no | 315 | 2000-2002 | 51 | 54 | 78 | 4.2 | nd | 6.0
Yamane, 2002 ^111^ France 11955852 | PVI guided by mapping the earliest PV potential | PVI guided additionally by electrogram polarity reversal | No | yes | 157 | nd | 100 | 54 | 60 | 3.7 | nd | 4.7
Saad 2003 ^109^ USA 12693885 | PVI guided by a circular mapping catheter | PVI guided by a 3D electroanatomic mapping system | No | no | 335 | nd | 52 | 54 | 78 | 4.2 | 53 | 5.2
Katritsis 2008 ^97^ Greece 18363086 | Ostial or antral PVI; Ablation time < median | Ostial or antral PVI; Ablation time > median | WACA | nd | 90 | nd | 100 | 55 | 83 | 4.1 | nd | nd

a Dixit 2008 is a subsequent study of Dixit 2006 with 1 year followup data and including slightly more patients. The patients were largely overlapped between these two studies.

b CHF: 4.4% (45 W) vs. 9% (30 W)

c No breakdown patient characteristics by groups was reported

Table 13 Outcomes comparing different technical issues related to RFA

Study, Year UI | Description | | No. Analyzed | | Outcome | Mean Follow-up, mo | Metric/Units | Results | | | Quality
Group 1 | Group 2 | Group 1 | Group 2 | Group 1 | Group 2 | P Between
Randomized controlled trials of 8mm vs. irrigated tip
Dixit 2006 ^49^ 16879626 | PVI - 8 mm | PVI - Closed Irrigated tip | 41^a^ | 40 | Complete freedom and/or >90% reduction in AF burden on or off previously ineffective AADs | 6 | rate | 78% | 70% | NS | Good
Dixit 2008 US ^44^ 18242535 | PVI - 8 mm | PVI - Closed irrigated tip | 41^a^ | 50 | Complete freedom and/or >90% reduction in AF burden on or off previously ineffective AADs | 12 | rate | 78% | 70% | NS | Good
Kanj 2007 ^99^ (comparison 1) USA and Italy 17433955 | PVI - 8 mm | PVI - Open Irrigated tip 30–50 W | 59 | 61 | Freedom from atrial arrhythmia off AAD | 6 | rate | 79% | 82% | 0.04^c^ | Fair
Kanj 2007 ^99^ (comparison 2) USA and Italy 17433955 | PVI - 8 mm | PVI - Open Irrigated tip 10–35 W | 59 | 60 | Freedom from atrial arrhythmia off AAD | 6 | rate | 79% | 68% | 0.04^c^ | Fair
Marrouche 2007 ^101^ Germany 17490437 | PVI - 8 mm | PVI - Open Irrigated tip | 27 | 26 | Recurrence of atrial arrhythmia^d^ | 14 | rate | 19% | 22% | NS | Fair
Randomized controlled trials of different tip outputs
Kanj 2007 ^99^ (comparison 3) USA and Italy 17433955 | PVI - Open Irrigated tip 30–50 W | PVI - Open Irrigated tip 10–35 W | 61 | 60 | Freedom from atrial arrhythmia off AAD | 6 | rate | 82% | 68% | 0.04^c^ | Fair
Randomized controlled trials of different imaging Modalities
Rotter 2005 ^102^ France 15741228 | PVI guided by 3D electroanatomic mapping | PVI guided by conventional fluoroscopy | 35 | 37 | Freedom from arrhythmia | 6.5 | rate | 74% | 78% | NS | Fair
Tondo, 2005 ^103^ Italy 15683472 | PVI guided by 3D electroanatomic mapping | PVI guided by conventional fluoroscopy | 30 | 30 | AF recurrence | 7 | rate | 10% | 20% | nd | Poor
Kistler 2008 ^100^ UK 18931059 | PVI guided by a 3D electroanatomic mapping + CT integration | PVI guided by fluoroscopy + CT registration | 38 | 39 | Freedom from AF or AT | 6 | rate | 50% | 56% | NS | Fair
Recurrent AF or AT | 12 | rate | 58% | 51% | NS
Tang 2008 ^122^ China 18364135 | PVI guided by a 3D electroanatomic mapping + CT integration | PVI guided by a 3D electroanatomic mapping | 42 | 39 | No recurrence of symptomatic and asymptomatic AT | 12 | rate | 79% | 74% | NS | Fair
Sra 2007 ^67^ US 17284262 | PVI guided by fluoroscopy + CT registration | PVI guided by conventional fluoroscopy | 25 | 25 | Freedom from arrhythmia | 9 | rate | 84% | 64% | nd | Poor
Randomized controlled trials of different Observation times
Wang, 2007 ^104^ (comparison 1) China 17522081 | PVI - no intraoperative post procedure observation (Obs) time | PVI - 30 min Obs time | 18 | 21 | Any AT (symptomatic or asymptomatic) lasting >30 secs (documented) | 6 | rate | 39% | 14% | .03^g^ | Fair
Wang, 2007 ^104^ (comparison 2) China 17522081 | PVI - no intraoperative post procedure observation (Obs) time | PVI - 60 min Obs time | 18 | 21 | Any AT (symptomatic or asymptomatic) lasting >30 secs (documented) | 6 | rate | 39% | 5% | .03^g^ | Fair
Nonrandomized comparative trials
Matiello 2008 ^37^ Spain 18515285 | Group 1: PVI - 8 mm | PVI - Closed irrigated tip (30–40 W) | 90 | 131 | Arrhythmia free after a single procedure, on or off AADs. | 12 | rate | 53% | 49% | nd | Poor
Matiello 2008 ^37^ Spain 18515285 | Group 2: PVI - Closed irrigated tip (30 W) | Group 3: PVI - Closed irrigated tip (40 W) | 42 | 89 | Arrhythmia free after a single procedure, on or off AADs. | 12 | rate | 35% | 55% | nd | Poor
Nilsson 2006 ^107^ Denmark 17043070 | PVI - 5 mm irrigated tip 45 W | PVI - 5 mm irrigated tip 30 W | 45 | 45 | Stable SR with no symptomatic recurrent AF | 15 | rate | 76% | 74% | NS | Poor
No need additional AAD | 15 | rate | 56% | 54% | NS
Martinek 2007 ^61^ Austria 17897124 | PVI - conventional electro-anatomic mapping | PVI - multislice CT integration with electroanatomic mapping | 53 | 47 | Full success: free of arrhythmias without class IC or class III AAD | 6 | rate | 49% | 77% | nd | Poor
Martinek 2007 ^61^ Austria 17897124 | PVI - conventional electro-anatomic mapping | PVI - multislice CT integration with electroanatomic mapping | 53 | 47 | No symptomatic recurrences, on AAD | 6 | rate | 19% | 9% | nd | Poor
Full success + success on AAD | 6 | rate | 68% | 85% | .02^h^
Estner 2006 ^106^ Germany 16831837 | PVI guided by conventional fluoroscopy | PVI guided by 3D electroanatomic mapping (without 3D geometric reconstruction) | 32 | 32 | Freedom from recurrence of symptomatic AF | 10.0 (fluoroscopy) vs. 9.5 (3D) | rate | 87% | 90% | nd | Poor
Estner 2006 ^106^ Germany 16831837 | PVI guided by conventional fluoroscopy | PVI guided by 3D electroanatomic mapping (without 3D geometric reconstruction) | 32 | 32 | Sinus rhythm | 10.0 (fluoroscopy) vs. 9.5 (3D) | rate | 68% | 74% | NS | Poor
Asymptomatic AF | 10.0 (fluoroscopy) vs. 9.5 (3D) | rate | 19% | 16% | NS
Piorkowski 2008 ^105^ Germany 18684284 | PVI using a manually controlled steerable sheath | PVI using a conventional nonsteerable transseptal sheath | 79 | 83 | AF recurrence (on or off AAD) | 6 | rate | 24% | 42% | 0.0009 | Poor
Retrospective cohorts
Yamada, 2006 ^110^ Japan 16607049 | PVI - 8 mm | PVI - 4 mm (nd) | 61 | 47 | Freedom from recurrence (no explicit definition; after multiple procedure) | 6 | rate | 84% | 66% | <.05 | Poor
Marrouche, 2003 ^108^ USA (comparison 1) 12756153 | PVI guided by circular mapping alone with no ICE | PVI with ICE (with or without monitoring of microbubbles) (group 2+3) | 56 | 259 | Freedom from recurrent AF | 21 (no ICE) vs. 11 (ICE) | rate | 80% | 87% | .01 | Poor
Marrouche, 2003 ^108^ USA (comparison 2) 12756153 | PVI with ICE but no micro-bubble | PVI with ICE and micro-bubble | 107 | 152 | Chronic success (not defined) | 14 (no micro-bubble) vs. 9 (micro-bubble) | rate | 80% | 90% | .01 | Poor
Yamane, 2002 ^111^ France 11955852 | PVI guided by mapping the earliest PV potential | PVI guided additionally by electrogram polarity reversal mapping | 113 | 44 | Free from AF (not explicitly defined) | 9 | rate | 42% | 39% | NS^j^ | Poor
Saad 2003 ^109^ USA 12693885 | PVI guided by a circular mapping catheter | PVI guided by electroanatomic mapping | 264 | 71 | Cure of AF after the last procedure without AAD (not explicitly defined) | 6 | rate | 92% | 30% | nd | Poor
Katritsis 2008 ^97^ Greece 18363086 | Ostial or antral PVI; Ablation time < median | Ostial or antral PVI; Ablation time > median | 45 | 45 | Freedom from AF | 12 | rate | 49% | 80% | 0.002 | Poor

a Excluding patient who died from atrio-esophageal fistula. Dixit 2008 is a subsequent study of Dixit 2006 with 1 year followup data and including slightly more patients. The patients largely overlapped between these two studies.

b Patients with recurrent AF during the 2-mon period were cardioverted

c P-value from chi-square test comparing 3 groups (8mm, irrigated 30–50 W, and irrigated 10–35 W)

d 2 patients in each groups had 2nd procedure

e Implied blanking period based on late recurrence (14 mo) rates were lower than early recurrence (8 wk) rates.

f Patients with recurrent AF during the 2-mo period were cardioverted

g P-value from chi-square test comparing 3 groups (no observational time, 30-min, and 60-min observational time)

h Non-concurrent comparison (first 53 patients compared with second 47 patients)

i Non-concurrent comparison (patients enrolled 2002-2004 compared with patients enrolled after 2004)

j Non-concurrent comparison (first 113 patients compared with second 44 patients)

Ten RCTs, ^44,^ ^49,^ ^67,^ ^68,^ ^99^ – ^104^ five nonrandomized comparative trials, ^37,^ ^61,^ ^105^ – ^107^ and five retrospective cohort studies ^97,^ ^108^ – ^111^ reported outcomes of PVI for AF comparing catheter tips, energy outputs, imaging guidance, or postprocedure duration of observation in the electrophysiology (EP) laboratory. Sample sizes in these studies ranged from 50 to 335 subjects. Patient characteristics were heterogeneous across studies, including proportion of patients with PAF (51% to 100%), percent male (52% to 90%), mean left atrial diameter (3.5 to 4.8 cm), and mean ejection fraction (33% to 66%).

#### Randomized Controlled Trials

8 mm versus irrigated (closed or open) tip catheter. Overall, data from four RCTs ^44,^ ^49,^ ^99,^ ^101^ did not show significant differences in long-term rhythm control comparing 8 mm tip catheters to irrigated (closed or open) tip catheters in patients undergoing PVI for drug refractory AF. Methodological quality of two studies were rated good; ^44,^ ^49^ and two were rated fair. ^99,^ ^101^

Using a 2×2 factorial design, one study randomized 42 patients with drug refractory AF into either electrical isolation of all PVs or electrical isolation of only arrhythmogenic PVs using an 8 mm tip versus a closed irrigated tip catheter. ^49^ The primary outcome, long-term rhythm control of AF, was defined as complete freedom or more than 90% reduction in AF burden either off or on previously ineffective AAD at 6 months following a single ablation procedure. The primary outcome was achieved in 32 patients (78%) in the 8 mm tip catheter arm versus 28 patients (70%) in the irrigated tip catheter arm (OR 1.52, 95% CI 0.56–4.15). A subsequent study by the same group with 1 year followup data including slightly more patients (but overlapped with the previous study) reported the same findings. ^44^ A total of 91 patients with drug refractory AF were randomized to PVI using an 8 mm tip or a closed irrigated tip catheter. Long-term rhythm control of AF was achieved in 32 patients (78%) in the 8 mm tip catheter arm versus 35 patients (70%) in the irrigated tip catheter arm (OR 1.18, 95% CI 0.47–2.99).

Two RCTs compared the outcomes of PVI using an 8 mm versus open irrigated tip catheter for treatment of AF. ^99,^ ^101^ The first RCT randomized 180 patients (mean followup 6 months) into three groups using different tips and settings: 8 mm tip catheter; open irrigated tip catheter with a higher power (50 W) and higher irrigation flow rate (30 mL/min); or open irrigated tip catheter with a lower power (35 W) and lower irrigation flow rate (17 to 30 mL/min). ^99^ The second RCT randomized 53 patients (mean followup 14 months) to either an 8 mm tip catheter or an open irrigated tip catheter, both set to a maximum power of 50 W ablation. ^101^ In both RCTs, there was no significant difference in rhythm control between patients who underwent PVI with an 8 mm tip catheter and those who underwent PVI with an open irrigated tip catheter using a higher power (50 W). However, in the second RCT, more patients who underwent PVI using an 8 mm tip catheter were free from atrial arrhythmia off AADs compared to those patients who underwent PVI using an open irrigated tip catheter with a lower power (35 W) (79% vs. 68%, respectively). Formal statistical testing was only done for differences among the three arms of this RCT (P=0.04), but no pairwise statistical testing was reported.

Different energy outputs. One fair quality RCT compared the outcomes of PVI in 121 patients with drug refractory AF using an open irrigated tip catheter with a higher power (50 W) and irrigation flow rate (30 mL/min) with the same catheter but using a lower power (35 W) and irrigation flow rate (17 to 30 mL/min). ^99^ More patients who underwent PVI using an open irrigated tip catheter with a higher power (50 W) were free from atrial arrhythmia off AADs than patients who underwent RFA with a lower power (35 W) (82% vs. 68%, respectively). As described previously, statistical testing was only done for differences among all three arms of this RCT without pairwise testing. Thus, the reported P value cannot be extrapolated to any of the two arm comparisons.

Different postprocedure duration of observation in the electrophysiology (EP) laboratory. One fair quality RCT examined the impact of postprocedure duration of observation in the EP laboratory on outcomes of PVI in 90 patients with PAF. ^104^ Patients were randomized into three groups of different observation time after PVI: no additional observation time; 30 minutes of observation; and an additional 60 minutes of observation. Patients were monitored and underwent additional ablation if recovery of PV was detected. At 6 months followup, 7/18 patients (39%) with no additional observation time, 3/21 patients (14%) with 30 minutes observation, and 1/21 patients (5%) with an additional 60 minutes observation had atrial tachyarrhythmia lasting >30 seconds. The differences between the three groups were statistically significant (P=0.03).

Different imaging modalities. Five RCTs, three fair quality ^68,^ ^100,^ ^102^ and two poor quality, ^67,^ ^103^ compared different imaging modalities used during RFA. Two RCTs compared a 3-dimensional mapping system with conventional fluoroscopic guidance. The other three RCTs examined the impacts of computed tomographic (CT) integration with either 3-dimensional mapping system or conventional fluoroscopic guidance. Each of the five RCTs enrolled fewer than 100 patients. Overall, data from the fair quality RCTs did not show significant differences in the outcomes of PVI in patients with drug refractory AF up to 1 year followup.

One fair quality RCT ^102^ and one poor quality RCT ^103^ compared the outcomes of PVI guided by a 3-dimensional mapping system versus the same ablation technique using only conventional fluoroscopic guidance in 72 and 60 patients with drug refractory AF, respectively. The fair quality RCT used a closed irrigated tip catheter and the results showed that, after a mean followup of 6.5 months, there was no significant difference in the rate of freedom from arrhythmia between patients who received PVI guided by a 3-dimensional mapping system and those who received PVI guided by conventional fluoroscopic guidance (74% vs. 78%, respectively). Seven patients in each arm were on AADs after ablation. The poor quality RCT used an open irrigated tip catheter. Over a mean followup of 7 months, fewer patients in the 3-dimensional mapping arm had recurrence of AF compared to those patients in the conventional fluoroscopic guidance arm (10% vs. 20%, respectively). No statistical testing was reported for this analysis. In the 3-dimensional mapping system arm, all three patients who had recurrence of AF had the event within 3 months of the ablation and required titration of their medications. In the conventional fluoroscopic arm, there was recurrence of AF in six patients; the timing of the recurrence was not reported, and in four patients the arrhythmias self-terminated.

One fair quality RCT compared the outcomes of PVI guided by a 3-dimensional mapping system with CT integration versus the same ablation technique using PVI guided by fluoroscopy (2-dimensional) with CT registration in 77 patients with drug refractory AF. ^100^ The results showed no significant difference in single procedure success (freedom from AF) between the two groups after 6 months of followup (50% vs. 56%, respectively).

One fair quality RCT compared CT integration versus the same ablation technique using an older version of a 3-dimensional mapping system without CT integration in 81 patients with drug refractory PAF. ^68^ After a mean followup duration of 1 year, there was no significant difference in the rate of ablation success (no recurrence of symptomatic and asymptomatic AT) between the two groups (79% vs. 74%, respectively).

One poor quality RCT compared the outcomes of PVI guided by fluoroscopy (2-dimensional) with CT registration versus the same ablation technique using only conventional fluoroscopic guidance in 50 patients with drug refractory AF. ^67^ Eight patients (five in the CT-fluoro-guided group) had undergone one prior catheter ablation procedure for AF. The results showed that more patients in the CT-fluoro-guided group were free from arrhythmia than those in the conventional fluoroscopic guidance group (84% vs. 64%). No statistical testing was reported for this analysis. The study did not provide information on the use of AADs first month post-ablation.

#### Nonrandomized Comparative Trials

8 mm versus closed irrigated tip catheter. One poor quality nonrandomized comparative trial of PVI compared an 8 mm to opened irrigated tip catheter with two different energy settings (30 or 40 W) in 221 patients with symptomatic AF. ^37^ The first 90 patients received RFA using an 8-mm tip catheter and the next 131 patients received RFA using a closed irrigated tip catheter. At 1 year followup, the probability of being arrhythmia-free after a single procedure was 53% and 49%, respectively (no statistical analysis was done for the difference between groups).

Different energy outputs. The same nonrandomized comparative trial of PVI, described above, also compared the outcomes of PVI using a closed irrigated tip catheter with two different energy settings (30 or 40 W). ^37^ Among the 131 patients, 42 patients received RFA at 45°C and 30 W power output, and the remaining 89 patients received RFA at 45°C and 40 W power output. At 1 year followup, ablation with a closed irrigated-tip catheter at 30 W led to a lower arrhythmia-free rate compared to ablation with a closed irrigated-tip catheter at 40 W (35% vs. 55%).

Another poor quality nonrandomized comparative trial of PVI using a 5 mm open irrigated tip catheter compared the outcomes of higher power (45 W) versus lower power (30 W) settings in 90 patients with AF who had undergone segmental PVI before the study. ^107^ After a mean followup of 15 months, there was no significant difference in the proportion of patients with stable sinus rhythm without symptomatic recurrent AF between groups (76% vs. 74%, respectively; not statistically significant).

Different imaging modalities. In the first study, the first half of 100 consecutive patients with drug refractory AF underwent PVI guided by conventional 3-dimensional electroanatomic mapping were compared to the second half of patients who underwent PVI using the same 3-dimensional electroanatomic mapping with the addition of CT image integration technology. The addition of CT image integration technology was associated with an improvement in rhythm control with or without AADs as compared to conventional 3-dimensional electroanatomic mapping used in the historical controls (85% vs. 68% P=0.02). ^61^

In the second study, the first half of 64 patients with drug refractory AF who underwent PVI with conventional fluoroscopic guidance were compared to the second half of patients who underwent PVI guided by a 3-dimensional mapping system. Patients in the two groups had similar rates of rhythm control over a mean followup of 10 months (74% vs. 68%, not statistically significant). ^106^

The third study described AF mapping and ablation using manually controlled steerable sheath catheter navigation and compared it to an ablation approach with a nonsteerable sheath. Patients (controls) treated with PVI in 2004 and 2005 using a conventional nonsteerable transseptal sheath were matched with subsequent patients (cases) ablated in 2006 with a similar line concept but mapping and ablation performed with a manually controlled steerable sheath. A total of 166 patients were included in the analyses. Patients ablated with the steerable sheath showed an increase in the success rate (freedom from AF) from 56% to 77% (P=0.0009) after a single procedure and 6 months of followup.

#### Retrospective Cohorts

Several retrospective studies compared different techniques of PVI. None of these analyses controlled for differences in RFA operators' experience or variations in RFA techniques. In some studies, there was no explicit definition of rhythm control, and different durations of followup were reported between groups. It is difficult to draw conclusions from this group of studies. Methodological quality of all five retrospective studies in this section was rated poor.

8 mm versus conventional 4 mm tip catheter. One retrospective study reported improved rhythm control (at 6 months) in patients who underwent PVI with an 8 mm tip catheter compared to those who underwent RFA with a conventional 4 mm tip catheter. ^110^ However, repeat RFA was performed only in patients who underwent RFA with an 8 mm tip catheter.

Different imaging or mapping techniques for PVI. Three studies compared the outcomes between different imaging and mapping techniques for PVI. The comparisons were different across studies, including circular mapping alone versus circular mapping enhanced with intracardiac echocardiogram (ICE) with or without monitoring for microbubble formation (which can indicate overheating of atrial tissue with RFA), ^108^ mapping the earliest PV potential alone versus additional mapping by electrogram polarity reversal approach, ^111^ and circular mapping versus electroanatomic mapping. ^109^ A total of 1,149 patients with drug refractory AF who had undergone PVI were analyzed.

In one study, rhythm control was significantly better in patients who underwent ICE-guided PVI compared to circular mapping guided PVI (87% vs. 80%, P=0.01). The difference was more pronounced in those patients in whom ICE guided PVI included the titration of RFA energy based on microbubble formation as compared to circular mapping alone (90% vs. 80%, P=0.009). Among the patients who underwent ICE guided PVI, rhythm control in patients in whom RFA energy was titrated based on microbubble formation was not statistically different compared to ICE guidance without microbubble monitoring (90% vs. 83%, P=0.08). ^108^ In another study, PVI guided by circular mapping had better rhythm control without the use of AADs in 92% (243/264) of patients (including 35 patients with second procedure), compared with the electroanatomically guided technique, in which only 30% (21 of 71) of patients were free of arrhythmia while not on AADs. ^109^ No other significant differences in the patients' outcome were reported in the remaining studies.

Different ablation time. One study reported outcomes of PVI in 90 patients with PAF. ^97^ Of these, 41 patients received ostial-antral PVI (32 patients had purely ostial and 9 patients antral ablation) while 49 patients underwent circumferential ablation. When all patients were analyzed together, it was found that 1 minute increase in RFA time was associated with 16% reduction in the risk for recurrence of AF (HR 0.84, 95% CI 0.77–0.90, P<0.001). This inverse relationship between RFA time and recurrence of AF remained after adjustment for potential confounders such as age, sex, cause of AF, LA size, and type of ablation technique (ostial-antral or circumferential) (HR 0.80, 95% CI 0.72–0.87, P<0.001), even. It is unclear what proportion of patients was on AADs at the time of followup.

## Key Question 4. What are the short- and long-term complications and harms associated with RFA?

Technologies and techniques of RFA of AF have evolved over the last decade. Because the risk of adverse events of RFA may theoretically depend on the specific ablation approach or catheter tip used, the studies were categorized according to ablation approach and catheter tip. For this section, ablation approaches were broadly classified into two groups: ostial (including focal and segmental approaches) and extra-ostial (all other approaches external to the pulmonary vein (PV) ostia including wide area circumferential ablation (WACA)) PV ablation.

A total of 116 cohorts from 100 studies ^23^ – ^30,^ ^33^ – ^35,^ ^37,^ ^39,^ ^40,^ ^43^ – ^56,^ ^58,^ ^59,^ ^61,^ ^63,^ ^65,^ ^68^ – ^71,^ ^73^ – ^75,^ ^77^ – ^83,^ ^85,^ ^87,^ ^89^ – ^95,^ ^97^ – ^140^ involving 22,344 patients reported adverse events: extraostial RFA with irrigated tip catheters (37 cohorts, Table 14), conventional 8 mm tip catheters (22 cohorts, Table 15), or other catheters (10 cohorts, Table 16), ostial PVI with irrigated tip catheter (18 cohorts, Table 17), conventional 8 mm tip (8 studies, Table 18), or other tips (10 cohorts, Table 19), and various ablation approaches (11 cohorts, Table 20).

Table 14 Adverse events (extraostial PVI, cooled- or irrigated-tip)

Author Year UI | F/up, mo | PV Stenosis, no/N (%) | Cardiac Tamponade^a^, no/N (%) | Stroke or [TIA], no/N (%) | Atrioesophageal Fistula, no/N (%) | Peripheral Vascular Complication, no/N (%) | 30-Day Mortality, no/N (%) | Other Major AE, no/N (%)
Wang 2008 ^112^ 18256124 | nd | | 4/452 (0.9%) | 2/452 (0.4%) | | 2/452 (0.4%)^b^ 2/452 (0.4%)^c^
Khaykin 2004 ^113^ 15851113 | 18 | 3/336 (0.9%)^d^ | 4/336 (1%) | 1/336 (0.3%) [1/336 (0.3%)]
Tang 2006 ^68^ 17235682 | 13 | 2/263 (0.8%)^e^ | 4/263 (2%) | 3/263 (1%) | | | | Pneumothorax | 1/31 (3%)
Cardiac arrest | 1/232 (0.4%)
Tao 2008 ^69^ 18855350 | 18.2 | 0/249 | 0/249 | [2/249 (0.8%) | 0/249 | 1/249 (0.4%)^f^ | 0/249
Forleo 2007 ^114^ I7636302 | 23 | 2/221 (0.9%)^e^ | 4/221 (2%) | 2/221 (0.9%) [2/221 (0.9%)]
Shah 2007 ^85^ 17655668 | 30 | 3/188 (2%)^g^ | 3/188 (2%) | | | | | Embolic events | 1/188 (0.5%)
Rotter 2005 ^115^ 16403060 | nd | | 2/181 (1%)
Piorkowski 2008 ^105^ 18684284 | 6 | 0/166 | 2/166 (1%) | | 0/166 | 3/166 (2%) | | Embolic event | 1/166 (0.6%)
Matiello 2008 ^37^ 18515285 | Intra-procedual | 0/159 | 0/159 | [3/159 (2%)] | | | | Pericarditis | 4/159 (3%)
Transient ST elevation | 3/159 (2%)
Jais 2008 ^28^ 19029470 | 12 | 1/155 (0.6%)^hi^ | 2/155 (1%)^i^ | 0/155^i^ | 0/155^i^ | 0/155^i^ | 0/155^i^
Bertaglia 2005 ^116^ 15869666 | 19 | | 2/143 (1%) | [1/143 (0.7%)] | | 1/143 (0.7%)^c^ | | Phrenic nerve paralysis | 1/143 (0.7%)
AV block | 1/143 (0.7%)
Jais 2004 ^47^ 15520313 | 12 | 0/136^j^ | 4/100 (4%) | | | | | Embolic events | 0/136^f^
Coronary artery events | 0/136^f^
Liu 2005 ^117^ 16336813 | 6 | 1/130 (0.8%)^c^ | 1/130 (0.8%) | 1/130 (0.8%) | | 1/232 (0.4%)^g^
Kanj 2007 ^99^ 17433955 | 6 | 0/121 | 2/121 (2%) | 0/121 | 0/121 | 0/121 | 0/121 | Pulmonary edema | 2/121 (2%)
Tondo 2005 ^103^ 15683472 | 7 | No adverse events (no=120)
Liu 2006 ^75^ 17062959 | 9 | 2/110 (2%)^g^ | | | | 1/110 (1%)^f^
Wazni 2003 ^79^ 14610012 | 12 | 2/108 (2%)^l^ | | 0/108
Turco 2007 ^118^ 17302684 | Periprocedural | | 1/107 (0.9%)
Ma 2006 ^119^ 17199954 | 12 | 0/106 | 2/106 (2%) | 0/106 | 0/106 | | 0/106
Wang 2008 ^81^ 18442966 | 12 | 0/106 | | 1/106 (0.9%) | | 3/106 (3%)^c^
Tondo 2006 ^120^ 16981920 | 14 | | 1/105 (1%) | 0/105 | | 5/105 (5%)^b^
Kistler 2007 ^121^ 17916142 | nd | | 1/101 (1%) | [1/101 (1%)]
Liu 2006 ^48^ 17239094 | 13 | 2/100 (2%)^g^ | 1/100 (1%) | 1/100 (1%) | | 1/100 (1%)^f^
Martinek 2007 ^61^ 17897124 | 6 | 3/100 (3%)^g^ | | 1/100 (1%) [2/100 (2%)] | | | | Phrenic nerve paralysis | 1/100 (1%)
Kistler 2006 ^58^ 16989651 | 6 | 1/94 (1%)^m^ | 1/94 (1%) | [1/94 (1%)]
Hocini 2005 ^73^ 16344401 | 15 | 1/90 (1%)^n^ | 1/90 (1%) | | | | | Phrenic nerve paralysis | 1/90 (1%)
Wang 2007 ^104^ 17522081 | 7 | | 0/90 | 0/90 | | 2/90 (2%)^c^
Tang 2008 ^122^ 18364135 | 12 | 0/81 | 2/81 (2%) | 0/81 | 0/81 | | 0/81
Kistler 2008 ^100^ 18931059 | 13.6 | 1/79 (1%) | 2/79 (3%)
Rotter 2005 ^102^ 15741228 | 6.7 | No adverse events (no=72)
Estner 2006 ^106^ 16831837 | 10 | 0/64 | 0/64 | 1/64 (2%) | 0/64 | 0/64
Mantovan 2005 ^82^ 16403059 | 16 | | 1/60 (2%)
Arentz 2007 ^52^ 17562956 | 15 | 1/55 (1%)^o^ | 1/55 (1%) | | | | | Pulmonary edema | 1/55 (1%)
Nilsson 2006 ^46^ 16923426 | 12 | 1/46 (2%)^p^ | | 1/46 (2%) [1/46 (2%)]
Oral 2003 ^50^ 14557355 | 6 | 0/40 | | | | | | Atrial Flutter | 1/40 (3%)
Oral 2005 ^77^ 16253904 | 10 | No adverse events (no=40)
Marrouche 2007 ^101^ 17490437 | 3 | 0/26 | | | 0/26

AE, adverse events; LA, left atrium: nd, no data; PV, pulmonary vein; PVI, pulmonary vein isolation; TIA, transient ischemic attack

a Pericardial effusion that required pericardiocentesis was considered cardiac tamponade.

b AV fistula

c Pseudoaneurysm.

d Asymptomatic PV stenosis with >70% reduction in diameter.

e Asymptomatic PV stenosis with 50% reduction in diameter.

f Catheter insertion site-related bleeding or hematoma requiring interventions (e.g., transfusion).

g Asymptomatic PV stenosis with >50% reduction in diameter.

h Symptomatic PV stenosis requiring interventions (e.g., stent placement).

i Fifty-three patients underwent in total 155 ablation procedures.

j The data were based on total number of procedures. Some patients underwent repeated ablations due to recurrent arrhythmias.

k Femoral vein thrombosis.

l Asymptomatic PV stenosis with 50–70% reduction in diameter.

m No explicit definition of PV stenosis reported.

n Asymptomatic PV stenosis with >70% reduction in diameter.

o Asymptomatic PV with 40% reduction in diameter.

p Asymptomatic PV stenosis with >30% reduction in diameter.

Table 15 Adverse events (extraostial PVI, conventional tip)

Author Year UI | F/up, mo | PV Stenosis, n/N (%) | Cardiac Tamponade^a^, n/N (%) | Stroke or [TIA], n/N (%) | Atrioesophageal Fistula, n/N (%) | Peripheral Vascular Complication, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Kilicaslan 2005 ^123^ 15734612 | 18 | 4/1125 (0.4%)^b^ | | 7/1125 (0.6%)
Pappone 2004 ^33^ 15520310 | 12 | 0/560 | 4/560 (0.7%) | 0/560 | | | | AT | 8/560 (1%)
Wazni 2007 ^124^ 17998456 | nd | | 2/355 (0.6%) | 3/355 (0.8%) | | 31/355 (9%)^c^ 5/355 (1%)^d^
Chugh 2005 ^55^ 15840468 | 13 | No adverse events (no=349)
Hachiya 2007 ^87^ 17286569 | 6 | | 1/252 (0.4%)
Kilicaslan 2006 ^125^ 16684021 | nd | | | 4/202 (2%)
Verma 2007 ^70^ 17338763 | 12 | 0/200 | 0/200 | 0/200
Corrado 2008 ^126^ 18363688 | 20 | | 0/194^e^ | 1/194 (0.5%)^e^ | 0/194^e^ | 0/194^e^ | | Hemothorax | 1/194 (0.5%)^e^
Yamane 2007 ^95^ 17457004 | 22 | 0/117 | | | | | | Atrial flutter | 4/117 (3%)
Essebag 2005 ^45^ 16183686 | 14 | 0/102 | 3/102 (3%) | [1/102 (1%)] | 0/102 | 4/102 (4%) | 0/102
Kottkamp 2004 ^59^ 15312874 | 12 | No adverse events (no=100)
Matiello 2008 ^37^ 18515285 | Intra-procedural | 0/88^f^ | 1/88 (1%) | [1/88 (1%)] | | | | Pericarditis | 4/88 (4%)
Rossillo 2008 ^30^ 18268419 | 15 | 6/85 (7%)^g^ | | 1/85 (1%)
Calò 2006 ^51^ 16781381 | 13 | | | | | 1/80 (1%)^c^ | | Hemothorax | 1/80 (1%)
Oral 2006 ^26^ 16510747 | 12 | 0/77 | 0/77 | 0/77 | 0/77 | 0/77 | 0/77 | Atrial Flutter | 5/77 (6%)
Oral 2006 ^26^ 16510747 | 12 | 0/77 | 0/77 | 0/77 | 0/77 | 0/77 | 0/77 | Sick sinus syndrome | 1/77 (1%)
Pneumonia | 1/77 (1%)
Pak 2008 ^83^ 18284506 | 39 | 1/77 (1%)^f^ | 2/77 (3%) | [1/77 (1%)]
Kanj 2007 ^99^ 17433955 | 6 | 0/59 | 0/59 | [1/59 (2%)] | 0/59 | 0/59 | 0/59
Tamborero 2005 ^93^ 16311935 | 4 | 0/41^h^
Wazni 2005 ^24^ 15928285 | 12 | 1/32 (3%)^g^ | | 0/32 | | | | Bleeding^i^ | 2/32 (6%)
Marrouche 2007 ^101^ 17490437 | 3 | 0/27
Okada 2007 ^91^ 17397672 | 6 | 1/27 (4%)^f^
Krittayaphong 2003 ^23^ 12866763 | 12 | 0/14 | 0/14 | 1/14 (7%) | 0/14 | 0/14 | | Gastrointestinal^j^ | 2/14 (14%)
Krittayaphong 2003 ^23^ 12866763 | 12 | 0/14 | 0/14 | 1/14 (7%) | 0/14 | 0/14 | | Sinus node dysfunction^j^ | 1 (7%)
Krittayaphong 2003 ^23^ 12866763 | 12 | 0/14 | 0/14 | 1/14 (7%) | 0/14 | 0/14
Dizziness^j^ | 1 (7%)
Pre-syncope^j^ | 1 (7%)

AT, atrial tachyarrhythmia; AAD, antiarrhythmic drug; AE, adverse event; nd, no data; adverse events; PV, pulmonary vein; PVI, pulmonary vein isolation; TIA, transient ischemic attack

a Pericardial effusion that required pericardiocentesis was considered cardiac tamponade.

b “Moderate to severe” PV stenosis.

c Catheter insertion site-related bleeding or hematoma requiring interventions (e.g., transfusion).

d Pseudoaneurysm.

e The data are based on the total number of procedures. Some patients underwent repeated procedures due to recurrent arrhythmias.

f Asymptomatic PV stenosis with >50% reduction in diameter.

g Asymptomatic PV stenosis with 50–70% reduction in diameter.

h Asymptomatic PV stenosis with >70% reduction in diameter.

i No details reported.

j Details were not reported. This might have been associated with concurrent AAD.

Table 16 Adverse events (extraostial PVI, various tips or no information on tip)

Author Year UI | F/up, mo | PV Stenosis, n/N (%) | Cardiac Tamponade^a^, n/N (%) | Stroke or [TIA], n/N (%) | Atrioesophageal Fistula, n/N (%) | Peripheral Vascular Complication, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Lakkireddy 2005 ^127^ 16360082 | 12 | (2%)^b^ | | (1%) | | | | Pulmonary edema | (0.5%)
Berruezo 2007 ^43^ 17395676 | 13 | 0/148 | | [2/148 (1%)] | | | | Pericarditis | 6/148 (4%)
Dressler's syndrome | 2/148 (1%)
Zhou 2007 ^71^ 17624261 | 7 | | | 1/148 (0.7%) [2/148 (1%)] | | | 1/148 (0.7%)^c^
Beukema 2005 ^53^ 16203925 | 15 | 0/105
Sheikh 2006 ^78^ 17318445 | 9 | 0/100 | 1/100 (1%) | [1/100 (1%)] | 0/100 | 0/100 | 0/100
Pappone 2006 ^27^ 17161267 | 12 | | | [1/99 (1%)]
Li 2008 ^128^ 18577822 | Intra-procedual | 0/92 | 0/92 | | 0/92
Stabile 2006 ^25^ 16214831 | 12 | 0/68 | 1/68 (1%) | 1/68 (1%) | | | | Phrenic nerve paralysis | 1/68 (1%)
Coronary artery events | 1/68 (1%)
Karch 2005 ^74^ 15927974 | 6 | 3/50 (6%)^d^ | 0/50 | 1/50 (2%) [2/50 (4%)]
Mansour 2004 ^89^ 15149421 | 11 | 0/40 | 1/40 (3%) | 1/40 (3%) | | 2/40 (5%)

AE, adverse events; PV, pulmonary vein; PVI, pulmonary vein isolation; TIA, transient ischemic attack

a Pericardial effusion that required pericardiocentesis was considered cardiac tamponade.

b Asymptomatic PV stenosis with >70% reduction in diameter.

c Died from pulmonary infection.

d Asymptomatic PV stenosis with >50% reduction in diameter.

Table 17 Adverse events (ostial PVI, cooled- or irrigated-tip)

Author Year UI | F/up, mo | PV Stenosis, n/N (%) | Cardiac Tamponade^a^, n/N (%) | Stroke or [TIA], n/N (%) | Atrioesophageal Fistula, n/N (%) | Peripheral Vascular Complication, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Hsu 2005 ^129^ 15683473 | nd | | 14/746 (2%)
Chen 2004 ^35^ 15028358 | 14 | 6/377 (2%)^b^ | 2/377 (1%) | 5/377 (1%) | | | | Pulmonary edema | 1/377 (0.3%)
Bhargava 2004 ^54^ 15028066 | 15 | 6/323 (2%)^b^ | 3/323 (1%) | 3/323 (1%)
Marrouche 2003 ^108^ 12756153 | 13 | 5/315 (2%)^b^ | | 2/315 (0.6%) [3/315 (1%)]
Della Bella 2005 ^39^ 15763523 | 12 | 2/234 (0.9%)^c^ 1/234 (0.4%)^b^ | 3/234 (1%) | 1/234 (0.4%) | | 4/234 (2%)^d^ 2/234 (0.9%)^e^
Fassini 2005 ^56^ 1630289 | Intra-procedural | | 1/187 (0.5%) | [1/187 (0.5%)]
Macle 2002 ^130^ 12475093 | 9 | 0/136 | | 0/136
Hsu 2004 ^131^ 15575053 | 12 | | 2/116 (2%) | 1/116 (0.9%) | | | | Death at 3 mo^f^ | 1/116 (0.9%)
Berkowitsch 2005 ^132^ 15683534 | 12 | 16/104 (15%)^b^
Nilsson 2006 ^107^ 17043070 | 15 | 0/90 | | [2/90 (2%)]
Arentz 2007 ^52^ 17562956 | 15 | 1/55 (1%)^g^ | 1/55 (1%)
Nilsson 2006 ^46^ 16923426 | 12 | | | 1/54 (2%) [1/54 (2%)]
Karch 2005 ^74^ 15927974 | 6 | 6/50 (12%)^h^ | 0/50 | 0/50 [1/50 (2%)]
Thomas 2004 ^133^ 15172657 | nd | 2/158 (1%)^i^ | | 1/48
Kettering 2008 18507536 ^98^ | 6 | 0/43^h^
Dixit 2006 ^49^ 16879626 | 6 | 0/40^b^ | 0/40 | [1/40 (3%)] | 0/40 | | 0/40
Oral 2003 ^50^ 14557355 | 6 | 0/40
Willems 2006 ^80^ 16782716 | 17^j^ | | 1/32 (3%) | [1/32 (3%)]

AE, adverse events; nd, no data; PV, pulmonary vein; PVI, pulmonary vein isolation; TIA, transient ischemic attack

a Pericardial effusion that required pericardiocentesis was considered cardiac tamponade.

b Asymptomatic PV stenosis with >70% reduction in diameter.

c Symptomatic PV stenosis requiring interventions (e.g., stent placement).

d Arteriovenous fistula.

e Venous thrombosis.

f Died from underlying congestive heart failure.

g Asymptomatic PV stenosis with 40% reduction in diameter.

h Asymptomatic PV stenosis with >50% reduction in diameter.

i The unit of analysis was each PV.

j Median.

Table 18 Adverse events (ostial PVI, conventional tip)

Author Year UI | F/up, mo | Cardiac Tamponade^a^, n/N (%) | Cardiac Tamponade, n/N (%) [effusion] | Stroke or [TIA], n/N (%) | Atrioesophageal Fistula, n/N (%) | Peripheral Vascular Complication, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Matsuo 2007 ^90^ 17506857 | 20 | 2/148 (1%)^b^ | 1/148 (1%)
Yamada 2006 ^110^ 16607049 | 6 | 0/108 | 0/108 | 0/108
Yamane 2007 ^95^ 17457004 | 34 | 3/70 (4%)^c^ | | | | | | Atrial flutter | 1/70 (1%)
Okada 2007 ^91^ 17397672 | 6 | 2/50 (4%)^d^
Dixit 2006 ^49^ 16879626 | 6 | 0/42^e^ | 0/42 | 0/42 | 1/42 (2%) | | 1/42 (2%)^f^
Oral 2005 ^77^ 16253904 | 10 | No adverse events (n=40)
Tamborero 2005 ^93^ 16311935 | 4 | 6/32 (19%)^e^
Thomas 2004 ^133^ 15172657 | nd | 4/81 (5%)^b,^ ^g^ | 1/31 (3%)

AE, adverse events; nd, no data; PV, pulmonary vein; PVI, pulmonary vein isolation; TIA, transient ischemic attack

a Pericardial effusion that required pericardiocentesis was considered cardiac tamponade.

b Asymptomatic PV stenosis with 50–70% reduction in diameter.

c No explicit definition of PV stenosis reported.

d Asymptomatic PV stenosis with >50% reduction in diameter.

e Asymptomatic PV stenosis with >70% reduction in diameter.

f Died from LA-esophageal fistula at 2 weeks.

g The unit of analysis was each PV.

Table 19 Adverse events (ostial PVI, various tips or no information on tip)

Author Year UI | F/up, mo | PV Stenosis, n/N (%) | Cardiac Tamponade^a^, n/N (%) | Stroke or [TIA], n/N (%) | Atrioesophageal Fistula, n/N (%) | Peripheral Vascular Complication, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Zado 2008 ^134^ 18462325 | 28 | 1/1506 (0.07%)^b,^ ^c^ 5/1506 (0.3%)^b,^ ^d^ | 12/1506 (0.8%)^b^ | 6/1506 (0.4%)^b,^ ^e^ | 1/1506 (0.07%)^b^ | 1/1506 (0.07)^b,^ ^f^ | | Phrenic nerve injury | 2/1506 (0.1%)^b^
Anaphylaxis | 2/1506 (0.1%)^b^
Sauer 2006 ^135^ 16831982 | 21 | “Major complications” (3%, no=629)
Gerstenfeld 2006 ^136^ 16443531 | 16 | 1/449 (0.2%)^c^ 2/449 (0.4%)^g^ | 6/449 (1%) | 4/449 (0.9%)^d^ | | 1/449 (0.2%)^e^
Saad 2003 ^109^ 12693885 | 5 | 18/335 (5%)^h^
Walczak 2006 ^94^ 16444625 | 17 | 5/183 (3%)^c^
Yamane 2002 ^111^ 11955852 | 9 | 0/157
Proclemer 2008 ^65^ 18667447 | 25 mo (median) | | 5/144 (3%) | 0/144 | | | 0/144
Dixit 2008 ^44^ 18242535 | 12 | 0/105^c^ | 0/105 | 1/105 (2%) | 1/105 (1%) | | 1/105 (1%)
Schwartzman 2003 ^92^ 14574043 | 6 | 2/42 (5%)^i^
Mansour 2004 ^89^ 15149421 | 21 | 0/40 | 2/40 (5%) | 1/40 (3%) | | 0/40

AE, adverse events; PV, pulmonary vein; PVI, pulmonary vein isolation; TIA, transient ischemic attack

a Pericardial effusion that required pericardiocentesis was considered cardiac tamponade.

b The data are based on the total number of procedures. Some underwent repeated procedures due to recurrent arrhythmia.

c Symptomatic PV stenosis requiring interventions (e.g., stent placement).

d Asymptomatic PV stenosis with >70% reduction in diameter.

e Both strokes and TIAs were combined.

f Catheter insertion site-related bleeding or hematoma requiring intervention (e.g., transfusion)

g No explicit definition of PV stenosis reported.

h Asymptomatic PV stenosis with 50–70% reduction in diameter.

i Asymptomatic PV stenosis with >50% reduction in diameter.

Table 20 Adverse events (miscellaneous)^a^

Author Year UI | F/up, mo | PV Stenosis, n/N (%) | Cardiac Tamponade^b^, n/N (%) | Stroke or [TIA], n/N (%) | Atrioesophageal Fistula, n/N (%) | Peripheral Vascular Complication, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Irrigated tip
Nilsson 2006 ^46^ 16923426 | 12 | | | | | | | Embolic events | 4/173 (2%)^c^
Conventional tip
Cha 2008 ^34^ 18474813 | 12 | 7/523 (1.3%)^d^ | 12/523 (2.3%) | 4/523 (0.8%) | | | | hemi-diaphragm paralysis | 4/523 (0.8%)
Cheema 2006 ^40^ 17019636 | 26 | 3/264 (1%)^e^ | 6/264 (2%) | 3/264 (1%) | | 21/264 (8%)^f,^ ^g^ | | Heart block | 1/264 (0.3%)
Valve injury | 1/264 (0.3%)
Oral 2006 ^137^ 16606789 | 11 | | 2/180 (1%)^c^ | [2/180 (1%)^c^]
Various tips or no information on tip
Bertaglia 2007 ^138^ 17905330 | nd | 1/1011 (0.1%)^h^ 3/1011 (0.3%)^d^ | 7/1011 (0.7%) | 4/1011 (0.4%) [1/1011 (0.1%)] | | 10/1011 (10%)^g^ 3/1011 (0.3%)^i^ | 0/1011 | Aortic root puncture | 1/1011 (0.1%)
Bertaglia 2007 ^138^ 17905330 | nd | 1/1011 (0.1%)^h^ 3/1011 (0.3%)^d^ | 7/1011 (0.7%) | 4/1011 (0.4%) [1/1011 (0.1%)] | | 10/1011 (10%)^g^ 3/1011 (0.3%)^i^ | 0/1011 | AV block | 1/1011 (0.1%)
Bertaglia 2007 ^138^ 17905330 | nd | 1/1011 (0.1%)^h^ 3/1011 (0.3%)^d^ | 7/1011 (0.7%) | 4/1011 (0.4%) [1/1011 (0.1%)] | | 10/1011 (10%)^g^ 3/1011 (0.3%)^i^ | 0/1011
Phrenic nerve paralysis | 1/1011 (0.1%)
Pneumothorax | 1/1011 (0.1%)
Gerstenfeld 2007 ^139^ 17081205 | 35 | (0.1%)^h^ (0.6%)^j^ | (0.9%) | (0.5%) [(0.2%)] | 1/1058 (0.1%) | (0.8%)^f^ (0.6%)^g^ (0.7%)^i^ (0.1%)^k^ | 2/1058 (0.2%)^l^ | Cardiogenic shock | (0.1%)
Gerstenfeld 2007 ^139^ 17081205 | 35 | (0.1%)^h^ (0.6%)^j^ | (0.9%) | (0.5%) [(0.2%)] | 1/1058 (0.1%) | (0.8%)^f^ (0.6%)^g^ (0.7%)^i^ (0.1%)^k^ | 2/1058 (0.2%)^l^ | Radiation burn | (0.1%)
Gerstenfeld 2007 ^139^ 17081205 | 35 | (0.1%)^h^ (0.6%)^j^ | (0.9%) | (0.5%) [(0.2%)] | 1/1058 (0.1%) | (0.8%)^f^ (0.6%)^g^ (0.7%)^i^ (0.1%)^k^ | 2/1058 (0.2%)^l^
Coronary air embolism | (0.4%)
Anaphylaxis | 1/1058 (0.1%)
Oral 2006 ^63^ 16908760 | 25 | | | 10/755 (1%)
Spragg 2008 ^140^ 18462327 | < 30 days | 1/641 (0.2%)^c,^ ^m^ | 8/641 (1%)^c^ | 7/641 (1%)^c^ | 0/641^c^ | 11/641 (2%)^c^ | 0/641^c^ | Hemothorax | 1/641 (0.2%)^c^
Spragg 2008 ^140^ 18462327 | < 30 days | 1/641 (0.2%)^c,^ ^m^ | 8/641 (1%)^c^ | 7/641 (1%)^c^ | 0/641^c^ | 11/641 (2%)^c^ | 0/641^c^ | Heart block | 1/641 (0.2%)^c^
Spragg 2008 ^140^ 18462327 | < 30 days | 1/641 (0.2%)^c,^ ^m^ | 8/641 (1%)^c^ | 7/641 (1%)^c^ | 0/641^c^ | 11/641 (2%)^c^ | 0/641^c^
Lung injury | 1/641 (0.2%)^c^
MV injury | 1/641 (0.2%)^c^
Pappone 2003 ^29^ 12875749 | 30 | 0/589 | 4/589 (1%) | 0/589
Schwartzman, 2003 ^92^ 14574043 | 6 | 4/112 (4%)^d^ | | | | 1/112 (1%)^f^ 3/112 (3%)^g^ 2/112 (2%)^I^ | | Non-cardiogenic pulmonary edema | 1/112 (0.9%)
Katritsis 2008 ^97^ 18363086 | 12 | 0/90 | 2/90 (2.2%) | | 0/90

AE, adverse events; AV, atrio-ventricular; MV, mitral valve; nd, no data; PV, pulmonary vein; PVI, pulmonary vein isolation; TIA, transient ischemic attack

a Various different ablation techniques were employed (e.g., extraostial PVI and ostial PVI).

b Pericardial effusion that required pericardiocentesis was considered cardiac tamponade.

c The data were based on total number of procedures. Some patients underwent repeated ablations due to recurrent arrhythmias.

d Asymptomatic PV stenosis with >50% reduction in diameter.

e Asymptomatic PV stenosis with >70% reduction in diameter.

f Catheter insertion site-related bleeding or hematoma requiring interventions (e.g., transfusion).

g Pseudoaneurysm.

h Symptomatic PV stenosis requiring interventions (e.g., stent placement).

i AV fistula.

j PV stenosis with >75% reduction in diameter regardless of symptoms.

k Femoral vein thrombosis.

l One died from anaphylactic shock after the procedure and the other died from left atrio-esophageal fistula at 3 weeks.

m “Occlusion” of PV

In general, the definition and monitoring of adverse events was not uniform among studies, and there were variations in the durations of followup. For example, not all studies evaluated asymptomatic PV stenosis at 3 months by computed tomography, and in those that did, different definitions of severe, moderate, or mild PV stenosis were used. Few studies provided detailed data on the exact timing of an adverse event, or explicitly defined the time frames of short- versus long-term complications. Thus, direct comparisons across studies or different ablation approaches were not possible.

There were 84 studies that reported at least one adverse event associated with RFA. Adverse events included PV stenosis, ^24,^ ^28,^ ^34,^ ^35,^ ^39,^ ^40,^ ^46,^ ^48,^ ^52,^ ^54,^ ^58,^ ^61,^ ^68,^ ^73^ – ^75,^ ^79,^ ^82,^ ^83,^ ^85,^ ^90^ – ^95,^ ^98,^ ^100,^ ^108,^ ^109,^ ^113,^ ^114,^ ^117,^ ^123,^ ^127,^ ^129,^ ^132^ – ^134,^ ^136,^ ^138^ – ^140^ cardiac tamponade, ^25,^ ^28,^ ^29,^ ^33^ – ^35,^ ^37,^ ^39,^ ^40,^ ^45,^ ^47,^ ^48,^ ^52,^ ^54,^ ^56,^ ^58,^ ^65,^ ^68,^ ^73,^ ^78,^ ^80,^ ^82,^ ^83,^ ^85,^ ^87,^ ^89,^ ^90,^ ^97,^ ^99,^ ^100,^ ^105,^ ^112^ – ^122,^ ^124,^ ^131,^ ^133,^ ^134,^ ^136^ – ^140^ stroke or transient ischemic attach (TIA), ^23,^ ^25,^ ^27,^ ^29,^ ^34,^ ^35,^ ^37,^ ^39,^ ^40,^ ^43^ – ^46,^ ^48,^ ^49,^ ^54,^ ^56,^ ^58,^ ^61,^ ^63,^ ^68,^ ^69,^ ^71,^ ^74,^ ^78,^ ^80,^ ^81,^ ^83,^ ^89,^ ^99,^ ^106^ – ^108,^ ^112^ – ^114,^ ^116,^ ^123^ – ^127,^ ^131,^ ^133,^ ^134,^ ^136^ – ^140^ bleeding or hematoma, ^40,^ ^48,^ ^51,^ ^69,^ ^75,^ ^92,^ ^124,^ ^134,^ ^136,^ ^139^ pseudoaneurysm, ^40,^ ^81,^ ^92,^ ^104,^ ^112,^ ^116,^ ^124,^ ^138,^ ^139^ femoral vein thrombosis, ^39,^ ^117,^ ^139^ or arteriovenous fistula. ^39,^ ^92,^ ^112,^ ^120,^ ^121,^ ^138,^ ^139^ (see Tables 14–20)

There were 78 studies that assessed the rates of asymptomatic or symptomatic PV stenosis. ^23^ – ^26,^ ^28^ – ^30,^ ^33^ – ^35,^ ^37,^ ^39,^ ^40,^ ^43^ – ^50,^ ^52^ – ^55,^ ^58,^ ^59,^ ^61,^ ^68^ – ^70,^ ^73^ – ^75,^ ^77^ – ^79,^ ^81,^ ^83,^ ^85,^ ^89^ – ^95,^ ^97^ – ^103,^ ^105^ – ^111,^ ^113,^ ^114,^ ^117,^ ^119,^ ^122,^ ^123,^ ^127,^ ^128,^ ^130,^ ^132^ – ^136,^ ^138^ – ^140^ The majority of these papers reported rates of asymptomatic PV stenosis between 0% and 19% (median 0.3%); of which, 36 studies did not identify a single case of PV stenosis. ^23,^ ^25,^ ^26,^ ^29,^ ^33,^ ^37,^ ^43^ – ^45,^ ^47,^ ^49,^ ^50,^ ^53,^ ^55,^ ^59,^ ^69,^ ^70,^ ^77,^ ^78,^ ^81,^ ^89,^ ^97^ – ^99,^ ^101^ – ^103,^ ^105^ – ^107,^ ^110,^ ^111,^ ^119,^ ^122,^ ^128,^ ^130^ Symptomatic PV stenosis requiring interventions occurred in 0.07% to 0.9% of patients in six studies. ^28,^ ^39,^ ^134,^ ^136,^ ^138,^ ^139^ Cardiac tamponade occurred in 0% to 5% (median 1%) of patients in 70 studies. ^23,^ ^25,^ ^26,^ ^28,^ ^29,^ ^33^ – ^35,^ ^37,^ ^39,^ ^40,^ ^44,^ ^45,^ ^47^ – ^49,^ ^52,^ ^54^ – ^56,^ ^58,^ ^59,^ ^65,^ ^68^ – ^70,^ ^73,^ ^74,^ ^77,^ ^78,^ ^80,^ ^82,^ ^83,^ ^85,^ ^87,^ ^89,^ ^90,^ ^97,^ ^99,^ ^100,^ ^102^ – ^106,^ ^110,^ ^112^ – ^122,^ ^124,^ ^126,^ ^128,^ ^129,^ ^131,^ ^133^ – ^140^ Cerebrovascular events were reported in 0% to 7% (median 0.9%) of patients in 72 studies, ^23^ – ^30,^ ^33^ – ^35,^ ^37,^ ^39,^ ^40,^ ^43^ – ^46,^ ^48,^ ^49,^ ^54^ – ^56,^ ^58,^ ^59,^ ^61,^ ^63,^ ^65,^ ^68^ – ^71,^ ^74,^ ^77^ – ^81,^ ^83,^ ^89,^ ^89,^ ^99,^ ^102^ – ^104,^ ^106^ – ^108,^ ^110,^ ^112^ – ^114,^ ^116,^ ^117,^ ^119^ – ^127,^ ^130,^ ^131,^ ^133^ – ^140^ of which 19 studies reported no cerebrovascular events. ^24,^ ^26,^ ^28,^ ^29,^ ^33,^ ^55,^ ^59,^ ^65,^ ^70,^ ^77,^ ^79,^ ^102^ – ^104,^ ^110,^ ^119,^ ^120,^ ^122,^ ^130^ Atrioesophageal fistula was assessed in 26 studies; ^23,^ ^26,^ ^28,^ ^44,^ ^45,^ ^49,^ ^55,^ ^59,^ ^69,^ ^77,^ ^78,^ ^97,^ ^99,^ ^101^ – ^103,^ ^105,^ ^106,^ ^119,^ ^122,^ ^126,^ ^128,^ ^134,^ ^135,^ ^139,^ ^140^ four of these reported one case each in 0.07% to 1.2% of patients. ^44,^ ^49,^ ^134,^ ^139^ The remaining studies did not identify any cases. In 16 studies, ^25,^ ^26,^ ^28,^ ^30,^ ^44,^ ^45,^ ^49,^ ^65,^ ^69,^ ^71,^ ^99,^ ^119,^ ^122,^ ^138,^ ^140,^ ^141^ five deaths were reported within 30 days postprocedure: one died from pulmonary infection, ^71^ one died from anaphylaxis after the procedure, ^139^ and three died from atrioesophageal fistula (three publications from the same group of investigators each reported one death from atrioesophageal fistula). ^44,^ ^49,^ ^139^

### Patient Characteristics Associated with Adverse Events

Eleven studies evaluated patient characteristics as predictors of certain procedure-related adverse events. Nine studies used univariate analysis to compare risk of adverse events in patients with or without a single predictor of interest; ^35,^ ^54,^ ^68,^ ^103,^ ^114,^ ^123,^ ^127,^ ^131,^ ^134^ whereas two large patient surveys assessed multiple patient-level predictors of various complications. ^138,^ ^140^ In general, studies failed to identify specific patient characteristics that would reliably predict particular adverse events. (Table 21)

Table 21 Studies associating patient characteristics with adverse events^a^

Predictor | PV Stenosis | Cardiac Tamponade^b^ | Stroke or TIA, | Peripheral Vascular Complication | Pulmonary edema | General | Total Studies, n
Gender | NS (H,I) | NS (H,I) | NS (H,I) | NS (I) | | NS (H,J^c^) | 3
Age | NS (B,I) | NS (B,I) | P<0.05 (B) NS (I) | NS (I) | | P=0.04^d^ (J) NS (B,J^e^,K) | 4
Duration of AF | NS (I) | NS (I) | NS (I) | | | | 1
Left atrial size | NS (I) | NS (I) | NS (I) | | | NS (J) | 2
EF | NS (A,I) | NS (A,I) | NS (A,I) | | | NS (J) | 3
CHF | | NS (G) | | P<0.01 (G) | | P<0.01 (G) NS (C) | 2
Paroxysmal AF | NS (I) | NS (I) | NS (I) | NS (I) | | NS (J) | 2
History of CVD | NS (I) | | NS (I) | | | | 1
Valvular HD | NS (I) | P<0.003 (I) | NS (I) | NS (I) | | | 1
CAD | NS (I) | P<0.005^f^ (I) | NS (I) | NS (I) | | | 1
DCM | NS (I) | NS (I) | NS (I) | NS (I) | | | 1
Hypertension | NS (I) | NS (I) | NS (I) | NS (I) | | NS (J) | 2
Diabetes | | | | | | P=0.002^g^ (F) | 1
Pacemaker or ICD | NS (E) | | NS (E) | | NS (E) | | 1
History of cardiac surgery | NS (D) | | NS (D) | | | | 1
Total studies, n | 6 | 5 | 6 | 2 | 1 | 6 | 11

AF, atrial fibrillation; CAD, coronary artery disease; CHD, congestive heart failure; CVD, cerebrovascular disease; DCM, dilated cardiomyopathy; HD, heart disease; ICD, intracardiac device; NS, not significant; TIA, transient ischemic attack.

a P-values are estimated by univariate analysis. Studies are coded as follows: A, Chen 200435 (no=377); B, Bhargava 200454 (no=323); C, Hsu 2004131 (no=116); D, Kilicaslan 2005123 (no=1125); E, Lakkireddy 2005127 (no=172); F, Tang 200668 (no=263); G, Tondo 2005103 (no=105); H, Forleo 2007114 (no=221); I, Bertaglia 2007138 (no=1015); J, Spragg 2008140 (no=640); K, Zado 2008134 (no=1165).

b One study (Bertaglia 2007138) assessed both cardiac tamponade and pericardial effusion requiring prolongation of hospital stay.

c P=0.014 in multivariate analysis. Female gender was significantly predictive of major complications (OR=3.0 [95% CI, 1.3–7.2]).

d P=0.002 in multivariate analysis. Age >70 was significantly predictive of major complications (OR=6.0 [95% CI, 1.9–19.1]).

e P=0.02 in multivariate analysis (the mean age of patients with or without complications was evaluated).

f P<0.008 in multivariate analysis.

g P=0.001 in multivariate analysis.

### Operator- or Hospital-Level Characteristics Associated with Adverse Events

Only one study examined the relationship between operator-level characteristics and adverse events of RFA. Spragg et al. ^140^ reported no statistically significant difference of complication rates between operators who had performed fewer than 50 total cases and those who had performed more than 50 cases (P=0.32).

Two studies reported data on the relationship between a center's learning curve for the procedure and adverse event rates. From a data registry of 1,011 consecutive patients with AF who underwent PV ablation at 10 electrophysiology laboratories, Bertaglia et al. evaluated multiple clinical and procedure-related characteristics to predict PV stenosis, hemorrhagic events, vascular events, and cerebral embolism. ^138^ In univariate analyses, none of these adverse event rates were statistically different between the first 50 procedures in a center and those performed thereafter. Another single center study ^140^ reported higher overall complication rates of 9% in the first 100 cases (9 major complications) compared to 4% in 541 cases thereafter (23 major complications; P values not reported), although no global temporal trends were observed in specific adverse event rates including PV stenosis, cardiac tamponade, stroke, or vascular complications.