# Methods

## Topic Development

The topic for this report was nominated in a public process. With input from technical experts, the Scientific Resource Center for the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program drafted the initial key questions and, after approval from AHRQ, posted them to a public web site. The public was invited to comment on these questions. After reviewing the public commentary, the Scientific Resource Center drafted final key questions and submitted them to AHRQ for approval.

Figure 1. Analytic framework

AF, atrial fibrillation; AADs, antiarrhythmic drugs; RFA, radiofrequency ablation.

This comparative effectiveness review of radiofrequency ablation (RFA) for the treatment of AF is based on a systematic review of the literature. The Tufts Medical Center Evidence-based Practice Center held teleconferences with a technical expert panel (TEP) formed for this project. The TEP served in an advisory capacity for this report, helping to refine key questions, identify important issues, and define parameters for the review of evidence. The TEP included cardiologists who are familiar with RFA and methodologists who are familiar with the evidence review process.

The methods for this comparative effectiveness review follows the methods suggested in the Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0 published by AHRQ (available at http://effectiveheealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf).

Please note that because of the large number of abbreviations for technical terms, their explanations have been repeated within each chapter. Also see the Abbreviations table listed after the references.

## Search Strategy

Our search strategy used the National Library of Medicine's Medical Subject Headings (MeSH) keyword nomenclature developed for MEDLINE^®^ and adapted for use in other databases. The searches were limited to the English language. The primary MEDLINE^®^ and Cochrane Clinical Trials Registry search strategy is presented in Appendix A.

We searched the MEDLINE^®^ and Cochrane Central Trials Registry databases from 2000 to December, 2008 for studies involving adults with atrial fibrillation (AF) who underwent RFA. We combined search terms or MeSH terms for atrial fibrillation, pulmonary vein, radiofrequency ablation, and catheter ablation, and we limited the search to English language articles of studies in adult humans. We included peer reviewed, primary studies of RFA treatment for AF. We excluded case reports and did not search systematically for unpublished data. We invited TEP members to provide additional citations.

## Study Selection

Key questions concerning the comparative effectiveness of RFA with other available treatments (e.g., medical treatment, surgery) were proposed and refined with input from the TEP over a series of teleconferences. Specifically, the questions that should be addressed, the populations of interest, the interventions and appropriate comparators, the outcomes, and the study designs were discussed and refined (see below).

The TEP advised us that the 8 mm and irrigated tip catheters are now the catheters of choice for RFA in the United States, and the conventional 4 mm tip catheter is no longer being used (or is rapidly being phased out). Thus, information on the conventional 4 mm tip catheter was thought to be no longer relevant to current practice. Because the 8 mm and the irrigated tip catheters were introduced in 2003, we decided to restrict our literature search from 2000 onward to ensure that preapproval studies were included.

We assessed titles and abstracts of citations identified from our literature search for inclusion, using the criteria described below. Full-text articles of potentially relevant abstracts were retrieved and a second review for inclusion was conducted by reapplying the inclusion criteria. Results published only as abstracts were not included in our reviews because adequate information is not available to assess the validity of the data and these reports have generally not been peer-reviewed.

### Population and Condition of Interest

We included studies of adults (≥18 years old) with paroxysmal, persistent, or permanent/chronic AF. We accepted the definitions of the various types of AF used by the study authors. For the purpose of this report, the terms “permanent” and “chronic” AF were used as reported in the individual studies, even though the definitions varied. It should be noted that the consensus statement on RFA for the treatment of AF published by the Heart Rhythm Society in 2007 no longer used the term chronic or permanent, the term adopted is longstanding persistent to define a continuous AF of greater than 1 year duration. ^1^ For a study to be included, at least 80 percent of the patients had to be treated with a first time RFA for AF. Study eligibility was not based on type or duration of AF or comorbid conditions. We excluded studies that were limited to patients with congenital heart disease, hypertrophic cardiomyopathy, or Wolff-Parkinson-White syndrome. We excluded studies that included only participants with successful ablations or other postprocedure eligibility criteria.

### Interventions of Interest

The intervention of interest was catheter-directed RFA of the left atrium (LA) with the goal of preventing AF recurrence. The RFA could be used as first or second line treatment of AF, with or without concurrent antiarrhythmic drugs (AADs).

We included studies of RFA strategies in which the explicit or intended goal was targeting of the pulmonary veins (PVs) or PV antra, with or without additional ablation. Studies in which PV electrical isolation was not the goal of ablation were excluded (e.g., standalone RFA of complex fractionated atrial electrograms (CFAE) and linear ablations). We also excluded studies of RFA of the atrioventricular (AV) junction, supraventricular tachycardia, standalone atrial flutter and RFA in conjunction with cardiac surgery.

We did not evaluate cryoablation or microwave ablation. We excluded studies that examined only surgical or medical approaches (without comparing to RFA). Studies of only periprocedural variables such as electrical mapping, atrial imaging techniques, or complications due to RFA that did not report patients' outcomes were excluded. As stated above and per recommendations from the TEP, we included only studies that used 8 mm tip or irrigated tip catheters. We excluded studies that included only 4 mm tip catheters. However, if the comparative arm in the 8 mm or irrigated tip catheter study were a 4 mm tip catheter, that study was included.

### Comparators of Interest

Given the known paucity of comparative studies, we included both uncontrolled and controlled studies, with any medical or surgical comparator.

### Outcomes of Interest

After discussion with the TEP, it was agreed that only relatively long-term clinical outcomes and serious adverse events were of interest, given the chronic nature of AF. For clinical outcomes, we required studies to have a minimum of 6 month followup and where possible, we excluded arrhythmia outcomes that occurred during the blanking period (a period postprocedure during which an episode of AF was not considered a recurrence; this typically ranged from 1 to 3 months after the procedure, as defined by the studies). For safety outcomes, we included all studies regardless of the length of followup.

Outcomes of interest included:

- Rhythm control
  - Rhythm control is defined as the absence of atrial fibrillation or atrial arrhythmia during followup. Surveillance for this outcome varied among studies and included reliance on symptomatic recurrence of the arrhythmia, documentation of the arrhythmia via periodic 12-lead electrocardiograms, continuous cardiac monitoring, or a combination of these approaches.
  - Rhythm control after RFA can be achieved with or without the use of AADs, and if separately reported, both outcomes (with and without AADs) were extracted for this review.
  - We did not exclude studies or findings based on whether a “blanking” period was defined.
- Congestive heart failure
- Left atrial and ventricular size changes
- Stroke
- Quality of life measures
- Avoiding anticoagulation
- Readmissions for AF
- Adverse events due to RFA
  - Symptomatic or severe pulmonary vein stenosis
  - Cardiac tamponade or pericardial effusion requiring intervention
  - Peri-procedural stroke or transient ischemic attack
  - Atrioesophageal fistula
  - Peripheral vascular complication, including deep vein thrombosis, pseudoaneurysm, catheter insertion site hematoma requiring transfusion or invasive intervention, or other vascular injury requiring transfusion or invasive intervention
  - 30-day mortality
  - Other major adverse events reported by the investigators and thought to be related to RFA (e.g., phrenic nerve paralysis)

### Study Designs of Interest

We included studies of any design: randomized controlled trials and nonrandomized trials; prospective and retrospective cohorts. Where the study design of an observational study was unclear (prospective versus retrospective), we assumed it was retrospective.

We also made the following a priori decisions. We included randomized controlled trials (RCTs) of any sample size. For non-randomized comparative studies (RFA versus other intervention or RFA versus RFA), we included only studies with at least 10 subjects per intervention arm, whether prospective or retrospective. For prospective cohort studies (no comparison), we included only those with at least 50 subjects receiving RFA. For retrospective cohort studies reviewed for adverse events, we included only those with at least 100 patients.

## Data Extraction

Data from each study were extracted by one of the reviewers and confirmed by another. The data on RFA techniques in all studies were also confirmed by a clinical cardiac electrophysiologist in the Tufts Medical Center evidence review team. The extracted data included information on patient samples, RFA characteristics (e.g., type of catheter tip, verification of electrical isolation), outcomes, adverse events, study design, and quality. For most outcomes, 6 months, 12 months, and/or only data from the last reported time point were included. Mortality data regardless of postprocedure duration were extracted.

## Quality Assessment

We used predefined criteria to grade study quality as good, fair, or poor. This system defines a generic grading system that is applicable to varying study designs including RCTs, nonrandomized comparative trials, and observational studies. For RCTs, we mainly considered the methods used for randomization, blinding, as well as the use of intention-to-treat analysis, the report of dropout rate and the extent to which valid primary outcomes were described and how well they were reported. Only RCTs could receive a “good” grade. For nonrandomized comparative studies and observational studies, the following elements were considered in assessing quality: clear reporting of eligibility criteria, similarity of comparative groups in terms of baseline characteristics and prognostic factors, use of intention-to-treat analysis, reporting on crossovers, differential loss to followup between the comparative groups or overall high loss to followup, and validity and adequacy of the description of outcomes and results. All retrospective studies were graded poor.

### Good (low risk of bias)

Studies rated “good” have the least bias and results are considered valid. These studies adhere mostly to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20% dropout; clear reporting of dropouts; and no obvious bias. Studies rated “good” must have reported the AF recurrence rate off AADs after the initial RFA procedure. Only RCTs could receive a “good” grade.

### Fair

Studies rated “fair” are susceptible to some bias, but not sufficient to invalidate the results. They do not meet all the criteria in category “good”, they have some deficiencies but none likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.

### Poor (high risk of bias)

Studies rated “poor” have significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; there are large amounts of missing information, or discrepancies in reporting. All retrospective studies received a “poor” grade.

## Rating the Body of Evidence

We assigned an overall grade describing the strength of evidence for each key question that was based on the number and quality of individual studies, duration of followup and the consistency across studies. The overall grade for each key question was rated by the authors who are responsible for the respective question. Differences were resolved by consensus. The grades corresponded to the following definitions:

### High - High confidence that the evidence reflects the true effect

Further research is very unlikely to change our confidence in the estimate of effect. There is a high level of assurance with validity of the results for the key question based on at least two high quality studies with long-term followup of a relevant population. There is no important scientific disagreement across studies in the results for the key question.

### Moderate - Moderate confidence that the evidence reflects the true effect

Further research may change our confidence in the estimates of effect and may change the estimate. There is a moderate level of assurance with validity of the results for the key question based on fewer than two high quality studies or in high quality studies that lack long-term outcomes of relevant populations. There is little disagreement across studies in the results for the key question.

### Low - Low confidence that the evidence reflects the true effect

Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. There is a low level of assurance with validity of results for the key question based on poor quality studies. There could be disagreement across studies in the results for the key question.

### Insufficient - Evidence either is unavailable or does not permit estimation of an effect

The grades provide a shorthand notation of the strength of evidence supporting the answers to the key questions. However, they may oversimplify the many complex issues involved in appraising a body of evidence. The individual studies involved in formulating the composite grade differed in their design, reporting, and quality. As a result, the strengths and weaknesses of the individual reports addressing each key question should also be considered, as described in detail in the text and tables.

## Data Synthesis

For key question 1 (RFA versus other interventions and RFA with versus without AAD) and key question 3 (ostial PVI versus other RFA techniques), relevant eligible studies were compiled into sets of summary tables that succinctly present the study features including design, patient-level and intervention-level characteristics, results, and study quality. For key question 2 (predictors of outcomes), the summary tables included only basic information about the type of RFA, the timing of the outcome measurement, the sample size, and the results. All studies included in these summary tables are also included in the summary tables for key questions 1 and 3, and study details can be found there. For key question 4 (adverse events), summary tables included the followup time and the event rates for the specific adverse events of interest.

We found that a large number of studies performed multivariable analyses of the association between preprocedure variables and AF recurrence (key question 2). Given the heterogeneous nature of patients analyzed within individual studies and the clinical heterogeneity across studies, multivariable analyses are best suited to address the association between predictor variables and outcomes. This is particularly the case in analyses of RFA for AF since many of the predictors of interest are correlated or confounded with each other. Thus, for most predictors, we evaluated only studies that reported multivariable analyses. We focused on the following predictors: type of AF, duration of AF, left ventricular ejection fraction, left atrial diameter, sex, age, structural heart disease, and hypertension. We also included other predictors that could be assessed prior to RFA. In this section, we did not analyze whether specific RFA techniques or procedures were associated with outcomes, as this was covered under key questions 1 and 3.

Because of particular interest by the TEP and study researchers in the question of whether AF type is associated with rate of AF recurrence, we also evaluated univariable (uncontrolled) analyses of AF type. Based on the studies that were performed we included the following comparisons: paroxysmal versus persistent AF, paroxysmal versus long-standing persistent (permanent/chronic) AF, and paroxysmal versus nonparoxysmal AF (combined persistent and long-standing persistent (permanent/chronic)). In studies in which detailed data for AF recurrences by each AF type were available, the corresponding relative risk (RR) was calculated. For these comparisons, we performed metaanalysis, as described below.

For adverse event data collection (KQ4), we consulted the TEP concerning the major adverse events that would be of relevance to RFA. We collected the rates reported for the following major adverse events: PV stenosis, cardiac tamponade or pericardial effusion requiring intervention, stroke and/or transient ischemic attack, bleeding requiring transfusion, atrioesophageal fistula, 30-day mortality, any deaths, and other major adverse events as reported in the studies. We organized the section according to whether the RFA was ostial or extra-ostial PVI and further subcategorize them by the types of catheter tips used in the RFA. We did not assess the quality of the study with respect to the adverse event reporting.

## Metaanalysis

Where the data were amenable to metaanalysis - based on the degree of clinical heterogeneity of studies, patients, and outcomes and the statistical heterogeneity of results - we performed meta-analyses using the random effects model. ^20^ For clinical outcomes (except for stroke), we employed the RR as the metric of choice to quantify relative benefit comparing RFA to medical treatment. For stroke, our primary analysis was a summary of the risk difference (RD) by the Mantel-Haenszel fixed-effects model because events (strokes) were rare and some studies reported no strokes. ^21^ For sensitivity analysis, we used the Peto method to combine odds ratios (ORs), which effectively excludes studies with zero events in both arms from the analysis. ^22^ We also performed random effects model meta-analyses of RR for AF type as a predictor of AF recurrence in univariable analyses.

## Peer Review and Public Commentary

A draft version of this report was reviewed by a panel of expert reviewers (see Appendix D), including representatives from professional society and industry. These experts were either directly invited by the Tufts Medical Center Evidence-based Practice Center or offered comments through a public review process. Revisions of the draft were made, where appropriate, based on their comments. The draft and final reports were also reviewed by staff from the Scientific Resource Center at Oregon Health and Science University. However, the findings and conclusions are those of the authors, who are responsible for the content of the report.