# Introduction

The Agency for Healthcare Research and Quality (AHRQ) commissioned this report to review the evidence for the clinical effects and safety of radiofrequency catheter ablation (RFA) for the management of atrial fibrillation (AF). Over the past decade, RFA has rapidly evolved as a tool for managing AF in select patients. ^1^ This rapid evolution has been driven by an enhanced understanding of the triggers and etiology of AF and the development of advanced catheter and imaging technologies.

## Background

AF remains the most common sustained arrhythmia in clinical practice. ^2^ Its prevalence increases with age, from 0.1% in people younger than 55 years to more than 9% by 80 years of age. ^3^ It is estimated that the prevalence of AF will increase with the aging of the population - the projected number of people with AF will exceed 10 million by 2050 according to one estimate. ^4^

The burden of AF is manifested in associated symptoms such as dyspnea, fatigue, decreased exercise tolerance, congestive heart failure related to reduction in left ventricular function, a reduced quality of life, an approximately 2-fold increased risk of death, and a 5-fold increased risk of stroke. ^3^ In addition to the risk of morbidity and mortality for the patient, AF constitutes a heavy burden on healthcare expenditure due to the high costs associated with AF-related hospitalization, evaluation, management, and loss of productivity. ^1^ The heavy burden of AF creates a pressing need for novel approaches to management. This is especially the case given the suboptimal clinical effect of current therapeutic strategies, which typically fall into two broad categories: rate control of the ventricular response; and rhythm control to maintain normal sinus rhythm. In some patients, symptoms as well as the hemodynamic effects of the arrhythmia can be controlled if the ventricular response is adequately slowed by atrioventricular (AV) nodal blocking agents such as beta blockers, calcium channel blockers, and digoxin. Occasionally, adequate rate control is not achievable with medications, and requires AV nodal ablation with implantation of a permanent pacemaker. In other patients, controlling the ventricular response rate is not an adequate treatment. In such cases, the lack of an atrial “kick” (an atrial contraction that contributes up to 20% of the left ventricular volume at the end of diastole), as well as the irregularity of the ventricular response, result in symptoms and deleterious hemodynamic consequences. The appropriate treatment is, therefore, the restoration of normal sinus rhythm which is performed electrically and/or chemically. ^3^ Class IC and class III antiarrhythmic drugs (AADs) are most commonly used. However, each AAD has a particular side effect profile. These management strategies must also be combined with appropriate anticoagulation strategy (i.e., aspirin or coumadin) based on the patient's risk factors (age, hypertension, underlying structural heart disease, congestive heart failure, diabetes mellitus, and history of stroke or a transient ischemic attack). ^3^

Several randomized controlled trials (RCTs) have compared the two strategies of rhythm control versus rate control in patients with AF. ^5^ – ^9^ Individually, these RCTs have failed to show that one strategy is superior to the other. ^5^ – ^9^ However, a metaanalysis of 5,239 patients with AF enrolled in RCTs comparing rhythm and rate control found that a strategy of rhythm control with AADs was associated with worse outcomes, including an increased rate of all-cause death and thromboembolic stroke. ^10^

It is well-recognized though, that a rhythm control strategy with AADs is not equivalent to maintenance of sinus rhythm. ^11^ In other words, the worse outcomes associated with a rhythm control strategy in the clinical trials is not equivalent to worse outcomes with maintenance of sinus rhythm, per se, and should not be a cause to abandon novel strategies aimed at maintaining sinus rhythm. This is especially crucial in patients who have highly symptomatic AF, in which case restoring sinus rhythm is required to improve symptoms. Importantly, restoring sinus rhythm may provide benefits beyond symptomatic relief. ^11^ In the Atrial Fibrillation Followup Investigation of Rhythm Management (AFFIRM) Study, the largest trial comparing rhythm and rate control, a rhythm-control strategy with AADs offered no survival advantage over a rate-control strategy. However, in an “on-treatment” analysis of the relationship of survival to cardiac rhythm and treatments as they changed over time, the presence of sinus rhythm was associated with a considerable reduction in the risk of death and AAD use was associated with increased mortality. This suggests that the beneficial effects of maintaining sinus rhythm with AADs may be offset by their serious side effects, leading the AFFIRM investigators to conclude that “if an effective method for maintaining sinus rhythm with fewer adverse effects were available, it might be beneficial.” ^11^ RFA for AF could be promising in that regard.

Catheter ablation for AF is based on the understanding that in many patients electrical activity emanating from the pulmonary veins (PVs) serves as a trigger for AF. ^12^ Sleeves of atrial muscle fibers extend from the left atrium into the PVs for 1 to 3 cm. ^13^ – ^16^ In a proof-of-concept study in 1998, Haissaguerre and colleagues studied 45 patients with paroxysmal AF (PAF) refractory to drug therapy. In the study, 94% of the points of AF origin were mapped to foci inside the PVs. They observed that elimination of local electrograms at these foci with radiofrequency energy rendered 62% of the patients free of AF recurrence over 8 months of followup. ^12^ This observation formed the basis for future development of RFA for AF.

Since the publication of Haissaguerre's study, the technique for RFA has rapidly evolved. The initial RFA strategy involved delivery of radiofrequency energy at the sites of earliest activation in a segmental fashion at the ostium of the PVs. After the recognition of PV stenosis as a potential complication of such an approach, the lesion set was moved to a more proximal, or antral, position within the atrium. ^17^ Some centers adopted this method of PV isolation (also known as segmental or focal PV isolation), which is guided by a circular multipolar catheter placed in the PV. The endpoint of the procedure is electrical isolation of the PVs or dissociation of PV potentials from atrial potentials.

Pappone reported a variation of Haissaguerre's initial technique known as wide area circumferential ablation (WACA, or left atrial circumferential ablation) in which radiofrequency energy is delivered in a circumferential fashion around the ipsilateral veins (with or without a lesion set at the carina which divides the ipsilateral veins). ^18^ In this anatomic-based procedure in which two encircling lesions are created, the endpoint of the procedure is an abatement of the voltage of the signal at the ablation site, which may be confirmed by a 3-dimensional voltage map of the PVs and left atrium at the end of the procedure.

The above strategies have been used in patients with AF, but these strategies have been most effective in patients with PAF, which is defined as two episodes or more of AF that spontaneously converts into normal sinus rhythm within 7 days. ^3^ RFA of persistent AF (an arrhythmia duration of greater than 7 days, with or without cardioversion) or longstanding persistent AF ^a^ (continuous AF of greater than 1 year duration) has required the development of additional lesions sets in order to improve clinical outcomes. ^1^

a According to the consensus statement on RFA for the treatment of AF published by the Heart Rhythm Society in 2007, the term chronic or permanent has been replaced by longstanding persistent to define continuous AF of greater than 1 year duration. ^1^

Additional lesion sets have been variably used in RFA of PAF and, in particular, in RFA of persistent or chronic AF in an attempt to ablate non-PV triggers of AF and also to target the substrate, or atrial areas thought to be responsible for maintenance of AF. ^1^ These linear lesions are placed in different regions in the left atrium and may include the posterior left atrium, the roof of the left atrium, the interatrial septum, and the isthmus formed between the mitral annulus and the pulmonary veins/left atrial appendage. In another effort to identify and ablate substrate sites, areas of complex fractionated atrial electrograms (CFAEs) have also been targeted. ^19^ When atrial flutter has been documented as a clinical rhythm, the cavotricuspid isthmus, which is the substrate for the maintenance of atrial flutter has been a target of ablation. On occasion, RFA of the cavotricuspid isthmus has been performed empirically, as atrial flutter could degenerate into AF. ^1^

The above techniques have been used in isolation or in combination at the discretion of the operator such that there is great variability in the techniques used in published studies of RFA as well as in clinical practice. At present, there is no standardization of technique. However, the Consensus Statement on Catheter and Surgical Ablation of Atrial Fibrillation, put forth by the Heart Rhythm Society (HRS) and endorsed by several professional organizations, states that the foundation of most AF ablation procedures is to target the PVs and/or PV antrum. ^1^

After discussion with the technical expert panel (TEP) convened for this comparative effectiveness review, and in accordance with the HRS Consensus Statement, we reviewed only studies that included targeting of the PVs or PV antrum, with or without the addition of other strategies.

Variability has been observed not only in technique but also in the technologies used to perform this procedure. Initially, conventional radiofrequency catheters with a 4 mm tip were used. Over the decade during which RFA for AF evolved, there has been a transition to use an 8 mm tip catheter and then to an ablation catheter with a saline-irrigated tip. ^1^ The irrigated catheters have either an internal or external cooling system. Following a discussion with the TEP, the decision was made to exclude studies that exclusively used a conventional 4 mm tip ablation catheter since, at present, it is infrequently used in the United States.

Numerous observational studies have been published describing different techniques and their associated outcomes, and several RCTs have examined the clinical effect of this approach in maintaining sinus rhythm. Based on these trials and other lines of evidence, current guidelines for the management of AF consider RFA a reasonable alternative in patients with symptomatic AF who have failed AAD therapy. ^3^

The present review examines the evidence for the short- and long-term clinical effect and safety of RFA for AF. After extensive discussion with AHRQ and the TEP, the key questions to be addressed in this report are:

## Key Questions

1 What is the effect of RFA on short- (6 to 12 months) and long- (>12 months) term rhythm control, rates of congestive heart failure, left atrial and ventricular size changes, rates of stroke, quality of life, avoiding anticoagulation, and readmissions for persistent, paroxysmal and long-standing persistent (chronic) atrial fibrillation?
2 What are the patient-level and intervention-level characteristics associated with RFA effect on short- and long-term rhythm control?
3 How does the effect of RFA on short- and long-term rhythm control differ among the various techniques or approaches used?
4 What are the short- and long-term complications and harms associated with RFA?