# Panel of Expert Reviewers

## Peer Reviewers

Peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- David Callans, MD
- Hospital of the University of Pennsylvania
- Department of Medicine
- Cardiovascular Medicine Division
- 9129 Founders Pavillion
- Philadelphia, PN 19104
- Email: david.callans@uphs.upenn.edu

- William Stevenson, MD
- Brigham and Women's Hospital
- Cardiovascular Division
- 75 Francis Street, Tower - 3
- Boston, MA 02115
- Phone: 617-732-7535
- Fax: 617-277-4981
- Email: wstevenson@partners.org

## Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives are sought. Divergent and conflicted opinions are common and perceived as health scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

- Hugh Calkins, MD
- Johns Hopkins Hospital
- 600 N. Wolfe Street
- Carnegie 592
- Baltimore, MD 21287
- Phone: 410-955-3339
- Email: hcalkins@jhmi.edu

- Kenneth Ellenbogen, MD
- Virginia Commonwealth University | VCU Health System
- School of Medicine | Department of Internal Medicine
- VCU Pauley Heart Center
- PO Box 980036
- Richmond, Virginia 23298
- Phone: 804-828-8885
- Email: kaellenb@vcu.edu

- Mark A. Hlatky, MD
- Stanford University
- Health Services Research
- 450 Serra Mall, HRP T152
- Stanford, CA 94305-5405
- Phone: 650-723-6426
- Fax: 650-725-6951
- Email: hlatky@stanford.edu

- Francis E. Marchlinski, MD
- Hospital of The University of Pennsylvania
- Department of Medicine
- Cardiovascular Medicine Division
- 9130 Founders Pavilion
- 3400 Spruce Street
- Philadelphia, PA 19104
- Phone: 215-662-6005
- Email: Francis.Marchlinski@uphs.upenn.edu

- Douglas A. Packer, MD
- Mayo Clinic
- Cardiovascular Disease
- 200 First Street SW
- Rochester, MN 55905
- Phone: 507-255-6263
- Email: Elliott.Jacqueline@mayo.edu

- Albert L. Waldo, MD
- Case Western Reserve University,
- Department of Medicine
- 11100 Euclid Avenue,
- Cleveland, OH 44106
- Phone: 216-844-7690
- Email: albert.waldo@case.edu