# Evidence Tables

Al Chekakie Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Al Chekakie, 2007 US 17593228 | | | | x | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Al Chekakie, 2007 US 17593228 | Paroxysmal or persistent AF refractory to anti-arrhythmic drug therapy who met the criteria: (1) no previous ablation procedure for AF and (2) antral PVI alone | Patients who underwent segmental ostial isolation or additional left atrial linear lesions | January 2003 to December 2004 | nd | Structural heart disease 23%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Al Chekakie, 2007 US 17593228 | nd | First PVI | 177 | 75 | 23% >65 years old | 71 | 6.06 | nd | 53% >4.2 | 8% <50% | C | Wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Al Chekakie, 2007 US 17593228 | yes | 100% [entrance block into all PVs, with elimination of all recordable high-frequency potentials confirmed by a circular mapping catheter placed at the venous ostium] | Cavotricuspid isthmus in patients with previously documented spontaneous or inducible cavotricuspid isthmus dependent atrial flutter | nd | 4-mm or 8-mm tip (SOLID TIP) | 40–50 | 60 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | 45 | 177

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes (24-hr Holter monitoring at 6 and 12 months and 30-day transtelephonic monitoring at 3 and 9 months after the procedure)
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | 2 months

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Men | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | HR: 1.28 | 0.67–2.44 | .462 | 1.25 | 0.63–2.51 | .53
Age >65 | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | 1.33 | 1.73–2.44 | .355 | 1.42 | 0.72–2.79 | .31
Persistent AF | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | 1.66 | 0.92–2.98 | .091 | 1.10 | 0.55–2.20 | .79
Structural heart disease | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | 1.45 | 0.78–2.69 | .244 | 0.91 | 0.45–1.86 | .80
La diameter >42 mm | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | 1.01 | 0.58–1.76 | .976 | 0.87 | 0.47–1.60 | .65
Hypertension | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | 1.81 | 1.04–3.17 | .037 | 1.82 | 0.87–3.79 | .11
EF<50% | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | 3.66 | 1.76–7.61 | <.001 | 2.70 | 1.13–6.46 | .03
AF duration (years) | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | 0.96 | 0.91–1.02 | .195 | 0.95 | 0.89–1.02 | 0.13
ACE-I | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | 2.10 | 1.12–3.93 | .02 | 1.29 | 0.57–2.93 | .54
ARB | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | 0.17 | 0.02–1.23 | .079 | 0.17 | 0.02–1.34 | .09
Stain | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | 1.40 | 0.78–2.52 | .265 | 1.10 | 0.55–2.27 | .80
RAS blockers | Al Chekakie, 2007 US 17593228 | Recurrence of AF | An electrocardiographically documented episode lasting >30 seconds, irrespectively of symptoms | First PVI | 13.8 | | | 1.19 | 0.65–2.19 | .573 | 0.94 | 0.46–1.93 | .87
RAS blockers and statins | | | 1.23 | 0.70–2.16 | .478 | 1.02 | 0.54–1.93 | .96

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Al Chekakie, 2007 US 17593228 | no | NA | NA | NA (retrospective study) | nd | Yes (0% dropout) | yes | yes | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | yes | no | yes | no
Explanation for Overall Quality Grade: | | | | Retrospective study

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Al Chekakie, 2007 US 17593228 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Arentz Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Arentz 2007 Germany 17562956 | x | | | | individual PVI vs. large area PVI; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Arentz 2007 Germany 17562956 | symptomatic drug resistant AF | LAD >55 mm; intracardiac thrombi; MI or heart surgery previous 3 mo; previous AF ablation | 2004-2006 | 1 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Arentz 2007 Germany 17562956 | nd | Individual vein PVI | 55 | 61 | 56 | 75 | 5.5 | nd | 4.0 | nd | B | moderate
ipsilateral veins PVI | 55

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Arentz 2007 Germany 17562956 | y | 100%(implied) [disappearance or dissociation of PV potentials on basket catheter or Lasso catheter] | (1)Circumferential ablation of ipsilateral veins (2) When PV conduction was still present after WACA, both PVs were mapped sequentially for site of earliest activation (lesion placed on ablation line) | n | irrigated tip | 25–35 | 50 | 49
58

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Arentz 2007 Germany 17562956 | primary end point | freedom from AF with no AAD; no AF or AT symptoms; no AT >30 s; after 1 ablation | individual vein PVI | 15 mo | 27 | 55 | 49%
| | | ipsilateral veins PVI | | 37 | 55 | 67% | | ≤0.05

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 1 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Paroxysmal AF | Arentz 2007 Germany 17562956 | primary end point | freedom from AF with no AAD; no AF or AT symptoms; no AT >30 s; after 1 ablation | individual vein PVI | 15 | 19 | 35
| | | | ipsilateral veins PVI | | 23 | 32 | | | 0.1
persistent AF | | | | individual vein PVI | 15 | 8 | 20
| | | | | | 14 | 23 | | | 0.16

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Arentz 2007 Germany 17562956 | individual vein PVI | | 40%, 1/55 (1.8%) | 1/55 (1.8%)
| ipsilateral veins PVI | | 40%, 1/55 (1.8%) | 1/55 (1.8%) | | | | | pulmonary edema (transient) | 1/55 (1.8%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Arentz 2007 Germany 17562956 | y | nd | n | y (?) | n | n | y | NA | y | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | y | y | n
Explanation for Overall Quality Grade: | | | | randomization technique not reported; unclear if there were any dropouts at followup

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Arentz 2007 Germany 17562956 | | X
Explanation for Applicability Grade: | | N=55 in each arm; relatively young patients

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Arruda Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Arruda, 2007 US 17850288 | | | | | X (prospectively comparing 2 non-concurrent groups) | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Arruda, 2007 US 17850288 | Consecutive patients with symptomatic AF, refractory to 3±1 AAD trials | None reported | nd | “41 patients were controlled with a previously ineffective AAD” (time was not reported) | Persistent AF = 10% Permanent AF = 39%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Arruda, 2007 US 17850288 | nd | PVI (n=190) | 407* | 51 | 55 | 79 | 6 | nd | nd | nd | C | Wide
PVI + SVCI (superior vena cava electrical isolation) (n=217)

* No breakdown patients' characteristics per intervention

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Arruda, 2007 US 17850288 | yes | PVI: nd [Endpoint - RF was delivered until EGMs on circular catheter were eliminated. Presumably 100%] | none | yes | 4-mm, 8-mm (Biosense Webster, Baldwin Park, CA), or irrigated tip (EP technologies, Sunnyvale, CA) | nd | 55 (4- or 8-mm tip); 35 (irrigated tip | Nd
yes | PVI+SVCI: nd for PVI; 59% for SVCI [abolishing all high frequency SVC potentials] | superior vena cava electrical isolation | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Arruda, 2007 US 17850288 | Recurrence of AF | nd | PVI or PVI+SVCI | 14.8 | 66 | 407

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24-hour or greater ECG screening performed? | No
Was a blanking period (time when AFib episodes were not recorded) used? | No | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Arruda, 2007 US 17850288 | no | NA | NA | Yes (assumed no dropout) | nd | Yes (0% dropout) | no | no | no | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | no | no | yes | no | no
Explanation for Overall Quality Grade: | | | | Poor reporting of interventions and patients' characteristics; the only comparison between the two techniques were among 25 patients who had a repeat procedure (see reviewer's comment)

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Arruda, 2007 US 17850288 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Arruda, 2007 US 17850288 | A repeat ablation procedure was performed in 25 of the 66 patients who had recurrence AF. Five of these 25 patients (20%) were found to have AF recurrence initiated by SVC triggers, of whom four were among group I patient (4/190, 2%) and one was from group III (1/217; 0.4%), p<0.05. All patients remained arrhythmia-free after repeat PVI and SVCI.

Berkowitsch Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Berkowitsch, 2005 Germany 15683534 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Berkowitsch, 2005 Germany 15683534 | - Highly symptomatic paroxysmal AF; - Refractory to > 3 AAD | nd | nd | nd | Only severe PV stenosis was assessed. No efficacy/effectiveness outcomes reported.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Berkowitsch, 2005 Germany 15683534 | nd | PVI (ostial) | 104 | 100 | 55 | 33 | nd | nd | nd | nd | AE data only

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Berkowitsch, 2005 Germany 15683534 | Yes | nd | nd | Nd | 4 mm, cooled tip (Chilli) | 15–50 | nd | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Berkowitsch, 2005 Germany 15683534 | PVI (ostial) | 12 | Severe*: 16/104** (15%) | nd | nd | nd | nd | nd | Nd

Only PV stenosis was assessed by MRI

* Severe stenosis was defines as a ≥ 70% narrowing of the initial ostial diameter.

** Patient is the unit of analysis. 18/357 per PV-based analysis (Severe stenoses was observed in 18 out of 357 total PVs, meaning that two patients developed severe stenosis in two left PVs).

Multivariate analyses by the Cox regression identified RRPVD1 ≥ 25% (HR=1.5 (95% CI, 2.5–8.3 (p<0.001))), RA >180° (HR=10.3 (95% CI, 2.4–47.8 (p<0.02))), and CE > 22000(J) (HR=2.9 (95% CI, 1.2–7.8 (p<0.03))) as statistically significant factors that predicted severe stenosis development. RRPVD1, relative reduction of PV after the procedure (day 1); RA, summary radial angle of energy delivery at the ostial circumference; CE, cumulative energy delivery per PV. Only factors associated with energy delivery were taken into account and no clinical/patient characteristics or operator characteristics were explored in the analyses.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Berkowitsch, 2005 Germany 15683534 | No | NA | NA | nd | NA | NA | Yes | Yes | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | No | NA | No | No | NA
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Berkowitsch, 2005 Germany 15683534
Explanation for Applicability Grade: | | Only paroxysmal. The details on patient characteristics and ablation procedure were not well described.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Berkowitsch, 2005 Germany 15683534 | Definition of severe stenosis was based on imaging results (MRI). Clinical symptoms were not taken into account. Only factors associated with energy delivery were taken into account and no clinical/patient characteristics or operator characteristics were explored in the multivariate analyses.

Berruezo Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Berruezo, 2007 Spain 17395676 | | | x | | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Berruezo, 2007 Spain 17395676 | Patients referred for AF ablation | Age<18 or .75 years, anteroposterior LAD at transthoracic echocardiography >55 mm, presence of LA thrombus on transesophageal echocardiography, and the presence of a mechanical prosthetic heart valve. | January 2003 to November 2005 | nd | Persistent AF=23.6% Permanent AF=15.5% Structural heart disease=19.6%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Berruezo, 2007 Spain 17395676 | Instituto de Salud Carlos III, Madrid, Spain and Spanish Society of Cardiology | Circumferential pulmonary vein ablation | 148 | 60.8 | 52 | 82.4 | 6.2 | nd | 4.1 | 60 | B | Wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Berruezo, 2007 Spain 17395676 | yes | Yes (100% implied) - in order to achieve a local electrogram 0.15 mV within this area.- electrical disappearance/reduction was checked by mapping the encircled area (low voltage inside the encircled area) | WACA, linear lesions LA posterior wall, roof, and mitral isthmus | no | 8 mm or irrigated tip (Navistar, Biosense Webster) | 8-mm: 60 Irrigated: 40 | 8-mm: 55 Irrigated: 45 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Berruezo, 2007 Spain 17395676 | AF recurrence | Symptomatic or asymptomatic AF episodes presenting after the first month | Circumferential pulmonary vein ablation | 13.1 | 39 | 148

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes (24 hr Holter monitoring at follow-up visits)
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | 1 month

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Age (year) | Berruezo, 2007 Spain 17395676 | AF recurrence | Symptomatic or asymptomatic AF episodes presenting after the first month | Circumferential pulmonary vein ablation | 13.1 | | | HR: 1.03 | 1.00–1.06 | .031 | | | ns
Male gender | Berruezo, 2007 Spain 17395676 | AF recurrence | Symptomatic or asymptomatic AF episodes presenting after the first month | Circumferential pulmonary vein ablation | 13.1 | | | HR: 1.02 | 0.45–2.32 | .942 | | | ns
Hypertension | Berruezo, 2007 Spain 17395676 | AF recurrence | Symptomatic or asymptomatic AF episodes presenting after the first month | Circumferential pulmonary vein ablation | 13.1 | | | HR: 2.70 | 1.43–5.07 | .002 | HR: 2.8 | 1.5–5.4 | .002
Permanent AF | Berruezo, 2007 Spain 17395676 | AF recurrence | Symptomatic or asymptomatic AF episodes presenting after the first month | Circumferential pulmonary vein ablation | 13.1 | | | HR: 2.23 | 1.08–4.59 | .042 | | | ns
Structural heart disease | Berruezo, 2007 Spain 17395676 | AF recurrence | Symptomatic or asymptomatic AF episodes presenting after the first month | Circumferential pulmonary vein ablation | 13.1 | | | HR: 1.28 | 0.61–2.69 | .331 | | | ns
AF duration (months) | Berruezo, 2007 Spain 17395676 | AF recurrence | Symptomatic or asymptomatic AF episodes presenting after the first month | Circumferential pulmonary vein ablation | 13.1 | | | HR: 1.00 | 1.00-1.00 | .989 | | | ns
LAD (mm) | | | HR: 1.11 | 1.05–1.18 | .001 | HR: 1.1 | 1.06–1.2 | 0.01
lVEDD (mm) | | | HR: 1.05 | 0.98–1.12 | .175 | | | ns
lVESD (mm) | | | HR: 1.07 | 1.00–1.15 | .029 | | | ns
LVEF (%) | | | HR: 0.98 | 0.95–1.01 | .128 | | | ns
LVS (mm) | | | HR: 0.99 | 0.78–1.27 | .843 | | | ns
LVPW (mm) | | | HR: 1.05 | 0.74–1.48 | .927 | | | ns

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Berruezo, 2007 Spain 17395676 | Circumferential pulmonary vein ablation | | 0 (at 4 month follow-up) | | | | | | Transient cerebrovascular ischemia | 2/148 (1.3%)
| | | | | | | | | pericarditis | 6/148 (4%)
| | | | | | | | | Dressler syndrome | 2/148 (1.3%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Berruezo, 2007 Spain 17395676 | no | NA | NA | 0 (assumed) | nd | Yes (0% dropout) | yes | yes | yes | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | yes | yes | yes | no
Explanation for Overall Quality Grade: | | | | Observational study

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Berruezo, 2007 Spain 17395676 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Berruezo, 2007 Spain 17395676 | A 2nd procedure was performed in 22 (14.8%) patients, and a third procedure was necessary in 4 of these patients (2.7%)

Bertaglia 2005 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Bertaglia, 2005 Italy 15869666 | | | | x | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Bertaglia, 2005 Italy 15869666 | Patients who underwent circumferential anatomical PV ablation using the CARTO nonfluoroscopic navigation system (Biosense Webster) for paroxysmal or persistent AF refractory to ≥2 antiarrhythmic drugs in 3 different Italian hospitals (Cirie, Maddaloni, Mirano). 143/158 (91%) consecutive patients who had not yet undergone a PV ablation procedure were selected | nd | March 2001 to March 2003 | 64 patients were still on a previous ineffective AAD: 40 on amiodarone, and 24 on 1C class drug (during a mean follow-up of 18.7 months, ranged 9–36 months) | Structural heart disease 62% 6% patients with LVEF <40%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Bertaglia, 2005 Italy 15869666 | nd | circumferential anatomical PV ablation | 143 | 45 | 61.4 | 66 | 5.0 | nd | 4.7 | 57.7 | C | wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Bertaglia, 2005 Italy 15869666 | yes | PVI: 87% [conduction block around each PV or around ipsilateral PVs according to the anatomy] | WACA Starting from the beginning of 2002, adjunctive RF ablation lines were created in the right or left atrium: along the cavotricuspid isthmus with electrophysiological assessment of transisthmic block, and along the isthmus between the mitral annulus and the left inferior PV without electrophysiological assessment of transisthmic block 83% received ablation of right isthmus 68% received ablation of left isthmus | no | 3.5 mm cooled-tip (Navistar, Biosense Webster Inc.) | 50 | 45 | 55.5

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Bertaglia, 2005 Italy 15869666 | Responders | Patients who did not present symptomatic or asymptomatic atrial tachyarrhythmias lasting >30 seconds after the first 3 months of follow-up | circumferential anatomical PV ablation | 18.7 | 102 | 143

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes (24-hr ECG Holter monitoring at followup)
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | 3 months

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Early relapse (within 3 months post RFA) | Bertaglia, 2005 Italy 15869666 | Responders | Patients who did not present symptomatic or asymptomatic atrial tachyarrhythmia lasting >30 seconds after the first 3 months of follow-up | circumferential anatomical PV ablation | 18.7 | 28 | 65 | | | <.0001, chi-square test
No early relapse | | | | | | 74 | 78

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Bertaglia, 2005 Italy 15869666 | circumferential anatomical PV ablation | | | 2/143 (1.4%) | | | | | Transient paralysis of the right phrenic nerve | 1/143 (0.7%)
| | | | | | | | | Transient ischemic attack | 1/143 (0.7%)
| | | | | | | | | AV block | 1/143 (0.7%)
| | | | | | | | | Pseudoaneurysm of the right femoral artery | 1/143 (0.7%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Bertaglia, 2005 Italy 15869666 | no | NA | NA | retrospective | no | no | no | no | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | yes | no | yes | no
Explanation for Overall Quality Grade: | | | | Retrospective study (143/158 consecutive patients who had not yet undergone a PV ablation procedure were selected); post-hoc analyses.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Bertaglia, 2005 Italy 15869666 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Bertaglia 2007 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Bertaglia, 2007 Italy 17905330 | | | x | | | MC/AG

Zoppo 2008 (18695424) is a post-hoc analysis of the same data

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Bertaglia, 2007 Italy 17905330 | Of the 32 Italian electrophysiology laboratories listed in the Italian Association of Arrhythmology and Cardiostimulation ablation procedures national Registry, 10 agreed to participate in this prospective registry, which was set up in April 2005. All consecutive patients who were undergoing catheter ablation in their laboratories for every type of AF. Not all centers entered the Registry within the same time period. | None | 18 months from April 2005. | nd | Persistent AF: 34.5% Permanent AF: 5.5% Structural heart disease: 32.6%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Bertaglia, 2007 Italy 17905330 | nd | All ablation strategies aimed at isolating or encircling the PVs were included. Additional linear lesions in the right or left atrium also were allowed. | 1,011 | 60 | 57.9 | 74.4 | 4.7 | nd | 4.4 | 56.7 | AE data only | wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Bertaglia, 2007 Italy 17905330 | yes | nd [a circumferential PV mapping catheter was used in 35% patients and a multipolar basket catheter in 4.3% patients to completely isolate the PV] | Linear lesions in 688 (66%) patients at the cavotricuspid isthmus, in 474 (46.8%) at the mitral-to-left inferior PV isthmus, and in 266 (26.3%) at the left atrium roof. | nd | 4-mm or 8-mm tip, or 3.5-mm open irrigated tip (ThermoCool, Biosense Webster Inc.) 89.5% used irrigated tip, 8.5% used 8-mm tip and 2% used 4-mm tip. | 4-mm: 40* 8-mm: 100* Irrigated: 50* | 4-mm: 50 8-mm: 60 Irrigated: 45 | 42.9

* When ablation was performed in the posterior wall of the left atrium, RF power was reduced to 30, 50, and 25 W for the 3 modalities, respectively.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Bertaglia, 2007 Italy 17905330 | All ablation strategies aimed at isolating or encircling the PVs | | 4/1011 (0.4% [PV Stenosis >50%. All but 1 without any clinical consequence] | 6/1011 (0.6%) | 4/1011 (0.4%)* | | 12/1011 (1.2%) | 0 | Pericardial effusion (all conservatively treated) | 8/1011 (0.8%)
| | | | | | | | | Cerebral embolism (including stroke and transient ischemic attack) | 5/1011 (0.5%)
| | | | | | | | | Aortic root puncture during the transseptal approach, without any clinical consequence | 1/1011 (0.1%)
| | | | | | | | | Complete atrioventricular block during ablation in the septal left atrium region, with subsequent dual-chamber pacemaker implantation | 1/1011 (0.1%)
| | | | | | | | | Transient phrenic nerve paralysis during right PV isolation | 1/1011 (0.1%)
| | | | | | | | | Pneumothorax conservatively treated | 1/1011 (0.1%)
| | | | | | | | | Pleural hematic effusion that required drainage | 1/1011 (0.1%)

* 3 strokes occurred on the day after the procedure while switching from intravenous unfractionated heparin to oral anticoagulation, whereas only 1 stroke occurred during the procedure.

Difference in catheter-tip (8-mm standard vs. irrigated cooled) was not a significant predictor of 5 major complications (pericardial tamponade/effusion, PV stenosis, stroke, all complications, vascular complications) Zoppo 2008 (18695424) ← this info is not relevant to our key questions...

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Bertaglia, 2007 Italy 17905330 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Bertaglia, 2007 Italy 17905330 | 152 procedures (15% of cases) were performed in the initial phase of the centers' learning curve (defined as <50 procedure). Predictors of complications: On multivariate analysis, only a history of coronary artery disease (OR 5.603, 95% CI 1.559 to 20.139, P<.008) continued to characterize patient who presented hemorrhagic complications (including cardiac tamponade and pericardial effusion, n=14). Multivariate analyses did not find any variable significantly predict vascular complications or cerebral embolic complications.

Beukema Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Beukema, 2005 Netherlands 16203925 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Beukema, 2005 Netherlands 16203925 | Symptomatic paroxysmal or persistent AF | nd | nd | 3 mo (96% of patients) followed by gradual tapering

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Beukema, 2005 Netherlands 16203925 | nd | PV circumferential ablation | 105 | 50 | 52 | 70 | 6.8 | nd | 4.2 | 54 | C | Wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Beukema, 2005 Netherlands 16203925 | Yes | Nd (100% inferred) [Bipolar electrogram amplitude ≤ 0.5 mV in the encircled area] | WACA LA: a line between left PVs and LA appendage (all), mitral isthmus line (n=42), and posterior LA line (some) RA: cavo-tricuspid isthmus line (in case of typical atrial flutter) | No | 8 mm (Navistar) | 80 | 60 | nd
3.5 mm irrigated (Navistar)* | 50 | 50 | nd

* N=32 pts

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Beukema, 2005 Netherlands 16203925 | Sinus rhythm at last follow-up | Unclear | PV circumferential ablation | 14.6 | 76 | 105 | 72%
Beukema, 2005 Netherlands 16203925 | Re-procedure | Patients who required a second procedure due to recurrent AF between 3 and 6 months after the first procedure | PV circumferential ablation | 14.6? | 23 | 105

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | nd | If yes, how long was it? | NA

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Beukema, 2005 Netherlands 16203925 | Change in LAD | Decrease in LAD between before and after procedure | cm | PV circumferential ablation | 6 | 105? | 4.2 | nd | Nd* | <0.01 (t-test)

Duplicate one row per outcome and per RFA intervention.

* Difference between before and after therapy in each subgroup in each therapy, not net difference between independent subgroups.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Paroxysmal AF | Beukema, 2005 Netherlands 16203925 | AF free survival | unclear | PV circumferential ablation | 14.6 | 45 | 52 | 87%
Persistent AF | Beukema, 2005 Netherlands 16203925 | AF free survival | unclear | PV circumferential ablation | 14.6 | 41 | 53 | 77%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

Kaplan-Meier estimates

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Persistent | Beukema, 2005 Netherlands 16203925 | Change in LAD | Decrease in LAD between before and after procedure | cm | PV circumferential ablation | 6 | 53? | 4.4 | nd | Nd* | 0.001 (t-test)
Persistent (only remain SR during follow-up) | Beukema, 2005 Netherlands 16203925 | Change in LAD | Decrease in LAD between before and after procedure | cm | PV circumferential ablation | 6 | 41? | 4.4 | 4.0 | 0.4* | <0.01 (t-test)
Persistent (only recurrent AF during follow-up) | Beukema, 2005 Netherlands 16203925 | Change in LAD | Decrease in LAD between before and after procedure | cm | PV circumferential ablation | 6 | 12? | 4.5 | 4.9 | -0.4* | 0.001 (t-test)
Paroxysmal | Beukema, 2005 Netherlands 16203925 | Change in LAD | Decrease in LAD between before and after procedure | cm | PV circumferential ablation | 6 | 52? | 4.1 | 3.8 | 0.3* | <0.01 (t-test)
Paroxysmal (only recurrent AF during follow-up) | Beukema, 2005 Netherlands 16203925 | Change in LAD | Decrease in LAD between before and after procedure | cm | PV circumferential ablation | 6 | 7? | 4.0 | 4.1 | -0.1* | NS (t-test)

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

* Difference between before and after therapy in each subgroup in each therapy, not net difference between independent subgroups.

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Beukema, 2005 Netherlands 16203925 | PV circumferential ablation | 14.6 | 0/105

Data on only PV stenosis were reported.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Beukema, 2005 Netherlands 16203925 | No | NA | NA | nd | nd | Nd/NA | Yes? | No | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | Yes?/nd | Yes | No
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Beukema, 2005 Netherlands 16203925 | | | Wide
Explanation for Applicability Grade: | | No explicit exclusion criteria → inferring clinical practice comparable patient spectrum

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Bhargava Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Bhargava, 2004 USA 15028066 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Bhargava, 2004 USA 15028066 | Symptomatic drug-refractory AF | nd | nd | nd | - Comparison among different age groups (<50 vs. 51–60 vs. >60); - May overlap Chen 2004 (Cleveland); - Age <50 group had a statistically significantly lower % of concomitant/underlying structural heart disease or hypertension than Age 51- group (33% vs. 60%, P<0.05); - Age <50 group had a statistically significantly lower number of failed prior AAD (but probably clinically insignificant) than Age 51- group (2.85 vs. 3.22, P<0.05)

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Bhargava, 2004 USA 15028066 | nd | PVI (PV ostial) | 323 | 54 | 54 | 80 | 6.2 | NA | 4.3 | 53 | C | Wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Bhargava, 2004 USA 15028066 | Yes | Nd (100% implied) [nd] | SVC if mapping demonstrated high-frequency potentials | No | 4 mm cooled-tip (EP technologies) | 35 | 35–40 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 8 weeks

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
<50 years | Bhargava, 2004 USA 15028066 | Freedom from recurrent AF | AF persisted beyond 8-week blanking period | PVI (PV ostial) | 14.9 | 90 | 106 | 85% | | NS (Chi-squared)
51–60 years | Bhargava, 2004 USA 15028066 | Freedom from recurrent AF | AF persisted beyond 8-week blanking period | PVI (PV ostial) | 14.8 | 95 | 114 | 83% | | NS (Chi-squared)
>60 years | 14.7 | 84 | 103 | 82%
<50 years, only paroxismal | Bhargava, 2004 USA 15028066 | Freedom from recurrent AF | AF persisted beyond 8-week blanking period | PVI (PV ostial) | 14.9 | 58 | 64 | 91% | | NS (Chi-squared)
51–60 years, only paroxysmal | Bhargava, 2004 USA 15028066 | Freedom from recurrent AF | AF persisted beyond 8-week blanking period | PVI (PV ostial) | 14.8 | 52 | 56 | 86% | | NS (Chi-squared)
>60 years, only paroxismal | 14.7 | 46 | 54 | 85%
<50 years, only persistent | Bhargava, 2004 USA 15028066 | Freedom from recurrent AF | AF persisted beyond 8-week blanking period | PVI (PV ostial) | 14.9 | 9 | 11 | 82% | | NS (Chi-squared)
51–60 years, only persistent | Bhargava, 2004 USA 15028066 | Freedom from recurrent AF | AF persisted beyond 8-week blanking period | PVI (PV ostial) | 14.8 | 13 | 16 | 81% | | NS (Chi-squared)
>60 years, only persistent | 14.7 | 6 | 8 | 75%
<50 years, only permanent | Bhargava, 2004 USA 15028066 | Freedom from recurrent AF | AF persisted beyond 8-week blanking period | PVI (PV ostial) | 14.9 | 23 | 31 | 74% | | NS (Chi-squared)
51–60 years, only permanent | Bhargava, 2004 USA 15028066 | Freedom from recurrent AF | AF persisted beyond 8-week blanking period | PVI (PV ostial) | 14.8 | 34 | 42 | 81% | | NS (Chi-squared)
>60 years, only permanent | 14.7 | 32 | 41 | 78%
Paroxysmal | Bhargava, 2004 USA 15028066 | Freedom from recurrent AF | AF persisted beyond 8-week blanking period | PVI (PV ostial) | 14.8 | 152 | 174 | 87%
Persistent | Bhargava, 2004 USA 15028066 | Freedom from recurrent AF | AF persisted beyond 8-week blanking period | PVI (PV ostial) | 14.8 | 28 | 35 | 80%
Permanent | 89 | 114 | 78%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

* Crude estimates. The number of relapse cases in each subgroup was reported in the paper.

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Bhargava, 2004 USA 15028066 | PVI (PV ostial) | 14.8 | 6/323* (2%) | 3/323 (1%) | 3/323** (1%) | nd | nd | nd | Nd

* Defined as >70 narrowing by CT.

** All the three patients belonged to Age>60 group (P<0.05). No statistically significant difference detected among groups in the other complications.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Bhargava, 2004 USA 15028066 | No | NA | NA | nd | nd | nd | no | No | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Bhargava, 2004 USA 15028066 | | | Wide
Explanation for Applicability Grade: | | Seems similar to clinical practice

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Calò Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Calò, 2006 Italy 16781381 | X | | | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Calò, 2006 Italy 16781381 | RFA for symptomatic persistent or permanent AFib AFib resistant >3 attempts of Rx or electric cardioversion or recurrent, persistent AFib despite prophylaxis with ≥3 different AAD (I±III) | None reported | Amiodarone (or sotalol, flecainide, propafenone if contraindication) × 6 mo | Persistent AFib: lasting >7 d Permanent AFib: resistant to cardioversion or relapsing within 24 hr Idiopathic dilated cardiomyopathy 11% Valvular disease 9%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Calò, 2006 Italy 16781381 | nd | Circumferential RFA plus mitral and cavotricuspid isthmus ablation (LA ablation) | 41 | 0% (Persistent 54% Permanent 46%) | 59 | 65% | 7 yr | nd | 5.1 cm | 50.7% | A | Moderate
Biatrial ablation | 39

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Calò, 2006 Italy 16781381 | Yes | Not checked The endpoint was completion of lesions. Neither definite isolation of PV nor complete block was a required prerequisite of the procedure. | L Atrium: WACA, Mitral isthmus line (Within circles where local electrogram amplitude ≥0.1 mV) RA: Cavotricuspid isthmus ablation | No | 8 mm Navistar | L atrium ≤80 W | 50–60° × 20–60 sec | 44 min (LA arm)
Biatrial: L Atrium: Same as above R Atrium: Posterior intercaval line Septal line from septal SVC to fossa ovalis, then to CS ostium with a circumferential line around ostium, then to IVC electrical disconnection of SVC from R atrium | R atrium (specifically SVC isolation) ≤40 W | 50° (target) | 63 min (bilat arm)

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Calò, 2006 Italy 16781381 | Recurrence | Documented AFib post blanking | LA RFA | 13 mo | 16 | 41 | OR 0.28 | 0.10, 0.81 | .03
| | | Bilat RFA | 15 mo | 6 | 39
| On AAD at 6 mo | | LA RFA | 6 mo | 21 | 41
| | | Bilat RFA | 6 mo | 18 | 39
| Free of AAD without recurrence | | LA RFA | 13 mo | 7 | 41
| | | Bilat RFA | 15 mo | 16 | 39

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Kaplan Meier actuarial estimates at 3, 6, 18 months also reported (page 4 just above figure)

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 6 weeks

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Calò, 2006 Italy 16781381 | Time to first recurrence | Not including blanking period (6 wk) | months | LA RFA | 13 mo | 41 | | 3.0±1.5
Bilat RFA | 15 mo | 39 | | 3.9±2.3

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

Multivariable Cox regression:

adjusting for age, gender, LAD, structural heart disease, persistent vs permanent AF, continuation of AAD p-6 mo:

Bilateral RFA a negative predictor of AF recurrence: HR = 5.2 (2.0–13.3), P=.001

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Calò, 2006 Italy 16781381 | LA RFA | | Echo performed at 3 mo, but data not reported | | | | | | Retroperitoneal hematoma (n=1) Hemothorax (n=1)
| Bilat RFA | | | | | | | | None reported

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Calò, 2006 Italy 16781381 | Yes | Yes | nd | Yes (0%) | No | Yes | Yes | Yes | Yes | A
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | No flaws

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Calò, 2006 Italy 16781381 | | Moderate
Explanation for Applicability Grade: | | Persistent or Permanent AFib only

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Calò, 2006 Italy 16781381 | Power calculation: 20% AFib recurrence (bilat) vs 50% (LA), alpha = 0.05, beta = 0.80: 40 per arm.

Cha Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Cha 2008 US 18474813 | | | | x | KQ2, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Cha 2008 US 18474813 | symptomatic AF; followup ≥3 mo | | 2000-2005 | AAD ≥ 2–3 mo in pts with early recurrence

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Cha 2008 US 18474813 | industry | PVI (57%) or WACA (42%) | 523 | 58 | 54 | 84 | 6.4 | nd | nd | 58 | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Cha 2008 US 18474813 | y in WACA | 100% (implied?) | WACA + cavotricuspid isthmus ablation (± mitral line, or SVC, or vein of Marshall, or CS ablation) | y in WACA | 5 mm in PVI | 30 | 50 | *
8 mm in WACA | 35 | 50 | *

Total ablation time for all pts (523) 53 +/- 26 min

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Cha 2008 US 18474813 | AF elimination | freedom from AF (no AAD) | PVI or WACA | 12 mo | 311 | 432 | 72%
Cha 2008 US 18474813 | AF elimination | freedom from AF (no AAD) | PVI or WACA | 24 mo | 212 | 296 | 72%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
lean (BMI<25) | Cha 2008 US 18474813 | AF elimination | freedom from AF | PVI or WACA | 12 mo | 60 | 80 | 75%
overweight (25–29.9) | | AF elimination | | | | 139 | 192 | 72%
obese (≥30.0) | | AF elimination | | | | 112 | 160 | 70% | -6.9% to 16.9% | 0.42 (obese vs. lean)
lean (BMI<25) | Cha 2008 US 18474813 | AF elimination | freedom from AF | PVI or WACA | 24 mo | 45 | 61 | 74%
overweight (25–29.9) | | AF elimination | | | | 95 | 130 | 73%
obese (≥30.0) | | AF elimination | | | | 72 | 105 | 69% | -9.1% to 19.1% | 0.49 (obese vs. lean)

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Cha 2008 US 18474813 | PVI or WACA | | ≥50%, 7/523 (1.3%) | 12/523 (2.3%) | 4/523 (0.8%) | | | | hemi-diaphragm paralysis | 4/523 (0.8%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Cha 2008 US 18474813 | n | NA | n | y | n | n | y | y | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | n | n | n | n | n
Explanation for Overall Quality Grade: | | | | retrospective; unclear if outcome included redos

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Cheema Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Cheema 2006 USA 17019636 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Cheema, 2006 USA 17019636 | - PV-based ablation (segmental or circumferential); - Minimum follow-up 12 mo | nd | nd | At least 2 mo. Only patients free from recurrent AF discontinued AADs thereafter.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Cheema, 2006 USA 17019636 | nd | PV-based ablation (segmental or circumferential) | 200 | 46 | 56 | 66 | 6.4 | nd | 4.4 | 59 | C | Moderate

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Cheema, 2006 USA 17019636 | Yes (segmental, n=87) | Nd [verified by circular mapping catheter] | Cavo-tricuspid isthmus line | No | Irrigated 4 mm (Chilli RPM) | 35 | 39 | nd
No (circumferential, n=113) | NA | WACA Cavo-tricuspid isthmus line Mitral isthmus line Posterior LA line Linear lesion in the LA (‘figure-of-eight’)* | No | 8 mm (Biosense Webster) | 70 | 55 | nd

* Only the first 42 patients. This addition was terminated because two patients developed PV stenosis.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental or circumferential) | 26 | 56 | 200 | 28%
Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental or circumferential) | 26 | 14 | 200 | 7%
Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (only single procedure) | PV-based ablation (segmental or circumferential) | 26 | 70 | 200 | 35%
Cheema, 2006 USA 17019636 | Re-procedure | Patients who failed single procedure, and underwent at least one repeat procedure** | PV-based ablation (segmental or circumferential) | 26 | 64 | 200 | 32%
Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 83 | 200 | 42%
Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 23 | 200 | 12%
Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 106 | 200 | 53%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Only crude estimates presented.

** Most asymptomatic patients did not undergo a repeat procedure. Some patients underwent the procedure more than twice (n=35 but the total number of reprocedures was 64). Multivariate analyses by logistic regression model showed that only non-paroxysmal AF and type of ablation (segmental vs. circumferential) were the statistically significant independent factors to predict long-term treatment results (OR=2.83 (95% CI, 1.23–6.05; P<0.01) and 0.44 (95% CI, 0.21–1.07; P=0.03), respectively). Other covariates taken into account were age, gender, AF duration, LAD, LVEF, and structural heart disease.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | No
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 3 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Cheema, 2006 USA 17019636 | QOL | Symptomatic burden (Darber scale*) | Scale | PV-based ablation (segmental or circumferential) | 26 | 200? | 24 | 9 | 15** | <0.01

Duplicate one row per outcome and per RFA intervention.

* Modification of the University of Toronto AF Severity Scale.

** Difference between before and after therapy in each subgroup in each therapy, not net difference between independent subgroups.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Segmental, any AF | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental) | 26 | 19 | 87 | 22%
Segmental, any AF | Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental) | 26 | 9 | 87 | 10%
Segmental, any AF | Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (only single procedure) | PV-based ablation (segmental) | 26 | 28 | 87 | 32%
Segmental, paroxysmal only | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental) | 26 | 17 | 50 | 34%
Segmental, paroxysmal only | Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental) | 26 | 3 | 50 | 6%
Segmental, paroxysmal only | Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (only single procedure) | PV-based ablation (segmental) | 26 | 20 | 50 | 40%
Segmental, non-paroxysmal | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental) | 26 | 2 | 37 | 5%
Segmental, non-paroxysmal | Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental) | 26 | 5 | 37 | 13%
Segmental, non-paroxysmal | Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (only single procedure) | PV-based ablation (segmental) | 26 | 7 | 37 | 19%
Circumferential, any AF | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (circumferential) | 26 | 37 | 113 | 32%
Circumferential, any AF | Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (circumferential) | 26 | 5 | 113 | 4%
Circumferential, any AF | Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (only single procedure) | PV-based ablation (circumferential) | 26 | 42 | 113 | 37%
Circumferential, paroxysmal only | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (circumferential) | 26 | 17 | 42 | 40%
Circumferential, paroxysmal only | Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (circumferential) | 26 | 3 | 42 | 7%
Circumferential, paroxysmal only | Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (only single procedure) | PV-based ablation (circumferential) | 26 | 20 | 42 | 47%
Circumferential, non-paroxymal | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (circumferential) | 26 | 20 | 71 | 28%
Circumferential, non-paroxymal | Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (circumferential) | 26 | 3 | 71 | 4%
Circumferential, non-paroxymal | Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (only single procedure) | PV-based ablation (circumferential) | 26 | 23 | 71 | 32%
Paroxysmal only (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental or circumferential) | 26 | 34 | 92 | 37%
Paroxysmal only (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental or circumferential) | 26 | 6 | 92 | 6%
Paroxysmal only (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (only single procedure) | PV-based ablation (segmental or circumferential) | 26 | 40 | 92 | 43%
Non-paroxysmal (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental or circumferential) | 26 | 22 | 108 | 20%
Non-paroxysmal (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental or circumferential) | 26 | 8 | 108 | 7%
Non-paroxysmal (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (only single procedure) | PV-based ablation (segmental or circumferential) | 26 | 30 | 108 | 28%
Paroxysmal only (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 46 | 92 | 50%
Paroxysmal only (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 11 | 92 | 12%
Paroxysmal only (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 57 | 92 | 62%
Non-paroxysmal (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 37 | 108 | 34%
Non-paroxysmal (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 12 | 108 | 11%
Non-paroxysmal (segmental or circumferential) | Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 49 | 108 | 45%
Patients with early (<3 mo) recurrence | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 38 | 128 | 30%
Patients with early (<3 mo) recurrence | Cheema, 2006 USA 17019636 | Long-term improvement | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 8 | 128 | 6%
Patients with early (<3 mo) recurrence | Cheema, 2006 USA 17019636 | Long-term satisfactory clinical outcome | Combination of “long-term success” and “long-term improvement” (repeat procedures included) | PV-based ablation (segmental or circumferential) | 26 | 46 | 128 | 36%
Patients with early (<3 mo) recurrence | Cheema, 2006 USA 17019636 | Long-term success | The absence of symptomatic AF during the 6 mo off AAD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental or circumferential) | 26 | 20 | 128 | 9% | | <0.01 (Chi-squared)
Patients without early (<3 mo) recurrence | Cheema, 2006 USA 17019636 | Long-term success | >90% reduction of symptomatic AF during the 6 mo off ADD prior to last follow-up excluding 3-mo blanking period (only single procedure) | PV-based ablation (segmental or circumferential) | 26 | 36 | 72 | 50%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

Crude estimates only.

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Patients with long-term success | Cheema, 2006 USA 17019636 | QOL | Symptomatic burden (Darber scale*) | Scale | PV-based ablation (segmental or circumferential) | 26 | 83 | 24 | 0 | 24** | <0.01
Patients with long-term improvement | Cheema, 2006 USA 17019636 | QOL | Symptomatic burden (Darber scale*) | Scale | PV-based ablation (segmental or circumferential) | 26 | 23 | 24 | 2 | 24** | <0.01
Patients with failure | Cheema, 2006 USA 17019636 | QOL | Symptomatic burden (Darber scale*) | Scale | PV-based ablation (segmental or circumferential) | 26 | 94 | 24 | 18 | 6** | <0.01

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

* Modification of the University of Toronto AF Severity Scale.

** Difference between before and after therapy in each subgroup in each therapy, not net difference between independent subgroups.

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Cheema, 2006 USA 17019636 | PV-based ablation (segmental or circumferential) | 26 | 3/264 (1%)* | 6/264 (2%) | 3/264 (1%) | nd | 21/264** | nd | - Transient heart block; - Valve injury | 1/264 (0.3%) 1/264 (0.3%)

Total 264 procedures in 200 patients were analyzed (35 patients reportedly underwent at least one repeat procedure). There was no statistically significant difference between different types of procedure (segmental vs. circumferential).

* Severe stenosis was defined as >70% narrowing of PV by MRI.

** Pseudoaneurysm in the groin or retroperitoneal bleeding requiring transfusion.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Cheema, 2006 USA 17019636 | No | NA | NA | Yes | nd | nd | Yes? | Yes | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | No | NA
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Cheema, 2006 USA 17019636 | | Moderate
Explanation for Applicability Grade: | | Patients with short follow-up were excluded, possibly affecting patient spectrum.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Chen Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Chen, 2004 USA 15028358 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Chen, 2004 USA 15028358 | Symptomatic AF; refractoriness to AAD; and no indication for open heart surgery. | nd | 12/2000–01/2003 | | - Patients in the EF<40% group had more heart disease (ischemic, hypertensive, or idiopathic) and more advanced CHF (NYHA III+IV) than those in the EF≥40% group.; - Twenty-three patients had undergone a prior cavotricuspid isthmus ablation for atrial flutter.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Chen, 2004 USA 15028358 | nd | PVI (PV ostial) | 377 | 51 | 55 | 78 | 5.2 | 100* | 4.5 | 50 | C | Wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Chen, 2004 USA 15028358 | Yes | 100% implied [To abolish all PV potentials measured by mapping catheter] | - Cavotricuspid isthmus line*; - Ablation of non-PV foci** (No mitral lines) | No | 4mm cooled-tip (Chilli, EP Technology) | nd | 35 | nd

* Thirty-five patients.

** Four patients in a second procedure (details unclear)

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | No | If yes, how long was it? | NA

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
EF≥40% | Chen, 2004 USA 15028358 | Freedom From AF | Any episode of AF identified through the Holter, loop recorder, or standard ECG regardless of duration or symptoms. Blanking period unclear. | PVI (PV ostial) | 14 | 247 | 283 | 87% | nd | 0.03 (log-rank)
EF<40% | 69 | 94 | 73% | nd
EF≥40% | Chen, 2004 USA 15028358 | Total cure off AAD | Unclear (second procedure was included) | PVI (PV ostial) | 14 | 266 | 283 | 94% | Nd | 0.2 (?)
EF<40% | 90 | 94 | 96% | nd
EF≥40% | Chen, 2004 USA 15028358 | Freedom from atrial flutter | Unclear | PVI (PV ostial) | 14 | 279 | 283 | 99% | nd | Nd
EF≥40% | Chen, 2004 USA 15028358 | Second procedure | Unclear | PVI (PV ostial) | 14 | 19 | 283 | 7% | | 0.05 (?)
EF<40% | 21 | 94 | 21%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
EF<40% | Chen, 2004 USA 15028358 | Change in cardiac function | Improvement of LVEF before and 6 mo after procedure | % | PVI (PV ostial) | 6 | 94 | 36 | 41 | 5 | 0.1
EF<40% | Chen, 2004 USA 15028358 | QOL | Improvement of physical functioning before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 43 | 28.7 | 90.8 | 62.1 | <0.05
EF<40% | Chen, 2004 USA 15028358 | QOL | Improvement of role limitation due to physical health before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 43 | 8.3 | 65.8 | 57.5 | <0.05
EF<40% | Chen, 2004 USA 15028358 | QOL | Improvement of role limitation due to physical problem before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 43 | 22.2 | 62.2 | 40.0 | <0.05
EF<40% | Chen, 2004 USA 15028358 | QOL | Improvement of energy and fatigue before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 43 | 25.2 | 61.2 | 36.0 | <0.05
EF<40% | Chen, 2004 USA 15028358 | QOL | Improvement of emotional well-being before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 43 | 39.7 | 72.0 | 32.3 | <0.05
EF<40% | Chen, 2004 USA 15028358 | QOL | Improvement of social functioning before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 43 | 44.2 | 93.2 | 49.0 | <0.05
EF<40% | Chen, 2004 USA 15028358 | QOL | Improvement of pain before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 43 | 68.9 | 95.2 | 26.3 | <0.05
EF<40% | Chen, 2004 USA 15028358 | QOL | Improvement of general health before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 43 | 48.5 | 76.9 | 28.4 | <0.05
EF≥40% | Chen, 2004 USA 15028358 | QOL | Improvement of physical functioning before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 150 | 28.7 | 96.8 | 68.1 | <0.05
EF≥40% | Chen, 2004 USA 15028358 | QOL | Improvement of role limitation due to physical health before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 150 | 8.3 | 70.8 | 62.5 | <0.05
EF≥40% | Chen, 2004 USA 15028358 | QOL | Improvement of role limitation due to physical problem before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 150 | 22.2 | 65.2 | 43.0 | <0.05
EF≥40% | Chen, 2004 USA 15028358 | QOL | Improvement of energy and fatigue before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 150 | 25.2 | 65.2 | 40.0 | <0.05
EF≥40% | Chen, 2004 USA 15028358 | QOL | Improvement of emotional well-being before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 150 | 39.7 | 76.0 | 36.3 | <0.05
EF≥40% | Chen, 2004 USA 15028358 | QOL | Improvement of social functioning before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 150 | 44.2 | 93.2 | 49.0 | <0.05
EF≥40% | Chen, 2004 USA 15028358 | QOL | Improvement of pain before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 150 | 68.9 | 97.2 | 28.3 | <0.05
EF≥40% | Chen, 2004 USA 15028358 | QOL | Improvement of general health before and 6 mo after procedure | Score | PVI (PV ostial) | 6 | 150 | 48.5 | 78.9 | 30.4 | <0.05

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Chen, 2004 USA 15028358 | PVI (PV ostial) | 14 | 6/377 (2%)* | 2/377 (1%) | 5/377 (1%) | nd | nd | nd | Pulmonary edema | 1/377 (0.3%)

* defined as >70 of narrowing by spiral CT

All reported complications rates were not statistically different in the two groups (with or without impaired LV function); thus combined results were presented here.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Chen, 2004 USA 15028358 | No | NA | NA | nd | nd | nd | Yes? | Yes | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Chen, 2004 USA 15028358 | | | Wide
Explanation for Applicability Grade: | | Inclusion criteria and no exclusion sound like day-to-day clinical practice

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Chugh Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Chugh, 2005 USA 15840468 | | | | X | May overlap other cohort studies conducted in U. Michigan (e.g. Oral 2006) | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Chugh, 2005 USA 15840468 | nd | nd | nd | AAD and any rate-control medications were discontinued at 3 mo after procedure if patients were free from symptomatic AF*

* 58 out of 349 (17%) did not take any AAD after the procedure.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Chugh, 2005 USA 15840468 | nd | LACA + additional lines | 349 | 65 | 54 | 79 | 6 | nd | 4.2 | 55 or 50* | C | Wide

* Selected after recognition of the risk of esophageal perforation

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Chugh, 2005 USA 15840468 | No* | NA | - WACA/LACA; - Posterior line or roof line (LA)**; - Mitral isthmus line (LA); - Cavo-tricuspid isthmus line***; - Ablation of foci of AT in the LA | Yes | 8 mm (Navistar) | 70 | 55 | nd

* Voltage abatement (by >80% or <0.1mV by local electrogram) was the ablation endpoint; however, it is not clear whether PVI was confirmed or not. The presence of complete block across ablation lines was not assessed in systematic fashion.

** Selected after recognition of the risk of esophageal perforation

*** Only patients with prior history of or inducible atrial flutter

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Chugh, 2005 USA 15840468 | Freedom from AT | AT: a regular supraventricular rhythm with a cycle length ≥ 200 ms and a consistent atrial activation sequences | LACA + additional lines | 12.7 | 264 | 349 | 76% (Kaplan-Meier)
Chugh, 2005 USA 15840468 | Re-procedure | Re-ablation procedure due to AT | LACA + additional lines | 12.7 | 28 | 349 | 8% (?)
Chugh, 2005 USA 15840468 | Freedom from AF | No explicit definition of relapse. No explicit definition of blanking period. | LACA + additional lines | 12.7 | 197 | 349 | 87% (Kaplan-Meier)
Chugh, 2005 USA 15840468 | Re-procedure | Re-ablation procedure due to symptomatic AF | LACA + additional lines | 12.7 | 35 | 349 | 10% (?)

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | No*
Was a blanking period (time when AFib episodes were not recorded) used? | No | If yes, how long was it? | NA

* A device to monitor the recurrence was provided only to symptomatic patients.

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Patients who developed AT during the first procedure | Chugh, 2005 USA 15840468 | Freedom from AT | AT: a regular supraventricular rhythm with a cycle length ≥ 200 ms and a consistent atrial activation sequences | LACA + additional lines | 12.7 | 32 | 71 | 45%
Persistent or chronic AF | Chugh, 2005 USA 15840468 | Freedom from AF | No explicit definition of relapse. No explicit definition of blanking period. | LACA + additional lines | 12.7 | 91 | 122 | 75% (Kaplan-Meier)

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

In multivariate analyses (by the logistic regression) taking account of age, sex, LVEF, LA, AF category, AAD, RFA duration, and AT during the first procedure, only the presence of AT during the procedure was a statistically significant independent factor to predict recurrent AT (OR=10.7, 95% CI, 5.3–21.9, P<0.001). However, this was not a statistically significant factor to predict recurrent AF (P=0.1).

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)

No adverse events reported except for a patient who died of unrelated cause at 2 mo after the procedure.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Chugh, 2005 USA 15840468 | No | NA | NA | Yes (“No drop out”) | nd | nd | Yes | Yes | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | nd | No (only symptomatic) | NA
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Chugh, 2005 USA 15840468 | | | Wide
Explanation for Applicability Grade: | | Included patients sound like from everyday clinical practice, inferring wide applicability

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Corrado Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Corrado 2008 US & Italy 18363688 | | | | X | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Corrado 2008 US & Italy 18363688 | >75 yo, symptomatic AF, drug refractory, ≥9 months followup | nd | 2001-2006 | nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Corrado 2008 US & Italy 18363688 | nd 1 author with industry grants | | 174 | 55% | 77 | 63 | 7 | nd | 4.6 | 53 | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Corrado 2008 US & Italy 18363688 | Yes | Around PV antrum (lasso poles) | PVAI and SVC isolation | No | 8 mm | 30 W up to microbubbles | 55 | nd

See Verma 2004 (Corrado 2008 methods).pdf

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Corrado 2008 US & Italy 18363688 | 2^nd^ ablation | | | 20 | 20 | 174 | 11%
| SR off AAD | after 1^st^ ablation | | 20 | 127 | 174 | 73%
| | after 1^st^ or 2^nd^ ablation | | 20 | 143 | 174 | 82%
| SR on/off AAD | after 1^st^ or 2^nd^ ablation | | 20 | 165 | 174 | 95%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 8 wk

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Corrado 2008 US & Italy 18363688 | | | | 0/194 | 1/194* (0.5%) | 0/194 | 0/194 | | Hemothorax | 1/194* (0.5%)

* in 174 patients

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Corrado 2008 US & Italy 18363688 | No | NA | NA | Yes | NA | ~Yes | Yes | No | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | retrospective study

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Della Bella Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Della Bella 2005 Italy 15763523 | | | | x | learning curve; KQ 1, 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Della Bella 2005 Italy 15763523 | symptomatic AF, failed ≥2 AADs | | 2001-2003 | 69% | evidence for learning curve

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Della Bella 2005 Italy 15763523 | nd | PVI | 234 | 78 | 56 | 78 | 6.2 | nd | nd | nd | C | wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Della Bella 2005 Italy 15763523 | y | 90% [elimination of PV muscle conduction distal to ablation site] | cavotricuspid isthmus ablation in 20/234 pts with atrial flutter | n | thermocouple-equipped (prior to 9/02) | 25–30 | 50 | nd
irrigated tip (after 9/02) | 25–30 | 43 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Della Bella 2005 Italy 15763523 | success | sinus rhythm maintenance | PVI | 6 mo | | | 72%
| | sinus rhythm maintenance | PVI | 12 mo | | | 65%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | n | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Paroxysmal AF | Della Bella 2005 Italy 15763523 | success | sinus rhythm maintenance | PVI | 12 mo | | | 68%
persistent AF | | | | | | | | 54% | | 0.008
isolated all 4 PVIs | Della Bella 2005 Italy 15763523 | | arrhythmia event free survival | PVI | 12 mo | | | 71%
isolated <4 PVIs | | | | | | | | 37% | | <0.001
Last 100 ablations | Della Bella 2005 Italy 15763523 | learning curve | mean procedure time; mean fluoroscopy time | PVI | | | | 210 ± 86 min; 46 ± 35 min
First 100 ablations | | | | | | | | 300 ± 108 min; 64 ± 41 min
| Della Bella 2005 Italy 15763523 | Age, sex, structural heart disease, HTN, mitral valve disease were not predictive of long-term outcome on multivariate analysis.
| | No significant difference was observed in the arrhythmia recurrence rate between pts who had conventional tip versus those with irrigated tip ablation.

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Della Bella 2005 Italy 15763523 | PVI | | 2 symptomatic (required stent) and 1 asymptomatic high grade (70–90%), 3/234 (1.3%) | 3/234 (1.3%) | 1/234 (0.4%) | | | | AV-fistula required surgery | 4/234 (1.7%)
Della Bella 2005 Italy 15763523 | PVI | | 2 symptomatic (required stent) and 1 asymptomatic high grade (70–90%), 3/234 (1.3%) | 3/234 (1.3%) | 1/234 (0.4%) | | | | venous thrombosis required prolonged anticoagulation | 2/234 (0.9%)
pericardial effusion | 12/234 (5.1%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Della Bella 2005 Italy 15763523 | n | NA | n | NA | n | n | y | y | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | y | y | n
Explanation for Overall Quality Grade: | | | | retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Della Bella 2005 Italy 15763523 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Della Bella 2005 Italy 15763523 | evidence for a learning curve

Dixit 2006 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Dixit, 2006 US 16879626 | X 2×2 factorial | | | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Dixit, 2006 US 16879626 | Drug refractory AFib undergoing 1^st^ ablation | Contraindication to RFA | Yes. Usually class IC or sotalol (6 wk minimum) | Arrhythmogenic PVs = veins documented to initiate AFib and or atrial premature complexes, by intracardiac catheters 11/2003–2/2005

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Dixit, 2006 US 16879626 | Boston Scientific (unrestricted). Authors: Proctor Gamble, Biosense Warner, Boston Scientific | 2×2 Factorial: | | 72% | 57 | 73% | 5.2 yr | nd | nd | nd | A (except C for multivariable analysis) | Moderate
Dixit, 2006 US 16879626 | Boston Scientific (unrestricted). Authors: Proctor Gamble, Biosense Warner, Boston Scientific | >PVI all | | 72% | 57 | 73% | 5.2 yr | nd | nd | nd | A (except C for multivariable analysis) | Moderate
Dixit, 2006 US 16879626 | Boston Scientific (unrestricted). Authors: Proctor Gamble, Biosense Warner, Boston Scientific | | | 72% | 57 | 73% | 5.2 yr | nd | nd | nd | A (except C for multivariable analysis) | Moderate
Dixit, 2006 US 16879626 | Boston Scientific (unrestricted). Authors: Proctor Gamble, Biosense Warner, Boston Scientific | >PVI arrhythmogenic PV | | 72% | 57 | 73% | 5.2 yr | nd | nd | nd | A (except C for multivariable analysis) | Moderate
* 8 mm (Navistar) | 42
* Cooled tip (Chilli) | 40

Arrhythmogenic PVs only: n=37 (18 cool tip; 19 8-mm); All PVs: n=45 (22 cool tip; 23 9-mm)

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Dixit, 2006 US 16879626 | Yes | Cool tip: 1144/118 PVs (97%) 8 mm: 134/135 PVs (99.3%) [Loss of PV potentials (entry block) and failure to capture LA during pacing (exit block)] | No | Yes (stimulation protocol) | 8 mm | ≤70 | ≤50° | nd
Cooled | ≤50 | ≤40° | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Dixit, 2006 US 16879626 | Long-term control of AFib | Complete freedom and/or >90% reduction in AFib burden on or off previously ineffective AA drugs at 6 months | 8 mm | 6 mo | 32 | 41* | 1.52 | 0.56, 4.15 | NS
Cooled | 28 | 40
| Complete freedom from AFib off AAD | | 8 mm | 6 mo | 25 | 41 | 1.56 | 0.65, 3.70 | NS
Cooled | 20 | 40

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

* Excluding patient who died from LA-esophageal fistula.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 1 month

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Dixit 2006 US 16879626 | Cooled tip | | Significant (>=70%) 0/40 | 0/40 | TIA (complete recovery w/in 24°) 45 min p-RFA 1/40 (2.5%) | 0/40 | nd | 0/40
| 8 mm | | 0/42 | 0/42 | 0/42 | LA-esophageal fistula at 2 wk -> death 1/42 (2%) | nd | 1/42 (2%)

* 75/81 had spiral CT at 3 mo to evaluate.

OTHER

Unadjusted OR for 6 mo Long term control (defined above): | | | Unadjusted OR for Freedom from AF at 6 mo w/o AA drug
Male vs Female | 1.20 (0.39, 3.65) | NS | 2.00 | NS
Parox AF Y v N | 4.40 (1.52, 12.8) | P=.006 | 4.34 (1.53, 12.3) | .006
HTN YvN | 0.61 (0.23, 1.67) | NS | 0.59 | NS
Sleep Apnea YvN | 1.06 (.26, 2.13) | NS | 1.73 | NS
Any Comorbidity YvN | 0.75 (0.26, 2.13) | NS | 0.68 | NS
Non PV triggers YvN | 0.57 (0.21, 1.54) | NS | 0.83 | NS
Adjusted OR for 6 mo Long term control (defined above): | | | Adjusted OR for Freedom from AF at 6 mo w/o AA drug
Adjusted for all above factors (including catheter tip) and apparently also recurrence at 6 wk check. Not explicitly listed though.
Parox AF Y v N | “5 × more likely” | P<.05 | nd (>1) | P<.05

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Dixit 2006 US 16879626 | Yes | nd | nd | Yes (0%) | Patients blinded | Yes (no dropout) | Yes | Yes | Yes (except for multivariable analysis) | A (except C for multivariable analysis)
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | Yes | Yes
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Dixit 2006 US 16879626 | | Moderate
Explanation for Applicability Grade: | | N<100

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Dixit, 2006 US 16879626 | Oddly, no explicit analysis of PVI of all PV vs only arrhythmogenic PVs.

Dixit 2008 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Dixit 2008 US 18242535 | x | | | | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Dixit 2008 US 18242535 | Drug-refractory AF undergoing their first ablation procedure | Any contraindication to undergoing AF ablation and/or inability to provide informed consent | July 2003 to February 2005 | Upon completion of the procedure, patients were started on antiarrhythmic drugs (usually class IC agent or sotalol) and warfarin (Coumadin) | 58% had comorbidities: hypertension, chronic pulmonary disease, diabetes, and sleep apnea

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Dixit 2008 US 18242535 | private | 2×2 factorial design:; - isolate all versus arrhythmogenic PVs; - cool tip vs. 4- (July, 2003 to Nov 2003) or 8-mm (Nov, 2003 to Feb 2005) tip catheter | 105 | 73 | 57 | 72 | 5.2 | nd | nd | nd | A | moderate

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Dixit 2008 US 18242535 | yes | 100% [loss of PV potentials and failure to capture LA during pacing from all bipoles of the Lasso catheter] | Simulation protocol to elicit non-PV triggers, which also were targeted Non PV triggers consisted of APCs (23pts) and Typical atrial flutter (3pts) | yes | 4 mm (used in 11% patients) | <=50 | <=52 | Isolated all veins: 50 +- 30 min Isolated arrhythmogenic veins: 40 +-23 min
Dixit 2008 US 18242535 | yes | 100% [loss of PV potentials and failure to capture LA during pacing from all bipoles of the Lasso catheter] | Simulation protocol to elicit non-PV triggers, which also were targeted Non PV triggers consisted of APCs (23pts) and Typical atrial flutter (3pts) | yes | 8 mm (used in 41% patients) | <=70 | <=50 | Isolated all veins: 50 +- 30 min Isolated arrhythmogenic veins: 40 +-23 min
Chili (used in 48% patients) | <=50 | <=40

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Dixit 2008 US 18242535 | Long-term control of AF | Complete freedom and/or >=90% reduction in AF burden either off or on previously ineffective antiarrhythmic drug at 1 year after a single ablation procedure | Isolated all PVs | 1 yr | 38 | 51 | OR=1.18 | 0.50, 2.83 | 0.7
Isolated arrhythmogenic PVs | 1 yr | 37 | 52
Dixit 2008 US 18242535 | Freedom from AF at 1 year off AAD | Secondary endpoint | Isolated all PVs | 1 yr | 30 | 51 | OR=1.03 | 0.47, 2.27 | 0.9
Isolated arrhythmogenic PVs | 1 yr | 31 | 52
Dixit 2008 US 18242535 | Long-term control of AF | Complete freedom and/or >=90% reduction in AF burden either off or on previously ineffective antiarrhythmic drug at 1 year after a single ablation procedure | 4 mm | 1 yr | 8 | 12 | OR=1.03 | 0.30, 3.57 | 0.96
Dixit 2008 US 18242535 | Long-term control of AF | Complete freedom and/or >=90% reduction in AF burden either off or on previously ineffective antiarrhythmic drug at 1 year after a single ablation procedure
8 mm | 1 yr | 32 | 41 | OR=1.18 | 0.47, 2.99 | 0.72
Chili | 1 yr | 35 | 50 | Ref group
Dixit 2008 US 18242535 | Freedom from AF at 1 year off AAD | Secondary endpoint | 4 mm | 1 yr | 8 | | OR=1.43 | 0.40, 5.11 | 0.6
Dixit 2008 US 18242535 | Freedom from AF at 1 year off AAD | Secondary endpoint | 8 mm | 1 yr | 27 | | OR=1.59 | 0.70, 3.59 | 0.3
Chili | 1 yr | 26 | | Ref group

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | No
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | 6 weeks

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Male | Dixit 2008 US 18242535 | Long-term control of AF | Complete freedom and/or >=90% reduction in AF burden either off or on previously ineffective antiarrhythmic drug at 1 year after a single ablation procedure | isolate all or arrhythmogenic PVs | 1 yr | 61 | 82 | OR=1.45 | 0.52, 4.08 | 0.5
Female | 1 yr | 14 | 21
Paroxysmal AF | Dixit 2008 US 18242535 | Long-term control of AF | | isolate all or arrhythmogenic PVs | 1 yr | 59 | 75 | OR=2.76 | 1.09, 7.01 | 0.032
Not paroxysmal AF | 1 yr | 16 | 28
Comorbidities | Dixit 2008 US 18242535 | Long-term control of AF | | isolate all or arrhythmogenic PVs | 1 yr | 41 | 58 | OR=1.28 | 0.53, 3.11 | 0.6
No comorbidities | 1 yr | 34 | 45
Early AF recurrence (within 6 weeks) | Dixit 2008 US 18242535 | Long-term control of AF | | isolate all or arrhythmogenic PVs | 1 yr | 8 | 20 | OR=0.14 | 0.05, 0.42 | <.001
no early AF recurrence | 1 yr | 65 | 79
Male | Dixit 2008 US 18242535 | Freedom from AF at 1 year off AAD | Secondary endpoint | isolate all or arrhythmogenic PVs | 1 yr | 50 | 82 | OR=1.42 | 0.54, 3.73 | 0.5
Female | 1 yr | 11 | 21
Paroxysmal AF | Dixit 2008 US 18242535 | Freedom from AF at 1 year off AAD | | isolate all or arrhythmogenic PVs | 1 yr | 49 | 75 | OR=2.53 | 1.04, 6.10 | 0.042
Not paroxysmal AF | 1 yr | 12 | 28
Comorbidities | Dixit 2008 US 18242535 | Freedom from AF at 1 year off AAD | | isolate all or arrhythmogenic PVs | 1 yr | 31 | 58 | OR=1.38 | 0.56, 3.36 | 0.5
No comorbidities | 1 yr | 30 | 45
Early AF recurrence (within 6 weeks) | Dixit 2008 US 18242535 | Freedom from AF at 1 year off AAD | | isolate all or arrhythmogenic PVs | 1 yr | 2 | 20 | OR=0.04 | 0.01, 0.20 | <.001
no early AF recurrence | 1 yr | 57 | 79

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Dixit 2008 US 18242535 | Isolated all PVs (n=53) | | 0 (>=70% PV stenosis) | 0 | 1 (2%) | 1 (2%) | | 1 (2%)
| Isolated arrhythmogenic PVs (n=52) | | 0 | 0 | 0 | 0 | | 0

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Dixit 2008 US 18242535 | yes | nd | nd | Yes (2%) | Patients only | Yes | yes | Yes | yes | A
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | yes | yes | yes | No
Explanation for Overall Quality Grade: | | | | As described above

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Dixit 2008 US 18242535 | | x
Explanation for Applicability Grade: | | Only 105 (42%) of 251 eligible subjects were randomized

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Dong Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Dong 2005 China 16117858 | | x | | | PVI vs. CPVA; KQ 1, 3 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Dong 2005 China 16117858 | symptomatic AF, failed AAD | | | 1 mo | first 50 cases of PVI or CPVA were excluded to exclude learning curve bias

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Dong 2005 China 16117858 | nd | CPVA | 68 | 68 | 56 | 76 | 6.6 | | 3.77 | 67 | C | moderate
PVI | 83 | 100 | 57 | 69 | 7.2 | | 3.78 | 67

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Dong 2005 China 16117858 | y | 100% implied [electrical isolation of PVs assessed circular mapping catheter] | PVI group; CPVA group | n | PVI by “an ablation catheter” (Tip not specified) | nd | nd | nd
irrigated tip (ThermoCool) in CPVA | nd | nd | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Dong 2005 China 16117858 | success | stable sinus rhythm without AADs | PVI | 12.7 mo | 50 | 83 | 60%
| | | CPVA | 7.2 mo | 56 | 68 | 82% | | <0.001

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | n | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Dong 2005 China 16117858

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Dong 2005 China 16117858 | n | NA | n | nd | n | n | y | n | n | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | n | n | n | y | n
Explanation for Overall Quality Grade: | | | | 2 groups not entirely comparable (different AFs, different followup); no information on pts lost to followup as they were excluded

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Dong 2005 China 16117858 | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Essebag Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Essebag, 2005 USA 16183686 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Essebag, 2005 USA 16183686 | Any patients with AF who underwent PV isolation by RFA | nd | | Nd. Patients with persistent/permanent AF or early relapse (<30 d) continued AADs. | - PV isolation was repeated in 6% of patients at a median of 5 moths (IQR, 2–7 moths) after the initial procedure.; - Ablation for atrial flutter had been performed prior to PV isolation (initial procedure) in 20% of patients

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Essebag, 2005 USA 16183686 | Canadian Institutes of Health Research (CIHR) and National Heart, Lung, and Blood Institute (NHLBI) | RFA (PV isolation) | 102 | 59 | 53 | 74 | nd | nd | 4.5 | 56 | C | Moderate

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Essebag, 2005 USA 16183686 | Yes | Nd (100% inferred) [entrance block (loss of PV potential) and exit block (failure to capture the LA by pacing (at 10 mA) 10–14 bipolar pairs of electrodes on a circumferential catheter positioned at the entrance of the PV)] | - LA: mitral isthmus line and/or posterior left line (in case AF/LA tachycardia was induced (n=21)); - RA: isthmus line (in case of a history of or inducible atrial flutter (52%)) | Yes* | NaviStar (8 mm) | nd | 52 | nd

* Defined as induction of AF or left atrial tachycardia lasting > 10s by pacing at the RA and CS, and isoproterenol.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Essebag, 2005 USA 16183686 | Freedom from AF | Asymptomatic and symptomatic atrial tachyarrhythmia consistent with AF lasting > 10 s beyond 30 days post-procedure period | RFA (PV isolation) | 15** | nd | 102 | 70% (at 6 mo) and 62% (at 12 mo) | nd | Nd

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

** Median

Multivariate analyses by logistic regression identified non-inducibility (OR=4.3 (95% CI, 1.2–15.5 (P=0.027)), paroxysmal AF(OR=3.2 (95% CI, 1.1–10.0 (P=0.040)), and no valvular heart disease (OR=4.0 (95% CI, 1.0–16.2 (P=0.050)) as statistically significant factors to predict freedom from relapse at 6 mo, and non-inducibility (OR=3.8 (95% CI, 1.0–15.5 (P=0.047)), paroxysmal AF(OR=4.8 (95% CI, 1.4–16.3 (P=0.012)) at 12 mo. Non-inducibility, age, sex, hypertension, AF type, and valvular heart disease were taken into account a priori.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 30 days

* 2-week transtelephonic event recorder and 24h Holter ECG at 1, 3, 6, and 12 months.

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Paroxysmal | Essebag, 2005 USA 16183686 | Freedom from AF | Asymptomatic and symptomatic atrial tachyarrhythmia consistent with AF lasting > 10 s beyond 30 days post-procedure period | PVI (ostial) | 15* | nd | 60 | 81% (at 6 mo) and 74% (at 12 mo) | nd | <0.001 (log-rank)
Persistent or permanent | | 42 | 54% (at 6 mo) and 45% (at 12 mo)
Paroxismal, non-inducible | Essebag, 2005 USA 16183686 | Freedom from AF | Asymptomatic and symptomatic atrial tachyarrhythmia consistent with AF lasting > 10 s beyond 30 days post-procedure period | PVI (ostial) | 15* | nd | 34 | 88% (at 6mo) and 81% (at 12 mo) | nd | 0.05 (log-rank)
Paroxismal, inducible | nd | 26 | 72% (at 6 mo) and 64% (at 12 mo)
Persistent, non-inducible | Essebag, 2005 USA 16183686 | Freedom from AF | Asymptomatic and symptomatic atrial tachyarrhythmia consistent with AF lasting > 10 s beyond 30 days post-procedure period | PVI (ostial) | 15 | nd | 11 | 82% (at 6mo) and 65% (at 12 mo) | nd | 0.30 (log-rank)
Persistent, inducible | nd | 22 | 45% (at 6 mo) and 41% (at 12 mo)
PV isolation + additional lines | Essebag, 2005 USA 16183686 | Freedom from AF | Asymptomatic and symptomatic atrial tachyarrhythmia consistent with AF lasting > 10 s beyond 30 days post-procedure period | PVI (ostial) | 15* | Nd | 15 | 57% (at 12 mo) | nd | 0.52 (log-rank)
PV isolation only | nd | 87 | 50% (at 12 mo)

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); chronic/persistent/paroxysmal; others

* Median

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Essebag, 2005 USA 16183686 | PVI (ostial) | 15* | 0/102 | 3/102 (3%)** | 1/102 (1%)*** | 0/102 | 4/102 (4%)**** | 0/102 | Nd

* Median

** Two of them required drainage.

*** TIA after 4h post-procedure.

**** All the four patients required blood transfusion.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Essebag, 2005 USA 16183686 | No | NA | NA | nd | nd | Nd/NA | Yes | Yes | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Nd** | Yes | No
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

** Patients who underwent repeated procedure should be counted as event but not explicitly reported.

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Essebag, 2005 USA 16183686 | | Moderate
Explanation for Applicability Grade: | | Inclusion criteria seem broad, but the procedure was performed by a single operator.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Estner Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Estner 2006 Germany 16831837 | | x | | | PVI with or without NavX^®^; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Estner 2006 Germany 16831837 | symptomatic AF, failed AADs | | nd | | non-concurrent comparison

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Estner 2006 Germany 16831837 | nd | PVI | 32 | 94 | 58 | 75 | 5.5 | | 4.76 | 32.4 | C | moderate
PVI with NavX® | 32 | 88 | 59 | 75 | 5.7 | | 4.6 | 33.9

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Estner 2006 Germany 16831837 | y | 93.5% and 96.8% [dissociation of PV potentials from the left atrium] | group 1: PVI with conventional fluoroscopy group 2: PVI using NavX® - only catheter location and tracking was visualized, no 3D geometry was performed | n | 4 mm irrigated (Celsius ThermoCool) | 25–35 | 48 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Estner 2006 Germany 16831837 | outcome 1 | freedom from recurrence of symptomatic AF | PVI | 10.0 | 27 | 31 | 87%
| | | PVI with NavX® | 9.5 | 28 | 31 | 90% | | nd
| outcome 2 | sinus rhythm | PVI | 10.0 | 21 | 31 | 68%
| | | PVI with NavX® | 9.5 | 23 | 31 | 74% | | 0.57
| outcome 3 | asymptomatic AF | PVI | 10.0 | 6 | 31 | 19%
| | | PVI with NavX® | 9.5 | 5 | 31 | 16% | | 0.99

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | n
Was a blanking period (time when AFib episodes were not recorded) used? | n | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Estner 2006 Germany 16831837 | PVI
| PVI with NavX^®^ | | | | 1/32 (3.1%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Estner 2006 Germany 16831837 | n | NA | NA | y | n | n | y (?) | n | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | n | y | y
Explanation for Overall Quality Grade: | | | | non-concurrent comparison, no statistical adjustment for potential confounders

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Estner 2006 Germany 16831837 | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Fassini Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Fassini 2005 Italy 16302895 | x | | | | PVI vs. PVI + left mitral isthmus ablation; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Fassini 2005 Italy 1630289 | drug refractory AF (amiodarone and IC) | nd | nd | 6 mo (in those with permanent AF) | 18% of patients had had previous ablations

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Fassini 2005 Italy 1630289 | nd | PVI | 92 | 67 | 55 | 80 | nd | nd | 4.26 | 56 | B | moderate
PVI + left mitral isthmus ablation | 95

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Fassini 2005 Italy 1630289 | y | 100% [complete elimination of PV electrical activity] | Group 1: PVI Group 2: PVI +mitral isthmus line (bidirectional block in 72 (76%) + RFA in distal CS in 54 (75%) | n | irrigated tip | 25–35 | 40 | 48 (PVI only group)

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Fassini 2005 Italy 1630289 | freedom from AF recurrence | maintenance of stable sinus rhythm after single procedure | PVI | 12 | | | 53 ± 5%
| | | PVI+MIL | | | | 71 ± 5% | | 0.01
| | continual use of AAD | PVI | 12 | | | 56
| | | PVI+MIL | | | | 50 | | NS
| | non-sustained AF | PVI | 12 | 6 | 92
| | | PVI+MIL | | 8 | 95 | | | NS

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | n | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
paroxysmal AF | Fassini 2005 Italy 1630289 | freedom from AF recurrence | maintenance of stable sinus rhythm | PVI | 12 | | | 62 ± 6%
| | | | PVI+MIL | | | | 76 ± 6% | | <0.05
persistent AF | Fassini 2005 Italy 1630289 | freedom from AF recurrence | maintenance of stable sinus rhythm | PVI | | | | 36 ± 9%
| | | | PVI+MIL | | | | 74 ± 9% | | <0.01

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Fassini 2005 Italy 1630289 | PVI | intra-procedural | | | TIA 1/92 (1.1%)
| PVI+MIL | intra-procedural | | 1/95 (1%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Fassini 2005 Italy 1630289 | y | nd | nd | nd | n | y | y | NA | n | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | y | y | n
Explanation for Overall Quality Grade: | | | | unclear how many patients completed followup at 12 mo; although ITT was performed; unclear what proportion of patients had permanent AF as they received 6 mo of AAD post treatment; this may have affected the findings

* observational study cannot be an A, retrospective study is always a C

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Fassini 2005 Italy 1630289 | | X
Explanation for Applicability Grade: | | relatively young population who failed at least 2 AAD (one must be amiodarone)

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
| unclear what proportion of patients had permanent AF as they received 6 mo of AAD post treatment; this may have affected the findings

Fiala Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Fiala 2008 Czech Rep 18684255 | | | | X | KQ2 | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Fiala 2008 Czech Rep 18684255 | First ablation of persistent or paroxysmal AF | None | 2002-2006 | nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Fiala 2008 Czech Rep 18684255 | nd No disclosures | RFA | 194 | 30 | 55 | 80 | nd | nd | 4.5 | 54 | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Fiala 2008 Czech Rep 18684255 | Yes | PV antrum encircling Endpoint was full elimination of all high frequency potentials within the encircled area validated by the ring catheter. | PLM (mitral) isthmus line Roof line LL-RL line PSM isthmus Septal line LAA septal line LA focal ablations (sites suspected or participating in the mechanism of organized AF or LAT) CS ablation (if LA tachycardia) | No | 4 mm (NaviStar) or | 50 W | 56° | nd
3.5 mm irrigated (NaviStar ThermoCool) | 35 W | 42° | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Unclear, not explicitly
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 3 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Long-lasting persistent AF (>6 mo) | Fiala 2008 Czech Rep 18684255 | Repeat ablation | | RFA | nd | 43 | 100 | 43%
Short-lasting persistent AF (<6 mo) | | | | | | 9 | 35 | 26%
Paroxysmal | | | | | | 16 | 59 | 27% | | nd
Long-lasting persistent AF (>6 mo) | Fiala 2008 Czech Rep 18684255 | Freedom of AF recurrence (after a single ablation, some on AAD) | | | 31 | 50 | 100 | 50%
Short-lasting persistent AF (<6 mo) | | | | | 27 | 22 | 35 | 63%
Paroxysmal | | | | | 36 | 39 | 59 | 66% | | nd

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
| nd

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Fiala 2008 Czech Rep 18684255 | No | NA | NA | Yes | NA | ~Yes | Unclear | No | No (very unclear results data) | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Unclear | Unclear | Yes | No
Explanation for Overall Quality Grade: | | | | Unclear results data

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Forleo Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Forleo 2007 Italy 17636302 | | x | | x | RFA in men vs. women; KQ 2, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Forleo 2007 Italy 17636302 | symptomatic AF; failed AADs | age <18 or ≥75 y; any condition that would make survival unlikely for ≤1 y; previous RFA for AF | nd | 1–3 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Forleo 2007 Italy 17636302 | nd | PVI in men | 150 | 61 | 57 | 100 | 3.9 | | 4.06 | 57 | C | moderate
PVI in women | 71 | 56 | 62 | 0 | 5 | | 4.4 | 57.4

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Forleo 2007 Italy 17636302 | y | 99% [abolition of all PV potentials] | PVI + cavotricuspid isthmus ablation ± roof lines/mitral line | n | 3.5 mm cooled tip | 35 | 45 | men - 34.5
women - 36.3

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Forleo 2007 Italy 17636302 | success | free of arrhythmia (AF or left AT, ± AADs) | PVI in men | 22.5 mo | | | 82.7%
| | | PVI in women | | | | 83.1%; HR 0.89 | 0.44–1.78 | 0.75
| success | free of arrhythmia (AF or left AT, no AADs) | PVI in men | 22.5 mo | | | 74%
| | | PVI in women | | | | 67.6% | | NS

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 1 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Forleo 2007 Italy 17636302 | QOL | change in SF-36 (physical) | | PVI in men | | nd | 35.02 | 78.17 | | NS
PVI in women | | nd | 33.03 | 82.19
| QOL | change in SF-36 (mental) | | PVI in men | | nd | 52.8 | 65.21 | | NS
PVI in women | | nd | 51.07 | 68.73

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Forleo 2007 Italy 17636302 | PVI in men | | 1 moderate to severe (50%) | 2/150 (1.3%) | 2/150 strokes (after 16 mo, 25 mo); transient neurological events, 2/150 (1.3%); | | | | mild pericardial effusion | 4/150 (2.7%)
PVI in women | | 1 moderate to severe (50%) | 2/71 (2.8%) | | | | | | 1/71 (1.4%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Forleo 2007 Italy 17636302 | n | NA | n | y | n | n | y | n | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | n | n | y
Explanation for Overall Quality Grade: | | | | no adjustment for potential confounders

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Forleo 2007 Italy 17636302 | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Gerstenfeld Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Gerstenfeld 2006 US 16443531 2007 US 17081205 | | | | x | | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Gerstenfeld 2006 US 16443531 | paroxysmal or persistent AF | nd | 2001-2004 | 6 wk (paroxysmal AF) to 6 mo (persistent AF) | Data on ≤2 and >2 PV ablations have been merged into one cohort in this extraction.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Gerstenfeld 2006 US 16443531 | nd | PVI | 451 | 73 | 55 | 76 | 6.7 | | 4.4 | 58 | C | wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Gerstenfeld 2006 US 16443531 | y | [loss of high frequency signals and loss of atrial capture pacing] | PVs targeted for ablation if they initiated AF or provoked any atrial premature depolarizations; empiric 4-PV isolation in patients without identifiable triggers | n | 4 mm, 8 mm, or cooled tip (Chilli - internal irrigation catheter) | nd | nd | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Gerstenfeld 2006 US 16443531 | AF Freedom after single procedure | no AF off AADs, a single isolated AF occurrence allowed | PVI | 16.4 mo | 284 | 450 | 63%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | nd
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 6 wk

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Gerstenfeld 2006 US 16443531 | PVI | | 3/449 (2 asymptomatic, 1 symptomatic required stent) (0.7%) | | stroke or TIA, 4/449 (1 had persistent neurologic deficit) (0.9%) | | | | pericardial effusion required drainage | 6/449 (1.3%)
jugular hematoma required intubation | 1/449 (0.2%)
Gerstenfeld 2007 US 17081205 | PVI | 35 | 0.1% (symptomatic) 0.6% (>75% narrowing regardless of symptoms) | 0.9% | 0.5% (stroke) 0.2% (TIA) | 1/1058 (0.1%) | 0.8% (hematoma) 0.6% (pseudoaneurysm) 0.7% (AV fistula) 0.1% () | 2/1058 (0.2%) (1 from anaphylaxis after the procedure and 1 from AE fistula) | Cardiogenic shock | 0.1%
Gerstenfeld 2007 US 17081205 | PVI | 35 | 0.1% (symptomatic) 0.6% (>75% narrowing regardless of symptoms) | 0.9% | 0.5% (stroke) 0.2% (TIA) | 1/1058 (0.1%) | 0.8% (hematoma) 0.6% (pseudoaneurysm) 0.7% (AV fistula) 0.1% () | 2/1058 (0.2%) (1 from anaphylaxis after the procedure and 1 from AE fistula) | Radiation burn | 0.1%
Gerstenfeld 2007 US 17081205 | PVI | 35 | 0.1% (symptomatic) 0.6% (>75% narrowing regardless of symptoms) | 0.9% | 0.5% (stroke) 0.2% (TIA) | 1/1058 (0.1%) | 0.8% (hematoma) 0.6% (pseudoaneurysm) 0.7% (AV fistula) 0.1% () | 2/1058 (0.2%) (1 from anaphylaxis after the procedure and 1 from AE fistula) | Coronary air embolism | 0.4%
Anaphylaxis | 1/1058 (0.1%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Gerstenfeld 2006 US 16443531 | n | NA | n | y | n | n | y | n | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | n | y | y | n | y
Explanation for Overall Quality Grade: | | | | retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Gerstenfeld 2006 US 16443531 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Hachiya Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Hachiya 2007 Japan 17286569 | | x | | | Extensive Encircling PVI (EEPVI) with ATP vs. EEPVI without ATP (historical cohort); KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Hachiya 2007 Japan 17286569 | paroxysmal or persistent AF | nd | 2003-2005 | | non-concurrent comparison

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Hachiya 2007 Japan 17286569 | nd | EEPVI+ATP | 82 | 76 | 56 | 82 | nd | nd | 4.17 | nd | C | Narrow
EEPVI only | 170 | 79 | 54 | 84 | nd | nd | 4.13 | nd

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Hachiya 2007 Japan 17286569 | y | 58% (?) [elimination of PV potentials or lack of capture during pacing] | Inducibility: After successful EEPVI, provoke reconnection by ATP 30 mg during isoproterenol infusion. In those with reconnection, re-ablation followed by re-ATP. | y | 8 mm | 30–35 | 50 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Hachiya 2007 Japan 17286569 | AF clinical recurrence | no AF and not on AAD | EEPVI+ATP | 6 mo | 60 | 82 | 73%
| | | EEPVI only | 6 mo | 102 | 170 | 60% | | 0.04

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | n
Was a blanking period (time when AFib episodes were not recorded) used? | n | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Hachiya 2007 Japan 17286569 | EEPVI +ATP | | | 1/82 (1.2%)
| EEPVI only | | | nd

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Hachiya 2007 Japan 17286569 | n | NA | NA | | n | n | y | n | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | n | y | y | n
Explanation for Overall Quality Grade: | | | | non-concurrent comparison, no adjustment for possible confounding factors

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Hachiya 2007 Japan 17286569 | X
Explanation for Applicability Grade: | | details regarding study population not completely reported

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Haissaguerre Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Haissaguerre, 2004 France 15184286 | X (not for our report purpose) | | | | RCT of PVI vs. PVI+ mitral isthmus ablation (additional line) | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Haissaguerre, 2004 France 15184286 | Episodes of clinical AF persisting for ≥1 hour to minimize the chance of random termination of AF during ablation | None stated | nd | All antiarrhythmic drugs were stopped after ablation, except for patients with early recurrence of AF. These patients were offered further ablation during the index hospitalization or trial of antiarrhythmics for 1 month. | 43% had structural heart disease

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Haissaguerre, 2004 France 15184286 | Government and private | PVI: circumferential (Lasso) PVI plus cavotricuspid isthmus ablation | 70 | nd | 53 | 74 | 5.1 | nd | Parasternal: 4.3 Longitudinal 5.4 Transverse: 4.0 | 67 | A; B for subgroup analysis | Moderate
PVI+MIA (mitral isthmus ablation): same as PVI group following additional left linear ablation between the left inferior PV (and contiguous root of the appendage) and the lateral mitral annulus

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Haissaguerre, 2004 France 15184286 | yes | 100% [total elimination or dissociation of the PV potentials] | PVI and CTI | Yes (inducibility was checked before ablation, after isolation of all PVs, and after MIA in those randomized to PVI+MIA group)** | 4-mm Irrigated tip (Celsius ThermoCool, Biosense-Webster) | 30 W (inside) and 40 W (outside the PV) | 50 | 70*
PVI+MIA + CTI (left linear ablation between the left inferior PV and contiguous root of the appendage and the lateral mitral annulus) (RF was also delivered in CS) | PVI: same as above MIA: 40 W; epicardially through the coronary sinus (when needed) with a power of 25 to 30 W | PVI: same as above MIA: 50 | PVI: 70* MIA: 22

* all patients were lumped together when calculated the mean ablation time

** After PV isolation, sustained arrhythmia (AF persisted for =10 min) persisted or could be induced in 30 patient (30/70, 43%). After the additional left linear ablation, 8 patients (8/35, 23%) being inducible (AF in 5 left atrial flutter in 3).

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Haissaguerre, 2004 France 15184286 | Arrhythmia free without the use of antiarrhythmics | Absence of arrhythmia (AF or flutter) beyond the 1^st^ month without the use of antiarrhythmics | PVI | 7 | 26 | 35 | | | nd
PVI+MIA | 29 | 35

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes. Patients were hospitalized for 1 day at 1, 3, 6, and 12 months after the last procedure. Surface ECG and bipolar endocardial electrograms were continuously monitored and stored on a computer-based digital amplifier/recorder system.
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | Within 1 month after ablation

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Noninducibility of AF after ablation | Haissaguerre, 2004 France 15184286 | Arrhythmia free without the use of antiarrhythmics | Absence of arrhythmia (AF or flutter) beyond the 1st month without the use of antiarrhythmics | PVI alone or PVI+MIA | 7 | 40 | 46 | | | 0.03 (log-rank test)
Inducibility of AF after ablation | 15 | 24

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Haissaguerre, 2004 France 15184286 | Yes (not for our report purpose) | nd | nd | 0% | nd | yes (0% dropout) | yes | No (for subgroup analysis) | yes | A; B for subgroup analysis
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | yes | yes | yes | no
Explanation for Overall Quality Grade: | | | | B for subgroup analysis because the analysis did not take into account patients received different procedures (PVI alone or PVI+MIA)

* observational study cannot be an A, retrospective study is always a C

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Haissaguerre, 2004 France 15184286 | | x
Explanation for Applicability Grade: | | Type of AF was not reported. N<100 per intervention

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Haissaguerre, 2004 France 15184286 | 15 patients with recurrent atrial arrhythmia, 4 had left atrial flutter and 11 had AF. 11 of these 15 patients underwent an additional procedure. The 3 previously noninducible patients showed PV recovery as compared with 4 of the 8 patients with persistent inducibility.

Hocini Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Hocini, 2005 France 16344401 | X | | | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Hocini, 2005 France 16344401 | Paroxysmal AFib | nd | Jan-Dec 2003 | D/C “after ablation” if no “concurrent indications” | 25/90 with structural heart disease

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Hocini, 2005 France 16344401 | Govt and professional organizations (Lecture fees and advisory board for B-W etc.) | PVI alone | 45 | 100 | 55 | 79 | 5.25 yr | nd | 4.1 | 67% | C | Moderate
PVI + roofline | 45

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Hocini, 2005 France 16344401 | Yes | 100% | Wide circumferential Bidirectional cavotricuspid isthmus block | Yes | 4 mm irrigated (Celsius ThermoCool) | 30–35 W (L veins at their anterior aspect: 25 W) | 50° | 33
Plus: LA roof joining superior PVs (with eval of complete linear block) | 35

In the event of recurrent symptomatic or asymptomatic arrhythmia, patients were offered an additional ablation after a trial of drug therapy.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Hocini, 2005 France 16344401 | Arrhythmia free | No atrial arrhythmia off AAD (symptomatic or asymptomatic) | PVI alone | 15 | 31 | 45 | | | .04
| | | PVI+roofline | 14 | 39 | 45

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Unclear | If yes, how long was it? | nd

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Hocini, 2005 France 16344401 | | | 1/90 at routine 12 mo CT (asymptomatic, 70%) | Pericardial tamponade 1/90* | | | | | R phrenic nerve injury 1/90**

* During cavotricuspid isthmus ablation, at 38 W. Percutaneous drainage with no long term sequelae

** Complete recovery at 4 mo

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Hocini, 2005 France 16344401 | Yes | nd | nd | Yes (0%) | nd | Yes (0%) | Yes | NA | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Unclear Redo's were done. | Yes | No
Explanation for Overall Quality Grade: | | | | Unclear about blanking. Unclear if outcome is after single procedure or includes repeats.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Hocini, 2005 France 16344401 | | Moderate
Explanation for Applicability Grade: | | Paroxysmal only

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Hsu 2004 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Hsu 2004 France 15575053 | | x | x | | | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Hsu 2004 France 15575053 | AF failed ≥2 AADs; ≥ NYHA class II with LVEF <45% CHF | | 2001-2004 | none | 58 pts matched for age, sex, and AF classification but without CHF were selected as controls

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Hsu 2004 France 15575053 | governments | PVI ± LA linear lines | 58 with CHF | 9 | 56 | 88 | 6.7 | 100 (NYHA 2.3) | 5.0 | 35 | B | moderate
58 with no CHG | 9 | 56 | 88 | 6.6 | 0 (NYHA 1.3) | 4.6 | 66

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Hsu 2004 France 15575053 | y | [disappearance or dissociation of PV potentials] | PVI+/-LA linear ablations (roof line +/- mitral line) Linear ablation in “most” patients. | n | 4 mm irrigated ThermoCool - external irrigation | 25–30 (PVI); 40 (linear) | 50

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Hsu 2004 France 15575053 | | sinus rhythm | PVI in pts with CHF (include repeat procedures), not on AADs | 12 mo | | | 69%
| | | PVI in pts without CHF, not on AADs | | | | 71%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Hsu 2004 France 15575053 | QOL | SF-36 - physical | | PVI in CHF | 12 mo | | | | 24 ± 21 | <0.001
| | SF-36 - mental | | PVI in CHF | 12 mo | | | | 21 ± 19 | <0.001
| QOL | SF-36 - physical | | PVI, no CHF | 12 mo | | | | 18 ± 17 | 0.003
| | SF-36 - mental | | PVI, no CHF | 12 mo | | | | 14 ± 19 | 0.004
| NYHA class ↓ (improvement) | | | PVI in CHF | 12 mo | | 2.3 | 1.4 | | <0.001
| | | | PVI, no CHF | | | | | | NS
| LVEF increase | | | PVI in CHF | 12 mo | | | | 21 ± 13 | <0.001

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Hsu 2004 France 15575053 | PVI in CHF | | | 1/58 (1.7%) | 1/58 (1.7%) | | | | death from worsening CHF (with CHD) at 3 mo (AF recurred at 1 mo) | 1/58 (1.7%)
| PVI no CHF | | | 1/58 (1.7%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Hsu 2004 France 15575053 | n | NA | n | y | n | n | y | ? | y | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Hsu 2004 France 15575053 | y | n | y | n
Explanation for Overall Quality Grade: | | | | cohort

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Hsu 2004 France 15575053 | | x
Explanation for Applicability Grade: | | applicable to pts with permanent AF with CHF

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Hsu 2005A Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Hsu 2005 (A) France 15683473 | | | | x | only cardiac tamponade events from retrospective cohort were extracted; KQ4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Hsu 2005 France 15683473 | AF ablation procedures including initial and repeat | | 2002

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Hsu 2005 France 15683473 | y | 90% [bidirectional mitral isthmus conduction block] | PVI + individualized LA ablation (mitral line, roof line or both) ± cavotricuspid isthmus (CTI) ablation | | 4 mm irrigated (Celsius) | PVI: 25–30 | 50
Hsu 2005 France 15683473 | y | 90% [bidirectional mitral isthmus conduction block] | PVI + individualized LA ablation (mitral line, roof line or both) ± cavotricuspid isthmus (CTI) ablation | | 4 mm irrigated (Celsius) | LA linear: 40–60
CTI: 45–50

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Hsu 2005 France 15683473 | PVI + individualized LA ablation + cavotricuspid isthmus (CTI) ablation | | | 10/348 LA linear ablation procedures (2.9%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Hsu 2005B Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Hsu 2005 (B) France 15683473 | | | x | | only cardiac tamponade events from retrospective cohort were extracted | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Hsu 2005 France 15683473 | AF ablation procedures including initial and repeat | | 2003

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Hsu 2005 France 15683473 | y | 92% [bidirectional mitral isthmus conduction block] | PVI + individualized LA ablation (mitral line, roof line, or both) ± cavotricuspid isthmus (CTI) ablation | | 4 mm irrigated (Celsius) | PVI: 25–30 | 50
Hsu 2005 France 15683473 | y | 92% [bidirectional mitral isthmus conduction block] | PVI + individualized LA ablation (mitral line, roof line, or both) ± cavotricuspid isthmus (CTI) ablation | | 4 mm irrigated (Celsius) | LA linear: ≤42
CTI: 45–50

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Hsu 2005 France 15683473 | procedural success

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Hsu 2005 France 15683473 | PVI + individualized LA ablation + cavotricuspid isthmus (CTI) ablation | | | 4/398 LA linear ablation procedures (1.0%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Jais 2004 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Jais 2004 France 15520313 | | x | | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Jais 2004 France 15520313 | Symptomatic, drug refractory paroxysmal AFib | LA thrombi | 4–12/2001 (PVI and CTA) 4–12/2002 (PVI and CT+MIA) | nd (use implied) | Structural heart disease 24%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality
Jais 2004 France 15520313 | nd | PV isolation Cavotricuspid ablation Mitral isthmus ablation | 100 | 100 | 55 | 87 | 6 | nd | 4.6 | 71 | C
PV isolation Cavotricuspid ablation | 100

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Jais 2004 France 15520313 | Yes | Endpoint: Isolation of all PVs was systematically performed. | WACA Cavotricuspid isthmus ablation Mitral isthmus ablation (endocardial and epicardial within CS) | No | 4 mm irrigated (Celsius ThermoCool) | PV: 20–30 CTI: 50 MIA: 40–60 (42*) | 50° | 65
WACA (PVI) CTIA | nd

* Initially 40–60. Reduced for safety reasons. See AE results.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Jais 2004 France 15520313 | Recurrence of atrial arrhythmia | Not clearly defined | PV isolation Cavotricuspid ablation Mitral isthmus ablation | 12 mo (implied) | 32 | 100 | | | .02
| | | PV isolation Cavotricuspid ablation | | 49 | 100
| Arrhythmia-free w/o AAD (including post-2^nd^ or more procedure) | | PV isolation Cavotricuspid ablation Mitral isthmus ablation | 12 mo | 87 | 100 | | | .002
| | | PV isolation Cavotricuspid ablation | | 69 | 100

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Screening done, but unclear if outcome includes ASx Afib
Was a blanking period (time when AFib episodes were not recorded) used? | nd | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

In patients with recurrent arrhythmia (unclear if mitral isthmus cohort alone or both cohorts), 36% had structural heart disease compared to 20% of those without recurrent arrhythmia (P=.02)

Multivariate analysis:

Only mitral isthmus ablation was associated with success without drugs: RR (AFib recurrence) 0.2 (0.1–0.4) P<.001

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Jais 2004 France 15520313 | PV isolation Cavotricuspid ablation Mitral isthmus ablation | 12 mo | 0/136 (100+36 redo) | 4/100* | | | | | Thromboembolic | 0/136
Coronary artery | 0/136
| PV isolation Cavotricuspid ablation | nd

* 1 during CT isthmus ablation at 48 W

2 during endocardial RF delivery at the mitral isthmus at >50 W => In the last 25 patients power limited to 42 W.

1 attributed to catheter manipulation in the LA during mitral isthmus ablation

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Jais 2004 France 15520313 | No | NA | NA | 0% | No | NA | Yes | Unclear (multivariate analysis performed) | No | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes (partly) | Yes, but unclear how used | No
Explanation for Overall Quality Grade: | | | | Incomplete reporting of comparator cohort Structural heart disease analysis: unclear who analyzed Unclear if recurrence included asymptomatic AFib ND blanking period

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Jais 2004 France 15520313
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Jais 2004 France 15520313

Jais 2008 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Jais 2008 France, US, & Canada 19029470 | y | | | | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Jais 2008 France, US, & Canada 19029470 | >18 y Symptomatic paroxysmal AF >/=6 mon | - Contraindication to >2 AADs in different classes; - Contraindication to oral anticoagulants; - Contraindication to the discontinuation of oral anticoagulation; - Intracardiac thrombus; - AF from a potentially reversible cause; - pregnancy | nd | none | - Up to 3 attempts to achieve freedom from arrhythmia (i.e., up to 2 repeat ablations) for RFA arm (n=23, 43%) and up to 4 attempts (i.e., up to 3 attempts for the modification of pharmacologic therapy such as altering drugs) for medical arm were allowed until 90 days from randomization (treatment stabilization period).; - At the time of treatment failure during the follow-up period, crossover to the alternative therapy was allowed.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Jais 2008 France, US, & Canada 19029470 | Biosense Webster, St. Jude Medical, Bard, Medtronic, Biotronik, Canada Research Chair in Electrophysiology and Adult Congenital Heart Disease, Canadian Institute of Health Research, Fonds de Recherche enSante, Boston Scientific, CryoCath Technologies | RFA (cPVI) | 53 | 100 | 51 | 84 | 5.5 (median) | nd | 4.0 | 64 | B | Moderate
Medical | 59

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Jais 2008 France, US, & Canada 19029470 | y | 100% (LPVs), 98% (RSPV), 94% (RIPV) [nd] | Roof (17%) and Mitral isthmus lines(30%) (LA) Cavo-Tricuspid Isthmus line (64%) (RA) Targeted Foci (23%) (non-venous structure) | n | 3.5- or 5-mm irrigated tip | Up to 35 W | Up to 50 Celsius | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Jais 2008 France, US, & Canada 19029470 | Freedom from recurrent AF | Relapse of AF (at least 3 min by ECG or patients' report) beyond day 90 until 12 mon | RFA (cPVI) | 12 | 46 | 52 | 89% (KM) | - | <0.0001 (log-rank)
Medical | 13 | 55 | 23% (KM) | -
Jais 2008 France, US, & Canada 19029470 | Discontinuation of anticoagulation therapy | Discontinuation of anticoagulation therapy at 12 mon, (ITT analysis) | RFA (cPVI) | 12 | 31 | 52 | 60% | - | 0.02 (Fisher)
Medical | 18 | 53 | 34% | -

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Patients in RFA arm received a mean of 1.8 procedures (median 2, range 1–3), those in medical arm received a mean of 2.5 drugs.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Y (some no)
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 90 days

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Jais 2008 France, US, & Canada 19029470 | LAD | LAD at 12 mon (ITT analysis) | Cm | RFA (cPVI) | 12 | 53 | 4.0 | 3.9 | Nd | 0.92 (at 12 mon only)
Medical | 59 | 4.0 | 3.9
Jais 2008 France, US, & Canada 19029470 | LVED | LVED at 12 mon (ITT analysis) | Cm | RFA (cPVI) | 12 | 53 | 5.2 | 5.0 | Nd | 0.35 (at 12 mon only)
Medical | 59 | 5.1 | 5.1
Jais 2008 France, US, & Canada | LVEF | LVEF at 12 mon (ITT analysis) | % | RFA (cPVI) | 12 | 53 | 63 | 65 | nd | 0.99 (at 12 mon only)
Medical | 59 | 66 | 65
Jais 2008 France, US, & Canada 19029470 | QOL | SF36 physical component summary (ITT analysis) | Score | RFA (cPVI) | 12 | 53 | 44.8 | 52.0 | 7.2 | 0.01 (at 12 mon only) 0.015 (net diff (GLM))
Medical | 59 | 43.0 | 48.9 | 6.0
Jais 2008 France, US, & Canada 19029470 | QOL | SF36 mental component summary (ITT analysis) | score | RFA (cPVI) | 12 | 53 | 46.1 | 56.6 | 9.7 | 0.01 (at 12 mon only) 0.09 (net diff (GLM))
Medical | 59 | 44.0 | 51.9 | 9.1

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Jais 2008 France, US, & Canada 19029470 | RFA (cPVI) | 12 | 1/155 (0.6%)stent | 2/155 (1%) | 0/155 (0/53) | 0/155 | 0/155 | 0/155
Medical | 12 | | | 0/59

Unit of analysis was “procedure’, not patient (n=53)

2 hypothyroidism and 2 death (not related with treatment) in ADD arm

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Jais 2008 France, US, & Canada 19029470 | y | nd | nd | y | nd | y | y | n | n | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | n | y | N
Explanation for Overall Quality Grade: | | | | Poor reporting → unclear methodology. Why 1 patient in RFA arm not evaluated? (discrepancy) outcome assessment after repeat procedure (43%)

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Jais 2008 France, US, & Canada 19029470 | | Moderate
Explanation for Applicability Grade: | | Only symptomatic paroxysmal AF

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Jais 2008 France, US, & Canada 19029470 | Multiple repeat ablation was allowed during stabilization period → may have resulted in better FFS in AF compared to other RCTs Would it be OK to include this study into meta-analyze this?

Kanj Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Kanj, 2007 USA and Italy 17433955 | X | | | | Circumferential PV and additional lines ablation, comparison among three different catheter-tip-related strategies | TT/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Kanj, 2007 USA and Italy 17433955 | 18–80 y Symptomatic AFib Failed at least one anti-arrhythmic | Previous PVI Previous esophageal or swallowing disorders | nd | 2 mo (sotalol and dofetilide) | PVAI (pulmonary vein antrum isolation (ablation outside of PV ostia as WACA/LACA with PVI as endpoint)) was performed.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Kanj, 2007 USA and Italy 17433955 | nd | PVAI, 8 mm | 59 | nd | 60 | 81 | 6 | nd | 4.2 | 54 | B | Moderate
Kanj, 2007 USA and Italy 17433955 | nd | PVAI, Irrigation 30–50 W | 61 | nd | 60 | 81 | 6 | nd | 4.2 | 54 | B | Moderate
PVAI, Irrigation 10–35 W | 60

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Kanj, 2007 USA and Italy 17433955 | Yes | 100 [No PV potentials along the antrum or inside the PV (Biosense LASSO), and dissociation of the PV from the LA] | RA-SVC junction ablation if no phrenic nerve capture during high-output pacing | No | 8 mm conventional (Celsius) | 30–70 | 55 | nd
Kanj, 2007 USA and Italy 17433955 | Yes | 100 [No PV potentials along the antrum or inside the PV (Biosense LASSO), and dissociation of the PV from the LA] | RA-SVC junction ablation if no phrenic nerve capture during high-output pacing | No | 3.5 mm Open irrigation (Thermo-Cool) | 30–50 | 45 | nd
10–35 | 45 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Kanj, 2007 USA and Italy 17433955 | Freedom from atrial arrhythmia | Any atrial arrhythmias by event recorder or implanted device after the discontinuation of AADs (2 mo period from the procedure) until 6 mos | PVAI, 8 mm | 6 | 46 | 59 | 79% | nd | 0.043 (Chi-squared) | nd | nd | nd
Kanj, 2007 USA and Italy 17433955 | Freedom from atrial arrhythmia | Any atrial arrhythmias by event recorder or implanted device after the discontinuation of AADs (2 mo period from the procedure) until 6 mos | PVAI, Irrigation 30–50 W | 6 | 50 | 61 | 82% | nd | 0.043 (Chi-squared) | nd | nd | nd
PVAI, Irrigation 10–35 W | 41 | 60 | 68%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes*
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 2 mo**

* Event record monitoring for at least 6 mo

** Patients with recurrent AFib during the 2 mo period were cardioverted

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Kanj, 2007 USA and Italy 17433955 | PVAI+ RA-SVC junction, 8 mm | 0/59 | 0/59 | TIA, 1/59 (2%) | Perforation, 0/59 Odynophagia or dysphagia, 3/59 (5%) | 0/59 | 0/59 | nd | nd
Kanj, 2007 USA and Italy 17433955 | PVAI+ RA-SVC junction, Irrigation 30–50 W | 0/61 | 2/61 (3%) | 0/61 | Perforation, 0/60 Odynophagia or dysphagia, 11/61 (18%) | 0/61 | 0/61 | Pulmonary edema | 2/61 (3%)
PVAI+ RA-SVC junction, Irrigation 10–35 W | 0/60 | 0/60 | 0/60 | Perforation, 0/60 Odynophagia or dysphagia, 2/60 (3%) | 0/60 | 0/60 | nd | nd

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Kanj, 2007 USA and Italy 17433955 | Yes | Yes | nd | 0% | nd | Yes/ nd | Yes | nd | No | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | nd** | Yes*** | No*
Explanation for Overall Quality Grade: | | | | Some important methodological components of RCT are not reported/adopted.

* observational study cannot be an A, retrospective study is always a C

** No report of re-procedure infers “yes”

*** Event record monitoring for at least 6 mo.

**** Descriptions in the Method section infers 100% compliance.

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Kanj, 2007 USA and Italy 17433955 | | X
Explanation for Applicability Grade: | | Inclusion criteria of patient are somewhat vague (refractory to only class I/III vs. digitalis, beta-blocker, or calcium-blocker also included?).

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Kanj, 2007 USA and Italy 17433955 | - Few descriptions on how they implemented the RCT and analyzed the data.; - The defined end point is “soft” but clearly defined (compliance not reported, though).; - No dropouts until 6 mo should be intention-to-treatment analysis and non-time-to-event type analysis should be fine.; - Minor discrepancy (typo): Freedom from any arrhythmia of 78% in text but 79% in Figure 2; - Unclear definition about “symptomatic AF” in inclusion criteria; - All patients developing new odynophagia or dysphagia underwent chest CT, and upper GI endoscopy if the scan was normal.

Karch Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Karch 2005 Germany 15927974 | X | | | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Karch 2005 Germany 15927974 | Drug refractory AFib ≥2×/mo | Intracardiac thrombi, EF<35%, recent MI or cardiac surgery, previous ablation | Mar 2002–Dec 2003 | No | A reablation procedure, with the use of the same technique as the first ablation, was offered to the patient in case of a symptomatic atrial fibrillation recurrence beyond the third month after the ablation procedure. Structural heart disease 57%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Karch 2005 Germany 15927974 | Govt etc. | Circumferential RFA | 50 | 89 | 60 | 64 | 4.5 | nd | 4.7 | 63% | B
Segmental RFA | 50

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Karch 2005 Germany 15927974 | Yes | Complete isolation not a target of procedure | WACA Line: L lower PV to MV annulus (mitral line) | No | 8 mm (Navistar), 40 patients | max 50–70 | 55° | 72
Karch 2005 Germany 15927974 | Yes | and/or cooled 4 mm (Navistar thermocouple), 22 patients (ThermoCool - external irrigation) | max 35–50 | No | 48°
Goal: effective electric isolation | Segmental | Irrigated (Celsius, Thermo-Cool) external irrigation | max 30–35 | 48° | 52

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Karch 2005 Germany 15927974 | Freedom from atrial tachyarrhythmia (including pts w/2nd procedure) | >30 sec on 7 day Holter at 6 mo | Circumferential | 6 mo | 21 | 50 | | | .02
| | | Segmental | | 33 | 50
| Freedom from atrial tachyarrhythmia (excluding pts w/2nd procedure) | (Success post 1 procedure) | Circumferential | 6 mo | 17 | 50
| | | Segmental | | 27 | 50
| Free of arrhythmia symptoms during 1–6 mo period | | Circumferential | 6 mo | 27 | 50 | | | <.01
| | | Segmental | | 41 | 50
| Reablation procedure | due to symptoms | Circumferential | 3–6 mo | 12 | 50 | | | NS
| | | Segmental | | 8 | 50

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 1 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Karch 2005 Germany 15927974 | Circumferential | | (>50%, Asymptomatic) 3/50 (6%) (3 PVs) | 0/50 | TIA 2/50 CVA 1/50 | | | | Pericardial effusion (mild, 3–8 mm) | 22/50
| Segmental | | 6/50 (12%) NS (7 PVs) | 0/50 NS | TIA 1/50 CVA 0/50 NS | | | | P<.01 | 5/50

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Karch 2005 Germany 15927974 | Yes | Yes | Yes | Yes (0%) | Yes | Yes | Yes | NA | Yes
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Katritsis Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Katritsis 2008 Greece 18363086 | | x | | x | KQ2, 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Katritsis 2008 Greece 18363086 | PAF, no reablation in 1 y | repeat ablation for AF recurrence, AFL, or focal tachycardia | | amiodarone for 6 wk

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Katritsis 2008 Greece 18363086 | nd | ostial or antral PVI or WACA | 90 | 100 | 55 | 83 | nd | nd | 4.1 | nd | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Katritsis 2008 Greece 18363086 | y | 100% (implied) Segmental ostial/antral : abolition /dissociation of distal PVs, entrance/exit block | WACA | n | 4 mm (ostial or antral) | 40 | 52 | 25.9
irrigated 4 mm (WACA) | 30 | 46 | 25.1

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Katritsis 2008 Greece 18363086 | Freedom from AF | symptom improvement; no EKG or Holter evidence of AF | ostial or antral PVI | 12 mo | 25 | 41 | 61%
| | | WACA | | 33 | 49 | 67% | | 0.5

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 6 wk

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
ablation time < median | Katritsis 2008 Greece 18363086 | Freedom from AF | symptom improvement; no EKG or Holter evidence of AF after 1 ablation (AAD?) | ostial or antral PVI or WACA | 12 mo | | | 49%
ablation time ≥ median | | | | | | | | 80% | | 0.002
Freedom from AF | Katritsis 2008 Greece 18363086 | ablation time | | ostial or antral PVI or WACA | 12 mo | | | 27.2 min
AF recurrence | | | | | | | | 22.3 min | | <0.001

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Katritsis 2008 Greece 18363086 | ostial or antral PVI or WACA | 12 mo | 0/90 | 2/90 (2.2%) | | 0/90

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Katritsis 2008 Greece 18363086 | n | NA | NA | nd | y | n | y | y | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | y | y | n
Explanation for Overall Quality Grade: | | | | retrospective; small sample size; unclear if a proportion of pts were on AADs at time of follow up

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Katritsis 2008 Greece 18363086 | Cox proportional hazard model showed that for one minute increase in radiofrequency energy delivery there was a 16% reduction in the risk for recurrence of AF (HR=0.84, 95% CI: 0.77–0.90, p<0.001). This inverse relationship between radiofrequency energy delivery time and recurrence of AF remained (HR: 0.80, 95% CI: 0.72–0.87, p<0.001), even after adjustment for potential confounders such as age, sex, cause of AF, left atrial size and type of ablation technique (ostial-antral or circumferential).

Kettering Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Kettering 2008 Germany 18507536 | | X | | X | KQ3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Kettering 2008 Germany 18507536 | symptomatic PAF; failed 1 attempt at AAD | valve disease or CAD req'd surgery; left atrial thrombus; hyperthyroidism; Cr ≥ 2.0 mg/dL; severe concomitant illness | consecutive patients, but Group A (2004-2006), Group B (2005-2007) | No AAD except for amiodarone | Compared to historical cohort; 2^nd^ procedure for 5% of the patients; 12% of patients on amiodarone during followup

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Kettering 2008 Germany 18507536 | nd | Group A: segmental PVI Group B: segmental PVI excluding sites if there were areas in close proximity to esophagus | Group A: 21; Group B: 22 | 100% | Group A: 59; Group B: 65 | Group A: 76; Group B: 55 | nd | nd | nd | Group A: 60; Group B: 59 | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Kettering 2008 Germany 18507536 | y | Group A: 67%; Group B: 55% (either no or dissociated PV potentials) | | n | 3.5 mm irrigated tip | 20–40 | 43

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Kettering 2008 Germany 18507536 | Freedom from AF recurrence | | segmental PVI | 6 mo | 17 | 21 | 81%
| | | segmental PVI with exclusion of sites if there were areas adjacent to esophagus | 6 mo | 18 | 22 | 82% | | 1.0
| | | 16/22 (73%) patients in group B: ablation strategy was modified significantly due to close proximity of PV to esophagus.

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 1 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
No modification of segmental PVI | Kettering 2008 Germany 18507536 | Freedom from AF recurrence | | No modification of segmental PVI | 6 mo | 23 | 27 | 85%
Modification of segmental PVI due to close proximity of PV to esophagus | | | | Modification of segmental PVI due to close proximity of PV to esophagus | 6 mo | 12 | 16 | 75% | | 0.69

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Kettering 2008 Germany 18507536 | | | significant (≥50%) - zero events in both groups; moderate (<50%?) - 3/43

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Kettering 2008 Germany 18507536 | n | NA | NA | NA | nd | y | y | n | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | n | n | y | NA
Explanation for Overall Quality Grade: | | | | enrollment dates are different between the 2 groups; 2 groups may not be comparable

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Khaykin Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Khaykin 2004 US 15851113 | | | | X | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Khaykin 2004 US 15851113 | AFib | LV dysfunction alone (without valve disease or history of prior cardiac surgery) | 12/2000–12/2002 | | 50% structural heart disease 26% with MV or AV disease 10% prior cardiac surgery

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Khaykin 2004 US 15851113 | nd | PV antrum isolation | 391 | 48% | 56 | 78% | ~7 | 24% LV dysfunction (EF<40%) | nd | nd | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Khaykin 2004 US 15851113 | Yes | The goal of PV antrum isolation was abolition of all PV potentials as measured by circular mapping catheter. | WACA No lines | No | Cooled tip (EP Technologies) (Chilli - internal irrigation) | nd | First 160: 35° Rest per microbubbles | 9.5 per PV

RESULTS (dichotomized or categorical outcomes)*

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Khaykin 2004 US 15851113 | AFib recurrence | Incl asymptomatic ≥10 sec on Holter | PVI | 10–18 mo (per subgroup) | 54 | 336
| Controlled on AAD | (subset of AFib recurrence) | PVI | 10–18 mo (per subgroup) | 12 | 336
| 2^nd^ PVI performed | (subset of AFib recurrence) | PVI | 10–18 mo (per subgroup) | 42 | 336
| On AAD post 2^nd^ procedure | | PVI | 10–18 mo (per subgroup) | 2 | 42

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

* Also results data, subgroup data, and complications data for subgroups who had PVI with “no-bubbles” technique (n=144) and “bubbles” technique (n=192).

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | No (not stated) | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Lone AFib without LV dysfunction | Khaykin 2004 US 15851113 | AFib recurrence | Incl asymptomatic ≥10 sec on Holter | PVI | 18 | 31 | 194
Valve disease (±LV dysfunction) | | | | | 11 | 17 | 102
Prior cardiac surgery (±LV dysfunction) | | | | | 10 | 6 | 40
Lone AFib without LV dysfunction | | Controlled on AAD | (subset of AFib recurrence) | PVI | 18 | 4 | 194
Valve disease (±LV dysfunction) | | | | | 11 | 5 | 102
Prior cardiac surgery (±LV dysfunction) | | | | | 10 | 3 | 40
Lone AFib without LV dysfunction | | 2nd PVI performed | (subset of AFib recurrence) | PVI | 18 | 27 | 194
Valve disease (±LV dysfunction) | | | | | 11 | 12 | 102
Prior cardiac surgery (±LV dysfunction) | | | | | 10 | 3 | 40
Lone AFib without LV dysfunction | | On AAD post 2nd procedure | | | 18 | 0 | 27
Valve disease (±LV dysfunction) | | | | | 11 | 2 | 12
Prior cardiac surgery (±LV dysfunction) | | | | | 10 | 0 | 3

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Khaykin 2004 US 15851113 | PVI | | 3/336 (0.9%) [≥70%, regardless of symptoms] | 4/336 (1.1%) | 1/336 (0.3%) [TIA 1/336 (0.3%)]

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Khaykin 2004 US 15851113 | No | NA | NA | Unclear (numbers don't add up) | No | No | Poorly reported | No (beyond subgroups) | No (unclear reporting) | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | Retrospective, with problems.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Kilicaslan 2005 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Kilicaslan 2005 US 15734612 | | x | | x | PVI in pts with previous cardiac surgery vs. without; KQ 2, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Kilicaslan 2005 US 15734612 | Pts who had PVI | hx of AFL ablation; concomitant AFL ablation + PVI; intracardiac thrombi | 2000-2003 | 2 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Kilicaslan 2005 US 15734612 | nd | PVI in pts with previous cardiac surgery | 63 | 54 | 57 | 81 | 6.9 | | 4.7 | 49 | C | moderate
PVI in pts without previous cardiac surgery | 1062 | 57 | 55 | 80 | 6.6 | | 4.4 | 54

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Kilicaslan 2005 US 15734612 | y | 100% [PV potentials surrounding the antrum were abolished.] | SVC also isolated Atrial flutter RFA (?# of pts) | n | 8 mm | ND (Marrouche 2003 did not report settings for 8 mm) | ND | ND

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Kilicaslan 2005 US 15734612 | recurrence | recurrence of AF | PVI in pts with previous cardiac surgery | 17 | 13 | 63 | 21%
| | | PVI in pts without previous cardiac surgery | 18.3 | 201 | 1062 | 19% | | 0.31
| | recurrence of AFL after 2 mo | PVI in pts with previous cardiac surgery | | 21 | 63 | 33%
| | | PVI in pts without previous cardiac surgery | | 43 | 1062 | 4% | | <0.0001

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 8 wk

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Kilicaslan 2005 US 15734612 | PVI in pts with previous cardiac surgery
| PVI in pts without previous cardiac surgery | | moderate or severe, 4/1062 (0.4%) | | 7/1062 (0.7%) | | | | pericardial effusion | 2/1062 (0.2%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Kilicaslan 2005 US 15734612 | n | NA | nd | NA | n | n | y | n | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | n | n | n | y | NA
Explanation for Overall Quality Grade: | | | | 2 groups not totally comparable at baseline: larger LAD, lower LVEF, higher incidence of AFL before PVI, in pts with previous history of cardiac surgery

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Kilicaslan 2005 US 15734612 | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Kilicaslan 2006 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Kilicaslan 2006 US 16684021 | | X | | | microbubble titrated PVI vs. standard power limited PVI; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Kilicaslan 2006 US 16684021 | symptomatic, drug-refractory AF | intracardiac thrombi or spontaneous echo contrast; preexisting neurological deficits | | | only adverse events extracted; no clinical outcomes >6 mo reported; non-concurrent comparison

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Kilicaslan 2006 US 16684021 | nd | microbubble guided RFA | 107 | 50 | 58 | 86 | 7.7 | | 4.3 | 55 | not rated
power limited RFA | 95 | 52 | 56 | 80 | 7.6 | | 4.2 | 54

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Kilicaslan 2006 US 16684021 | y | 100% [all PV potentials surrounding the vein were abolished] | PVAI using ICE guidance; SVC was also isolated (microbubble guided in group 1; power limited in group 2) | n | 8 mm | 30–70 | 55 | nd
45–50 | 55 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Kilicaslan 2006 US 16684021 | microbubble guided RFA | | | | 1/107 (0.9%)
| power limited RFA | | | | 3/95 (3.1%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Kilicaslan 2006 US 16684021 | n | NA | nd | NA | n | n | y | n | y | NR
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | n | n | n | NA
Explanation for Overall Quality Grade: | | | | non-concurrent comparison

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Kilicaslan 2006 US 16684021 | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Kistler 2006 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Kistler, 2006 UK 16989651 | | | x | | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Kistler, 2006 UK 16989651 | Patients who underwent first catheter ablation for AF. All patients had symptomatic documented AF and had failed >2 AAD. | None | December 2003 to September 2005 | None | Structural heart disease 19%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Kistler, 2006 UK 16989651 | Government, private, and industry | Wide encirclement PVI → Left atrial circumferential ablation → linear ablation (roof line and/or mitral line) and/or targeting of fractionated electrograms → cavotricuspid isthmus ablation RFA was guided by either 3D mapping or 3D mapping (CARTO or NavX system) with CT integration (Cartomerge™) | 94 | 49 | 56 | 80 | 6 | nd | 4.4 | nd | B | Wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Kistler, 2006 UK 16989651 | YES | Right PVs: 95% Left PVs: 96% [no PV potential was detected] PVs were continuously assessed for EI using the circular mapping catheter. | Left atrial circumferential ablation (LACA) to all patients. If LACA is not successful, then further ablation was performed at the venoatrial junction. If AF continued following PVI, a combination of the following was performed: (1) roof line, (2) mitral isthmus line, and (3) complex fractionated electrograms - left and right atria were mapped systematically for fractionated potentials which were then targeted for ablation. If AF still continued, a cavotricuspid isthmus ablation was performed in all patients requiring internal cardioversion and where typical atrial flutter had been previously documented. Paroxysmal AF (n=46): 50% had cavotricuspid isthmus ablation Persistent/permanent AF (n=48): 89.5% had additional ablation (a combination of linear ablation at the LA roof, mitral isthmus, and cavotricuspid isthmus) | no | 3.5 mm irrigated tip | LACA: 30 CTI: 50 | LACA: 50 CTI: 60 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes (clinical outcome was assessed on 7 day Holter monitor at 6 month)
Was a blanking period (time when AFib episodes were not recorded) used? | no | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
3D mapping | Kistler, 2006 UK 16989651 | Sinus rhythm | Freedom from AT/AF off antiarrhythmic medication | Wide encirclement PVI → Left atrial circumferential ablation → linear ablation (roof line and/or mitral line) and/or targeting of fractionated electrograms → cavotricuspid isthmus ablation | 6.25 | 28 | 47 | | | <.05
3D mapping with CT integration | 6 | 39 | 47

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Kistler, 2006 UK 16989651 | Wide encirclement PVI → Left atrial circumferential ablation → linear ablation (roof line and/or mitral line) and/or targeting of fractionated electrograms → cavotricuspid isthmus ablation | | | | | | | | Pericardial effusions | 2/94 (2%)*
| | | | | | | | | Intraoperative transient ischemic attack | 1/94 (1%)**

* Both in 3D mapping group

** in the CT group

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Kistler, 2006 UK 16989651 | no | NA | NA | 0 | nd | Yes (0% dropout) | yes | no | yes | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | no | yes | no | yes | No
Explanation for Overall Quality Grade: | | | | Non-RCT. total ablation time was not reported. Not sure if the two groups of patients were comparable although all reported characteristics did not statistically significantly different.

* observational study cannot be an A, retrospective study is always a C

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Kistler, 2006 UK 16989651 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Kistler, 2006 UK 16989651 | This study aimed to compare 3D Mapping to CT integration. The ablation procedures were not exactly the same between the groups although there was no statistical significant difference between groups. Among patients with recurrences, repeat procedures were performed in 30 patients (18 in the 3D mapping group and 12 in the CT group, p=0.2) and not in 11 (controlled on medication in 7, asymptomatic in 3, and death during follow-up in 1)

Kistler 2007 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Kistler, 2007 UK 17916142 | | | x | | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Kistler, 2007 UK 17916142 | Consecutive patients who underwent their first catheter ablation for AF. All patients had symptomatic documented AF and had failed or been intolerant of >1 antiarrhythmic drug. | None | 2005 to 2006 | None | 21% structural heart disease

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Kistler, 2007 UK 17916142 | Government and private | Left atrial circumferential ablation; additional progressive linear ablation (12%) and further cardioversion (26%) | 101 | 62 | 56 | 71 | 5.7 | nd | 4.6 | nd | (AE data only) | wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Kistler, 2007 UK 17916142 | YES | Right superior PV: 100% Right inferior PV: 98% Left superior PV: 100% Left inferior PV: 100% [no PV potential was detected] PVs were continuously assessed for EI using the circular mapping catheter. | Left atrial circumferential ablation (LACA) for all patients. For 38 patients who remained in AF following completion of PVI, further ablation was performed: 12 patients received progressive AF organization (roof line and coronary sinus line; ablation within the CS if CS disconnection was not achieved) and 26 patients received cardioversion (cavotricuspid isthmus ablation) due to AF continued following linear ablation and targeting of fractionated electrograms. LACA for all 38 pts: roof line, CS line, CS RFA, CFAEs 12 pts: AT RFA 26 pts: CV and CTI RFA 25 (of 63 pts) in PAF group (i.e. separate from the above persistent group): CTI RFA | no | 3.5 mm irrigated tip | LACA: 30 Cardioversion: 50 | LACA: 50 Cardioversion: 50 | 206

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Kistler, 2007 UK 17916142 | Left atrial circumferential ablation; additional progressive linear ablation (12%) and further cardioversion (26%) | nd | | | | | | | Pericardial effusions* | 2/101

* one requiring pericardiocentesis and one transient ischemic attack

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Kistler, 2007 UK 17916142 | n | NA | NA | 0% | nd | Yes (0% dropout) | NA | NA | yes
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
| | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Kistler, 2007 UK 17916142 | No long-term outcomes; adverse events only. A total of 5 operators and “there were no systematic differences in the approach to ablation between operators”.

Kistler 2008 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Kistler 2008 UK 18931059 | X | | | | KQ3b | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Kistler 2008 UK 18931059 | symptomatic AF; failed ≥2 AADs | previous AF ablation | 2006 | none

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Kistler 2008 UK 18931059 | World Congress of Cardiology | WACA ± CT integration | 80 | 59 | 56 | nd | 6.3 | nd | nd | nd | B

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Kistler 2008 UK 18931059 | y | 94% (electrical disconnection assessed by circular mapping) | WACA (encircle L and R PV in pairs); if AF continued, then a combination of the following: a) roof line; CS line, CS ablation; or AT activation map b) target CFAE; c) internal conversion with CTI ablation; also CTI in AFL pts | n | 3.5 mm irrigated (Navistar Thermocool, Biosense Webster) | 30 | 50 | N/A

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Kistler 2008 UK 18931059 | Primary: freedom from AF or atrial tachycardia | no AF or atrial tachycardia >30 s after a 4 wk blanking period, no AAD, single procedure | WACA without CT integration | 6 mo | 22 | 39 | 56% | | 0.65
| | | WACA with CT integration | | 19 | 38 | 50%
| Secondary: recurrent AF or atrial tachycardia | | WACA without CT integration | 12 mo | 20 | 39 | 51% | | 0.65
| | | WACA with CT integration | | 22 | 38 | 58%
| reablation | | WACA without CT integration | 12 mo | 14 | 39 | 36% | | 0.64
| | | WACA with CT integration | | 16 | 38 | 42%
| Secondary: sinus rhythm, no AADs | | WACA without CT integration | 13.6 mo | 30 | 39 | 77% | | 0.61
| | | WACA with CT integration | | 27 | 38 | 71%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 4 wk

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Kistler 2008 UK 18931059 | WACA without CT integration | | 1/40 (2.5%)
| WACA with CT integration | | | 2/39 (5.1%) | | | | | death (unrelated) 1/39 (2.6%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Kistler 2008 UK 18931059 | y | nd | nd | y | y | n | y | NA | y | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | y | y | y
Explanation for Overall Quality Grade: | | | | small number of subjects; no power calculation

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Kottkamp 2004 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Kottkamp 2004 15312874; Hindricks 2005 Germany 16009793 | | | x | | | EB/SI/AG

Some results and data come from Kottkamp, 2004 15312874

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Hindricks 2005 Germany 16009793 | AF >18 mo; failed ≥1 AAD; 3 documented AF episodes with symptoms | none reported | nd | Amiodarone or flecainide for 3 months | only compared to pts with documented AF in a continuous 7-day ECG monitoring before RFA; 9% of pts had prior RFA

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Hindricks 2005 Germany 16009793 | Biosense Webster (unrestricted educational grant) Swiss National Research Foundation (1 author) [From Kottkamp 2004 810] | circumferential + lines | 114 | 84 | 54 | 71 | 5 (median) | | 4.0 | 62 | B (Hindricks data) C (Kottkamp data)

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Hindricks 2005 Germany 16009793 | Not required | Not goal, implied Demonstrated in <20% [Pacing within the circles with CARTO] (from Kottkamp, n=100) | Circumferential lesions around the L and R PVs. Linear lesion connecting the circular lesions (roof line) Linear lesion connecting the Left circular lesion with the mitral annulus (L atrial isthmus) R isthmus ablation 9% who had atrial flutter | No | 8 mm (Navistar) | 60 W max | 60° target | 33 min

The endpoint of the procedure was the completion of the proposed circular and linear lesions.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Kottkamp, 2004 Germany 15312874 | Repeat procedure | for documented symptomatic AFib recurrences | RFA | Done at mean 7 mo | 22* | 100
| Secondary atrial flutter procedure | for stable gap-related LA flutter | RFA | nd | 5 (additional to 22 AFib repeats) | 100
| Thromboembolic event | | | 12 | 0 | 100
| Freedom from AFib | on 7-day ECG† | | 6 mo | 52% 53% on AAD | 100?
| | | | 12 mo | 63% | 100?
| Use of Antiarrhythmic drug† | Flecainide or amiodarone | | 6 mo | 53% | 100?
| | | | 12 mo | 40% | 100?

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

* 1 patient had a 3rd procedure.

“In 8 patients (8%) with documented typical atrial flutter, RA isthmus ablation was performed during follow-up.”

† Also data from 24 hour ECGs (lower rates of AFib detected). And data from 3 months, prior to ablation, post ablation.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes (recurrence data is at specific timepoints, not cumulative) | If yes, how long was it? | Up to timepoint

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Hindricks 2005 Germany 16009793 | | asymptomatic AF | | | baseline** | 92 | 5 | | | 0.021
| 6 mo | 54 | | 20
| | asymptomatic AF | | | baseline | 92 | 5 | | | 0.05
| 12 mo | 25 | | 9
| | symptomatic AF | | | baseline | 92 | 35 | | | 0.078
| | | | | 6 mo | 54 | | 14
| | symptomatic AF | | | baseline | 92 | 5 | | | 0.07
| | | | | 12 mo | 25 | | 5
| | symptomatic + asymptomatic AF | | | baseline | 52 | 92 | | | 0.001
| | | | | 6 mo | 54 | | 20
| | symptomatic + asymptomatic AF | | | baseline | 52 | 92 | | | 0.001
| | | | | 12 mo | 25 | | 11

** only compared to pts with documented AF in a continuous 7-day ECG monitoring before RFA

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
| Hindricks 2005 Germany 16009793 | There were no significant differences in patients with different AF perception with respect to age, sex, LVEF, LAD, LA appendage flow velocity, and AF duration.

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Paroxysmal | Kottkamp, 2004 Germany 15312874 | Oral anticoagulation | | | 3 mo | 77 | 80? (implied)
| | | | | 6 mo | 67 | 80?
| | | | | 12 mo | 59 | 80?
Persistent | | | | | 3 mo | nd
| | | | | 6 mo | 66% | 20?
| | | | | 12 mo | 66% | 20?
Paroxysmal | | Freedom from AFib | on 7-day ECG† | | 6 mo | 55% 49% on AAD | 80?
| | | | | 12 mo | 74% 42% on AAD | 80?
Persistent | | | | | 6 mo | 38% 67% on AAD | 20?
| | | | | 12 mo | 22% 33% on AAD | 20?
Paroxysmal | | Use of AAD | † | | 6 mo | 49% | 80?
| | | | | 12 mo | 42% | 80?
Persistent | | | | | 6 mo | 67% | 20?
| | | | | 12 mo | 33% | 20?

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Paroxysmal | Kottkamp, 2004 Germany 15312874 | AFib episode lasting >24 hr | Paroxysmal AFib existed at time of measurement | | | 12 mo | | 13/61 | 1/33 | | .02 (pre post)

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Kottkamp, 2004 Germany 15312874 | RFA | nd | 0/100 | | | | | | Major Bleeding (12 mo) | 0/100

No other procedure-related complications were observed.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Hindricks 2005 Germany 16009793 | n | NA | NA | y | NA (blinded to symptoms) | n | y | y | Yes (Hindricks) No (Kottkamp) | B (Hindricks data) C (Kottkamp data)
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | y | Yes (Kottkamp) | y | y
Explanation for Overall Quality Grade: | | | | cohort study; in Kottkamps: Unclear denominators throughout. Only %ages reported.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Hindricks 2005 Germany 16009793 | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Krittayaphong Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Krittayaphong, 2003 Thailand 12866763 | X | | | | Circumferential PV and additional lines ablation with transient concurrent antiarrhythmics vs. Only (continuous) antiarrhythmics | TT/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Krittayaphong, 2003 Thailand 12866763 | - M or F, 15–75 y; - Symptomatic (> 6 mo) paroxysmal or persistent AFib; - Refractory to at least 1 of class IA/IC, digitalis, beta-blocker, or Ca-blocker; - No prior amiodarone | - Transient AFib or treatable cause; - Bleeding disorder; - Thyroid disorder; - Previous stroke; - Other comorbidity with less than 1-year life expectancy; - Psychiatric disorder; - Valvular heart diseases; - Unwilling to participate | nd | 3 mo (amiodarone 200 mg qd without loading dose) | Amiodarone arm: Loading dose:; - 1200 mg qd (1 wk); - 600 mg qd (2 wks); Maintenance dose:; - 200 mg qd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Krittayaphong, 2003 Thailand 12866763 | Faculty of Medicine Siriraj Hospital | RFA (WACA) | 15 | 67 | 52 | 63 | 56 | nd | 3.9 | 63 | C | Narrow
Amiodarone | 15

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Krittayaphong, 2003 Thailand 12866763 | No | NA* | LA: WACA + mitral line RA: Cavotricuspid isthmus line, SVC-IVC, and mid RA horizontal line | No | 8 mm (Navistar) | nd | 55 | 212

* Only the assessment of the completeness of these lines was performed.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Krittayaphong, 2003 Thailand 12866763 | Freedom from AF | Probability of AF free at 1 year (AF not clearly defined) | RFA (WACA) | 12 | 11 | 14 | 79% | nd | 0.018 (Log-rank) | nd | nd | nd
Amiodarone | 6 | 15 | 40%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Relapse rates at 1 year were numerically reported in the paper but Freedom from RF was also presented in a K-M graph.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes*
Was a blanking period (time when AFib episodes were not recorded) used? | nd** | If yes, how long was it? | nd

* Regular ECG (at clinic?) and 24 h ECG at 1, 3, 6 mo

** No description on a blanking period; however, no relapse cases reported in the RFA arm of the Kaplan-Meier graph during the first three-month period.

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Krittayaphong, 2003 Thailand 12866763 | Quality of life | SF-36, general health score | Score | RFA (WACA) | 12 | 14 | 46 | 66 | | 0.048 (ANOVA)
Amiodarone | 12 | 15 | 41 | 43
Krittayaphong, 2003 Thailand 12866763 | Quality of life | SF-36, physical fitness score | Score | RFA (WACA) | 12 | 14 | 63 | 86 | | 0.691 (ANOVA)
Amiodarone | 12 | 15 | 71 | 68

Duplicate one row per outcome and per RFA intervention.

* Bar graph presented but no numerical data available.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Krittayaphong, 2003 Thailand 12866763 | RFA (WACA with anterior linear lesion and cavotricuspid line ablation) | 0/14 | 0/14 (0) | Cerebral infarction, 1/14 (7%) | 0/14 | Minor groin hematoma, 1/14 (7%) | Nd | Amiodarone-related* | 3/14 (21%)
Amiodarone | | | | | | nd | Amiodarone-related** | 7/15 (47%)

* Three patients had at least one adverse event during the first 3-month “concurrent” therapy period. Reports include GI adverse events (n=2), sinus node dysfunction (n=1), dizziness (n=1), and presyncope (n=1), meaning that some same patients might have had multiple adverse events. Grade/severity not provided.

** Seven patients had at least one adverse event. Reports include GI adverse events (n=6), corneal microdeposit (n=2), hypothyroidism (n=2), abnormal LFT (n=2), hyperthyroidism (n=1), and sinus node dysfunction (n=1), meaning that some same patients might have had multiple adverse events. Grade/severity not provided.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Krittayaphong, 2003 Thailand 12866763 | Yes | nd | nd | Yes (7%) | nd | No | Yes | nd | No | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | nd** | Nd*** | Yes**** | No*****
Explanation for Overall Quality Grade: | | | | Poor description of the conduct of RCT and no ITT analysis.

* observational study cannot be an A, retrospective study is always a C

** Not defined but reported as freedom from Afib only.

*** not clearly defined, but no reports on re-procedure infers “yes”

**** Regular ECG (at clinic?) and 24 h ECG at 1, 3, 6 mo

***** Method section infers 100% compliance.

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Krittayaphong, 2003 Thailand 12866763 | X
Explanation for Applicability Grade: | | N<30

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Krittayaphong, 2003 Thailand 12866763 | - Few/unclear descriptions on how they implemented the RCT and analyzed the data.; - Unclear about post procedure blanking period.; - No ITT analysis; they excluded a patient who failed the procedure of RFA from analysis; - Probably no blinded outcome assessment of the “soft” outcome with relatively scanty (1, 3, 6, 12 mo) follow-up timings (survival curve infers this).; - Only 15 per arm.; - Also included class I/III antiarrhythmic naïve patients (only failures of digi, beta-blocker, or Ca-blocker), meaning some of them (number not presented) underwent RFA almost as first line therapy, which might have affected the results.; - Cannot apply the results to those with valvular diseases. The same may be true in psychiatric population.

Lakkireddy Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Lakkireddy 2005 US 16360082 | | x | x | | Patients with pacemaker or ICD vs. patients without; KQ 2, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Lakkireddy 2005 US 16360082 | Symptomatic drug resistant AF | Left atrial clots | 2000-2003 | 8 wk | In group 1: 81% pacemakers and 19% defibrillators

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Lakkireddy 2005 US 16360082 | nd | RFA in pts with pacemaker or ICD | 86 | 58 | 60 | 70 | 2.6 | | 4.55 | 48.6 | C | moderate
RFA in pts without pacemaker or ICD | 86 | 60 | 60 | 70 | 3.8 | | 4.39 | 52.4

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Lakkireddy 2005 US 16360082 | y | | SVC also isolated in those with sharp high-frequency potentials without phrenic nerve pacing | | 8 mm or 4 mm cool-tip (Chilli internal irrigation) | 50 | 50

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Lakkireddy 2005 US 16360082 | success | Freedom from AF recurrence | RFA in pts with pacemaker or ICD | 12 mo | | | 81%
| | | RFA in pts without pacemaker or ICD | | | | 79% | | 0.73
| Weight in kg is the only significant independent predictor of cumulative recurrence (95%CI 1.013–1.055, P=0.002)

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 2 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Lakkireddy 2005 US 16360082 | RFA in pts with pacemaker or ICD | | Significant (>70%), 2% | | 1% | | | | Pulmonary edema | 1%
Lakkireddy 2005 US 16360082 | RFA in pts with pacemaker or ICD | | Significant (>70%), 2% | | 1% | | | | Symptomatic mode switch (pertains only to this group) | 12/86 (14%)
Asymptomatic mode switch | 2/86 (2.3%)
| RFA in pts without pacemaker or ICD | | Significant (>70%), 1% | | 1% | | | | Pulmonary edema | 0%

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Lakkireddy 2005 US 16360082 | N | NA | NA | Nd | N | N | Y | N | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | n | N | Y | n
Explanation for Overall Quality Grade: | | | | Baseline characteristics not totally comparable, higher DM and CAD rates in pts with pacemakers or ICD; followup rate unclear

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
| | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Lemola Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Lemola 2006 US 16843185 | | x | | | CPVA vs. Electrogram guided ablation (EGA); KQ 3 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Lemola 2006 US 16843185 | Paroxysmal or persistent AF | | nd | | CPVA pts overlaps with Oral 2003

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Lemola 2006 US 16843185 | government | CPVA | 42 | 57 | 57 | 83 | 7 | | 4.4 | 58 | C | moderate
EGA | 42 | 60 | 57 | 83 | 6 | | 4.2 | 56

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Lemola 2006 US 16843185 | n | | AF induced by rapid atrial pacing at onset in 38 pts in NSR. CPVA (including mitral line and roof line) Electrogram guided ablation (EGA) - focal ablation at sites of complex electrograms (CFAEs); linear ablation not performed, end point was termination of AF and non-inducibility | Yes in EGA | 8 mm | | | 42
| | 35

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Lemola 2006 US 16843185 | success | Freedom from symptomatic or asymptomatic AF, not on AADs, after a single ablation | CPVA | 9 mo | 28 | 42 | 67%
| | | EGA | | 30 | 42 | 71% | | 0.6

Duplicate one row per outcome and per RFA intervention

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 6 wk

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Lemola 2006 US 16843185

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Lemola 2006 US 16843185 | n | NA | Nd | Y | N | N | Y | N | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Y | Y | Y | Y | y
Explanation for Overall Quality Grade: | | | | Unclear how patients were selected into the respective groups

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Lemola 2006 US 16843185 | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Li Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Li 2008 China 18577822 | | | | x | | EB/AG

PROBABLE OVERLAP WITH OTHER STUDIES FROM BEIJING ANZHEN HOSPITAL (319, 275, 458, 603, 528)

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Li 2008 China 18577822 | Chronic AF | | | Amiodarone, propafenone, or sotalol for 2 months

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Li 2008 China 18577822 | Gov't | RFA | 92 | 0 | 59 | 76 | 5.6 | nd | 4.2 | 60 | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Li 2008 China 18577822 | Yes | Circumferential PV ablation (Goal - electrical isolation of all PVs) | CFAE targeting “critical isthmus” causing any Aflutter or macro-reentrant atrial tachycardia | No | nd | nd | nd | nd

RESULTS (dichotomized or categorical outcomes) No reporting of total # with recurrent AF, only among those with early recurrence

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Li 2008 China 18577822 | | | 0/92 | 0/92 | | 0/92

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported? | | | | C
Explanation for Overall Quality Grade: | | | | Poor, incomplete reporting throughout.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Estner 2006 Germany 16831837
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Liu 2005 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Liu, 2005 China 16336813 | | | X | | | EB/AG

Almost definite partial overlap with separately extracted Tang 2006 275, Ma 2006 458, Dong 2005 603.

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Liu, 2005 China 16336813 | Highly symptomatic AFib, multiple AAD, paroxysmal or persistent | none | 9/2004–6/2005 | Yes (1 mo) | 39% had HTN and structural heart disease

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Liu, 2005 China 16336813 | Government | Circumferential PV ablation | 130 | 70% | 58 | 73% | 7.1 yr | nd | 3.8 cm | 67% | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Liu, 2005 China 16336813 | Yes | 100% [nd] | (They used the term CPV...but is essentially equivalent to WACA except that PV isolation was explicitly specified as an endpoint) | No, from Methods (but they do mention induced AT in Results) | Irrigated 3.5 mm (ThermoCool) | 35 W max | 43° target | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Liu, 2005 China 16336813 | Persistent recurrent atrial tachyarrhythmia | After 2 months, atrial tachycardia alone, AFib alone, or AT and AFib. Derived from convoluted reporting. Text data used (different from Table) 52=ATa w/in 2 mo 22=spontaneous resolution of ATa | CPVA | Unclear. Mean resolution occurred at about 3 mo | 30 (52-22=30) | 130
| Repeat ablation | | | nd | 21 | 130
| Symptom free after 2^nd^ ablation | | | 6 | 116 | 130

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Initial yes. Post-2nd ablation no
Was a blanking period (time when AFib episodes were not recorded) used? | Yes (essentially) | If yes, how long was it? | 2 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Liu, 2005 China 16336813 | CPVA | | 1/130 (0.8%) (50% stenosis, asymptomatic) | 1/130 (0.8%) (not defined, no long term sequelae) | 1/130 (0.8%) (no long term sequelae)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Liu, 2005 China 16336813 | No | NA | NA | yes (0%) | nd | y | no (poor outcome chosen) | incomplete | No | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | Incompletely | Yes, though not used throughout | No
Explanation for Overall Quality Grade: | | | | Results poorly reported. Text does not match Table data (23 vs 25, 14 vs 19)

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Liu 2006a Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Liu 2006 China 17062959 | X | | | | stepwise PVI (SPVI) vs. CPVI; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Liu 2006 China 17062959 | 20–80 y; NYHA I or II; ≥9 mo followup; failed multiple AADs | LAD >55mm; LVEF <35%; prior AF ablation; contraindication to anticoagulation; presence of LA thrombus | nd | 2 mo | included only patients with ≥9 mo followup; excluded initial 50 cases (to avoid learning curve bias); first time ablation

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Liu 2006 China 17062959 | government | stepwise PVI | 55 | 100% | 58 | 66 | 5 | nd | 3.8 | 63.6 | C | moderate
circumferential PVI (CPVI) | 55

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Liu 2006 China 17062959 | y | 100% [elimination or dissociation of PV potentials assessed by Lasso catheter] | SPVI + linear ablation along LA roof in persistent or inducible sustained AF; mitral annulus isthmus line ablation in those with inducible AF refractory to LA roof ablation (transthoracic cardioversion in those who failed); endpoint is non-inducibility of AF Def of inducibility: AF>10 min; linear lesions were also tested for block. CPVI; RF applied for 30 s at each site until the maximal local electrogram amplitude decreased by >70% or <0.1 mV; endpoint is continuity of the circular lesions and PVI verified by circumferential PV mapping | y | 4 mm irrigated tip | 30 | 43 | 63
n | 3.5 mm irrigated tip | ~30 | ~43 | 59

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Liu 2006 China 17062959 | successful clinical outcome | absence of atrial tachyarrhythmias relapse (defined as any symptomatic AT, regardless of duration; and any asymptomatic AT >10 min) without the use of AADs during the 3–9 mo after the last procedure | SPVI | 9 mo | 43 | 55 | 78%
| | | CPVI | | 46 | 55 | 84% | | 0.63
| repeat procedure | | SPVI | 3–5 mo of initial procedure | 7 | 55 | 13%
| | | | | 5 | 55 | 9% | | nd

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 3 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Liu 2006 China 17062959 | SPVI | | asymptomatic right superior PV stenosis, 1/55 (1.8%) | | | | | | subcutaneous hematoma | 3/55 (5.5%)
requiring transfusion | 1/55 (1.8%)
| CPVI | | asymptomatic right superior PV stenosis, 1/55 (1.8%) | | | | | | subcutaneous hematoma | 4/55 (7.3%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Liu 2006 China 17062959 | y | y | n | nd | n | n | y | NA | n | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | n | y | n
Explanation for Overall Quality Grade: | | | | unclear what the initial total enrollment was, since the first 50 was not counted and only those who completed 9 mo of followup since last procedure were included in the final sample

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Liu 2006 China 17062959 | | X
Explanation for Applicability Grade: | | n=55 in each arm

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Liu 2006b Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Liu 2006 China 17239094 | X | | | | aggressive CPVA vs. modified CPVA (CPVA + segmental PV ostia ablation); KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Liu 2006 China 17239094 | 20–80 y; NYHA I or II; ≥6 mo followup; failed multiple AADs | LAD >55mm; LVEF <35%; prior AF ablation; contraindication to anticoagulation; presence of LA thrombus | 2004-2005 | 3 mo | included only patients with residual PV conduction; with ≥6 mo followup; first time ablation

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Liu 2006 China 17239094 | government | aggressive CPVA | 50 | 75% | 57 | 69 | 6.7 | nd | 3.9 | 64.5 | B | moderate
modified CPVA | 50

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Liu 2006 China 17239094 | y | 96% [isolation confirmed by circumferential mapping] in a-CPVA and 100% in m-CPVA | In patients with residual PV conduction after initial CPVA, then; 1 aggressive CPVA: supplementary ablations along the CPVA lines close to the earliest ipsilateral PV spikes; additional conduction gap considered if PV activation sequence changed after one gap was closed or; 2 modified CPVA: sites with earliest activation in each PV perimeter were targeted during SR or CS pacing; Also, in patients with AFL before or during the procedure, tricuspid annulus isthmus ablation was performed to achieve a bidirectional conduction block. | n | 3.5 mm irrigated tip | 35 | 43 | 58

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Liu 2006 China 17239094 | successful outcome | absence of atrial tachyarrhythmias relapse (defined as any symptomatic AT, regardless of duration; and any asymptomatic AT >5 min) without the use of AADs beyond the first 3 mo after the initial procedure | a-CPVA | 13 mo (?) | 41 | 50 | 82%
| | | m-CPVA | | 29 | 50 | 58% | | 0.01

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 3 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Liu 2006 China 17239094
modified CPVA predicted late AT recurrence (RR 0.318; 95% CI 0.123–0.821; P=0.02)

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Liu 2006 China 17239094 | a-CPVA | | | 1/50 (2%) | | | | | subcutaneous hematoma requiring transfusion | 1/50 (2%)
| m-CPVA | | asymptomatic single PV stenosis (>50% reduction in diameter) 2/50 (4%) | | 1/50 (2%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Liu 2006 China 17239094 | y | y | n | nd | n | n | y | NA | n | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | ? | y | n
Explanation for Overall Quality Grade: | | | | unclear if re-dos were counted in success rate

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Liu 2006 China 17062959 | | X
Explanation for Applicability Grade: | | n=50 in each arm

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Ma Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Ma, 2006 China 17199954 | | | x | | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Ma, 2006 China 17199954 | Nonvalvular AF, age <80 years, function of heart (NYHA I-II0, refractory to >2 AAD, no severe structural heart disease; no history of stroke in the previous half year | Age<20, LA thrombus identified by transesophageal echocardiography, severe impairment of liver function or kidney function, be hyper susceptible to warfarin, thyroid disorder; other severe disease (such as malignant tumor) | Since September 2004 | Oral amiodarone (in 26 patients, 25%) or propafenone (in 27 patients, 25%) was taken after ablation. Among them, 16 patients took oral amiodarone for >3 months (patients with chronic AF or those whose PVs had not been isolated completed). | 16% persistent AF 15% permanent AF

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Ma, 2006 China 17199954 | nd | Linear ablation of LA guided by both Carto and double lasso catheters | 106 | 73.6 | 51.4 | 77 | 7.1 | nd | nd | nd | B | wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Ma, 2006 China 17199954 | yes | 88.7% [absence of all PV spikes detected by the 2 Lasso catheters within the ipsilateral PVs, or dissociation of PVPs (fibrillation in PVs, while sinus rhythm in atria) for >30 minutes] | “Circumferential lines of ablation” Regions in LA with fragmented potentials were also ablated in patients with persistent or permanent AF (31%). External cardioversion was performed if the patients still presented with atrial fibrillation after the complete isolation of PVs. Additionally, linear ablation of the cavotricuspid isthmus was performed until bidirectional block was acquired at the isthmus if the patient had previous history of atrial flutter. | no | 3.5-mm irrigated tip (ThermoCool Navi-Star, Biosense Webster, USA) | 30–40 | 43–45 | 25.4

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Ma, 2006 China 17199954 | Success of ablation | No recurrence of atrial tachyarrhythmias according to the symptoms, ECG and Holter monitoring during the followup periods from the 4^th^ month of post ablation procedure to current time | Linear ablation of LA guided by both Carto and double lasso catheters | 11.5 | 62 | 87

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | yes
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | 3 months

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Ma, 2006 China 17199954 | Linear ablation of LA guided by both Carto and double lasso catheters | | 0 | 2/106 (1.9%) | | | | 0 | Atrioesophageal fistula | 0

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Ma, 2006 China 17199954 | no | NA | NA | 18% | nd | no | yes | no | no | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | yes | yes | yes | No
Explanation for Overall Quality Grade: | | | | Incomplete reporting of patients characteristics. Descriptive analyses only.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Ma, 2006 China 17199954 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Ma, 2006 China 17199954 | Long-term clinical outcomes assessed in 87 (82%) patients who had follow-up >3 months. During followup, 9 patients underwent a second ablation procedure for the recurrence of atrial tachyarrhythmia and all of them had acquired PVPs isolation. After the 2nd ablation procedure, there have been (6.2+-3.7) months (1–14 months) during which no recurrence of atrial tachyarrhythmias has been observed.

Macle Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Macle, 2002 France 12475093 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Macle, 2002 France 12475093 | Symptomatic drug-refractory AF | nd | nd | nd | 37 patients had undergone cavo-tricuspid isthmus line previously

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Macle, 2002 France 12475093 | nd | Ostial PVI + additional lines | 136 | 90 | 52 | 80 | 7.0 | nd | nd | nd | C | Wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Macle, 2002 France 12475093 | Yes | 100% [Abolition or dissociation of all PV potentials recorded within the PV] | - Cavo-tricuspid isthmus line (all); - Non-PV foci (if induced); - Other linear lines (for persistent AF only): roof line, line between ipsilateral PVs, and mitral isthmus line | Yes | 4 mm irrigated-tip (Celcius Thermo-Cool) | 25–30* | 50 | 36.9**

* Ablation energy was delivered at 25 W at the right inferior PV only whereas 30 W was used for the other PVs.

** Only ablation time for PVIs was taken into account.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Macle, 2002 France 12475093 | Cure without AAD | Freedom from AF recurrence (no detailed definition on recurrence (but symptoms suspected of AF were considered recurrence) and post-procedure blanking period) | Ostial PVI + additional lines | 8.8 | 90 | 136 | 66%
Macle, 2002 France 12475093 | Cure with/without AAD | Freedom from AF recurrence (no detailed definition on recurrence (but symptoms suspected of AF were considered recurrence) and post-procedure blanking period) | Ostial PVI + additional lines | 8.8 | 110 | 136 | 81%
Macle, 2002 France 12475093 | Re-procedure | At least one re-procedure | Ostial PVI + additional lines | 8.8? | 67 | 136 | 49%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Most likely crude estimates

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Nd
Was a blanking period (time when AFib episodes were not recorded) used? | nd | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Macle, 2002 France 12475093 | Ostial PVI + additional lines | 8.8 | 0/136* | nd | 0/136 | nd | nd | nd

* 50% narrowing by PV angiography was reported in one patient.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Macle, 2002 France 12475093 | No | NA | NA | nd | nd | nd/NA | No | No | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | Probably no | nd | NA
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Macle, 2002 France 12475093 | | | Wide
Explanation for Applicability Grade: | | No exclusion criteria. Should have patient spectrum similar to clinical practice.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Mansour Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Mansour, 2004 USA 15149421 | | | | X | Retrospective comparison between segmental ostial PVI and circumferential extraostial approach | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Mansour, 2004 USA 15149421 | Paroxysmal or persistent symptomatic drug-refractory AF | nd | 09/2000–12/2002 | nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Mansour, 2004 USA 15149421 | nd | Segmental ostial PVI | 40 | 81 | 54 | 85 | nd | nd | 4.0 | Nd* | C | Narrow
Circumferential extraostial PVI | 40

* 13% of patients (10/80) had EF<40%

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Mansour, 2004 USA 15149421 | Yes (Segmental ostial PVI) | 90% [Entrance block] | nd | No | nd | 25–30 | 50 | 44
Yes (Circumferential extraostial PVI) | 100% [Entrance block during sinus/paced-LA rhythm and exit block in PV pacing] | Mitral isthmus line* | 50 | 60 | 71

* Only if patients were ablated during AF or AF still showed some organization after completion of the circumferential PVI (n=12).

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Mansour, 2004 USA 15149421 | Relapse free | Free from AF (no explicit definition) recurrence during follow-up (Kaplan-Meier at unclear time point) | Segmental ostial PVI | 21 | 24 | 40 | 60% | | nd
Circumferential extraostial PVI | 11 | 30 | 40 | 75%
Mansour, 2004 USA 15149421 | Repeat procedure | Patients who required a repeat procedure (reason not explicitly provided) during follow-up (crude estimate?) | Segmental ostial PVI | 21 | 6 | 40 | 15% | | nd
Circumferential extraostial PVI | 11 | 4 | 40 | 10%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | No
Was a blanking period (time when AFib episodes were not recorded) used? | No | If yes, how long was it? | NA

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Mansour, 2004 USA 15149421 | Segmental ostial PVI | 21 | 0/40**** | 2/40 (5%) | 1/40 (3%)* | nd | 0/40 | Nd
Circumferential extraostial PVI | 11 | 0/40**** | 1/40 (3%) | 1/40 (3%)** | nd | 2/40 (5%)*** | nd

* Symptoms (left-sided hemipararesis) appeared 10 h after the procedure. This patient had patent foramen oval.

** Symptoms (alexia) appeared 10 h after the procedure.

*** Significant femoral vascular complication requiring vascular repair.

**** Only patients who needed a repeat procedure underwent a MRI evaluation.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Mansour, 2004 USA 15149421 | No | NA | NA | nd | nd | nd | Yes | No | No | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | Nd | No | No
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Mansour, 2004 USA 15149421 | X
Explanation for Applicability Grade: | | N<30 per intervention

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Mantovan Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Mantovan 2005 Italy 16403059 | | X | | | anatomical vs. integrated approach; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Mantovan 2005 Italy 16403059 | drug refractory AF | intracardiac thrombi | nd | 6 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Mantovan 2005 Italy 16403059 | nd | anatomical | 30 | 65 | 54 | 85 | 4.2 | nd | 4.3 | 60 | C | moderate
integrated | 30

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Mantovan 2005 Italy 16403059 | no in anatomical; yes in integrated | 100% in integrated group; endpoint [elimination or dissociation of distal PV potentials leading to no PV muscle conduction distal to the ablation site] | Anatomical - circumferential lines around each PV at >5 mm from the PV ostia; no linear lesions Integrated - anatomical plus assessment of PV potentials with further ablation if there were residual PV potentials | n | 3.5 mm irrigated tip (ThermoCool - external irrigation) | 40 | nd | 43
30 (at or inside the ostium) | nd | 42

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Mantovan 2005 Italy 16403059 | primary endpoint (stable sinus rhythm) | freedom from recurrent AF - no symptomatic AF, no asymptomatic sustained AF (>30 s) | anatomical | 15.1 | 17 | 30 | RR 1.78 | 1.07–2.09 | <0.02
| | | integrated | 15.9 | 25 | 30
| | sinus rhythm without AAD | anatomical | | 4 | 30 | 13% | | 0.002
| | | integrated | | 16 | 30 | 53%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 2 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Mantovan 2005 Italy 16403059 | anatomical | | asymptomatic PV stenosis by TEE, 1/30 (3.3%)
| integrated | | | | | | | | pericardial effusion requiring drainage | 1/30 (3.3%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Mantovan 2005 Italy 16403059 | n | NA | NA | y | n | n | y | n | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | n | y | y
Explanation for Overall Quality Grade: | | | | unclear if the success rate included redo

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Mantovan 2005 Italy 16403059 | | x
Explanation for Applicability Grade: | | N=30 in each group; relatively young patients

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
| unclear how successful the procedure was as majority of the patients remained on AAD

Marrouche 2003 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Marrouche, 2003 USA 12756153 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Marrouche, 2003 USA 12756153 | nd | nd | 12/2000–05/2002 | Nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Marrouche, 2003 USA 12756153 | nd | Ostial PVI | 315 | 51 | 54 | 78 | 6.0 | nd | 4.2 | Nd | C | Moderate

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Marrouche, 2003 USA 12756153 | Yes | 88–100%* [abolition of all ostial PV potentials] | nd | nd | 4 mm cooled-tip EP TECHNOLOGIES | Nd** | 35** | nd

* PV-based data were presented. Unclear if these data showed %success (assuming that all four PVs were tried) or % performed (assuming 100% success)

** Energy delivery was titrated 5-watt upward/downward monitoring microbubbles by ICE in 152 patients. In this group, energy delivery ranged from 20 to 50 watts with 20 to 50 temperature at the ablated sites.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Marrouche, 2003 USA 12756153 | Freedom from recurrent AF** | Freedom from recurrence after 8-week blanking period. Definition of AF recurrence not explicitly provided. | Ostial PVI | 13 | 271 | 315 | 86%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

** Recurrence rate was reported in the text.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 8 weeks

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
No ICE (Group 1) | Marrouche, 2003 USA 12756153 | Freedom from recurrent AF | Freedom from recurrence after 8-week blanking period. Definition of AF recurrence not explicitly provided. | Ostial PVI | 21 | 45 | 56 | 80 | | 0.009 (Group 1 vs. 3, Cox??) 0.08 (Group 2 vs. 3, ?)
ICE without microbubble assessment (Group 2) | 14 | 89 | 107 | 83
ICE with microbubble assessment (Group 3) | 9 | 137 | 152 | 90
No ICE (Group 1) | Marrouche, 2003 USA 12756153 | Freedom from recurrent AF | Freedom from recurrence after 8-week blanking period. Definition of AF recurrence not explicitly provided. | Ostial PVI | 21 | 45 | 56 | 80 | | 0.01 (?)
ICE (Group 2+3) | 11 | 226 | 259 | 87
ICE without microbubble assessment (Group 2) | Marrouche, 2003 USA 12756153 | Chronic Success | Unclear | Ostial PVI | 14 | Nd | 107 | 80 | | 0.009 (log-rank?)
ICE with microbubble assessment (Group 3) | 9 | nd | 152 | 90

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

Discrepancies of adopted statistical tests (Cox regression without specifying covariates were mainly described in the text, whereas log-rank was inferred in the methods and graphs).

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Marrouche, 2003 USA 12756153 | Ostial PVI | 13 | 5/315 (2%) | nd | 5/315 (2%)* | nd | nd | nd

No patient who underwent microbubbles assessment by ICE (Group 3) developed severe (>60%) PV stenosis or stroke (P<0.05, compared with Group 1(?) per report).

* Three of these five patients developed TIA.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Marrouche, 2003 USA 12756153 | No | NA | NA | nd | nd | nd | ? | ? | No | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | No | Inferred yes | No
Explanation for Overall Quality Grade: | | | | Retrospective study with many discrepancies on methodology applied

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Marrouche, 2003 USA 12756153 | | Moderate
Explanation for Applicability Grade: | | Should have been categorized as wide with detailed inclusion/exclusion criteria reported…

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Marrouche 2007 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Marrouche, 2007 Germany 17490437 | X | | | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Marrouche, 2007 Germany 17490437 | Symptomatic AFib, for PV antrum isolation | nd | None (implied) | nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Marrouche, 2007 Germany 17490437 | 1 researcher: BARD (German engineering company) | Open Irrigation RF, 3.5 mm (Thermo-cool or Navistar-Thermo-Cool) with ICE | 26 | 62% | 54 | 75% | 5.0 yr | 53% | 4.3 cm | nd | B | Narrow
8 mm (Navistar or Celsius DS) with ICE and microbubble | 27

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Marrouche, 2007 Germany 17490437 | Yes | 100% Lasso used [electrical disconnection of the PV-antra from the left atrium] | Isolation of the SVC from the RA | No (nd) | Irrigation RF | Max 50 (Mean 43) | 50° (Mean 45°) | 5.1 min
8 mm | Min 20 (Mean 44) | nd (Mean 49°) | 9.2 min

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Marrouche, 2007 Germany 17490437 | Recurrence atrial arrhythmia (late) | AFib or AFlutter | Irrigated | 14 | 5 | 26 | | | NS
| | | 8 mm | 14 | 6 | 27
| 2nd isolation procedure | | Irrigated | 14 | 2 | 26 | | | NS
| | | 8 mm | 14 | 2 | 27

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes implied | If yes, how long was it? | 8 weeks

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Marrouche, 2007 Germany 17490437 | Irrigated | 3 mo | 0/26 | | | | | | LA-esophageal fistulae | 0/26
| 8 mm | 3 mo | 0/27 | | | | | | | 0/27
| Irrigated | | | | | | | | Dyspepsia with esophageal wall changes (within 2 wk) | 0/26
| 8 mm | | | | | | | | | 1/27

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Marrouche, 2007 Germany 17490437 | Yes | nd | nd | Yes (0%) | nd | Yes (no dropouts) | Yes | NA | Yes | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Not explicitly | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | Study design features lacking. Recurrence outcome definition not explicit. N<30 per arm

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Marrouche, 2007 Germany 17490437 | Narrow
Explanation for Applicability Grade: | | N<30 per arm

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Marrouche, 2007 Germany 17490437 | Also data on esophageal ulcers etc., all of which healed without incident. Endoscopy was done in all. Also data on Early AFib recurrences (8 wk) Small N. Clearly reported, but few study method details.

Marsan Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Marsan 2008 Netherlands 18805109 | | | | X | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Marsan 2008 Netherlands 18805109 | Symptomatic, drug refractory AF | nd | <2007 | 3 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Marsan 2008 Netherlands 18805109 | nd | RFA | 57 | 75 | 56 | 77 | 4.6 | nd | nd | 57 | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Marsan 2008 Netherlands 18805109 | Y | Goal (PVI confirmed by entrance block) | no | Y | 4 mm irrigated (ThermoCool) | 30 | 50°

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Marsan 2008 Netherlands 18805109 | AF Recurrence | >3 min Sxic or >30 sec on ECG/Holter | RFA | 7.9 | 19 | 57 | 33%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Y
Was a blanking period (time when AFib episodes were not recorded) used? | Y | If yes, how long was it? | 1 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
PAF | Marsan 2008 Netherlands 18805109 | AF Recurrence | >3 min Sxic or >30 sec on ECG/Holter | RFA | 7.9 | 11 | 45 | 24% | | <.05
Persistent | | | | | | 8 | 12 | 75%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Marsan 2008 Netherlands 1880510

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Marsan 2008 Netherlands 18805109 | N | NA | NA | N | NA | Y | Y | Y | Y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Y | Y | Y | Y | N
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Martinek Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Martinek 2007 Austria 17897124 | | X | | | RFA with multislice CT vs. without; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Martinek 2007 Austria 17897124 | symptomatic drug-refractory AF | nd | 2005 | | Non-concurrent comparison (first 53 patients compared with second 47 patients over a period of 7 mo)

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Martinek 2007 Austria 17897124 | nd | RFA with conventional electroanatomic mapping (Carto XP) | 53 | 59 | 56 | 85 | 6.5 | nd | 4.8 | 55 | C | moderate
RFA with multislice CT integration with Carto MERGE | 47

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Martinek 2007 Austria 17897124 | y | 100% [complete electrical disconnection] | LA circumferential ablation with further linear lesions (roof, mitral isthmus, and inferior line) or focal RF applications at areas with CFAE if AF could not be terminated | n | 4mm irrigated tip (ThermoCool) | 30 | 48 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Martinek 2007 Austria 17897124 | full success | free of arrhythmias without class IC or class III AAD | Carto XP | 6 mo | 26 | 53
| | | Carto Merge | | 36 | 47
| success on AAD | no symptomatic recurrences, on AAD | Carto XP | | 10 | 53
| | | Carto Merge | | 4 | 47
| failure | no clinical benefits, with AF episodes | Carto XP | | 17 | 53
| | | Carto Merge | | 7 | 47
| overall success | full success + success on AAD | Carto XP | | 36 | 53 | 67.9%
| | | Carto Merge | | 40 | 47 | 85.1% | | 0.018

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | n | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Paroxysmal AF | | overall success | | Carto XP | 6 mo | 23 | 31
| | | | Carto Merge | | 23 | 28
Persistent/permanent AF | | overall success | | Carto XP | 6 mo | 13 | 22
| | | | Carto Merge | | 17 | 19 | | | 0.197 (paroxysmal vs. persistent/permanent)

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Success did not vary between patients receiving their first RFCA or having repeated procedures (P=0.199).

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Martinek 2007 Austria 17897124 | Carto XP | | >50% stenosis, 3/53 (5.7%) | | TIA, 1/53 (1.9%); major stroke, 1/53 (1.9%)
| Carto Merge | | | | TIA, 1/47 (2.1%) | | | | right phrenic n. injury | 1/47 (2.1%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Martinek 2007 Austria 17897124 | n | NA | NA | y | n | n | y | y(?) | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | n | y | n
Explanation for Overall Quality Grade: | | | | non-randomized; non-concurrent comparison

* observational study cannot be an A, retrospective study is always a C

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Martinek 2007 Austria 17897124 | | X
Explanation for Applicability Grade: | | relatively few patients, patients relatively young with normal ejection fraction

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Matiello Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Matiello 2008 Spain 18515285 | | X | | | Three intervention groups (non-concurrent comparisons) | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Matiello 2008 Spain 18515285 | Patients with documented symptomatic refractory paroxysmal, persistent, and permanent AF | Age<18 or >75 years, anteroposterior left anterior descending artery and transthoracic echocardiography>55 mm, presence of left anterior thrombus on transesophageal echo, and the presence of a mechanical prosthetic heart valve | nd | Previous AAD was maintained for >1 month in order to manage early recurrences and then discontinued if there were no recurrences 1–3 months after ablation | Persistent AF: 24% Permanent AF: 14%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Matiello 2008 Spain 18515285 | Government | First 90 patients - 8-mm tip catheter, next 42 patients - saline cooled-tip catheter (Celsius ThermoCool) at 45°C and 30 W power output; the remaining 89 patients - saline cooled-tip catheter (Celsius ThermoCool) at 45°C and 40 W power output | 221 | 62 | 52 | 76 | nd | nd | 4.1 | nd | C | wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Matiello 2008 Spain 18515285 | yes | Anatomical approach [The endpoint was the disappearance of the local electrogram inside the whole surrounded areas] | LA roof, post vwall Mitral isthmus ablation was anatomically performed by creating an RF line from the posterolateral aspet of the left-sided encircling lesions to the mitral valve | no | Group 1: 8-mm | 50 | 55 | No breakdown by groups. Total ablation time = 2197 +- 944 s
Matiello 2008 Spain 18515285 | yes | Anatomical approach [The endpoint was the disappearance of the local electrogram inside the whole surrounded areas] | LA roof, post vwall Mitral isthmus ablation was anatomically performed by creating an RF line from the posterolateral aspet of the left-sided encircling lesions to the mitral valve | no | Group 2: irrigated tip | 30 | 45 | No breakdown by groups. Total ablation time = 2197 +- 944 s
Group 3: irrigated tip | 40 | 45

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Matiello 2008 Spain 18515285 | Arrhythmia free after a single procedure | At 1 year follow-up, on or off AADs. A total of 7 (8%), 4 (10%), and 13 (15%) of the patients of each group were taking 1 AAD despite they had no recurrences beyond the blanking period. | Group 1: 8-mm | 12 | 53% | 90 | | | nd
Matiello 2008 Spain 18515285 | Arrhythmia free after a single procedure | At 1 year follow-up, on or off AADs. A total of 7 (8%), 4 (10%), and 13 (15%) of the patients of each group were taking 1 AAD despite they had no recurrences beyond the blanking period.
Group 2: irrigated tip (30 W) | 12 | 35% | 42
Group 3: irrigated tip (40 W) | 12 | 55% | 89
| Arrhythmia recurrence | Implied including repeated procedure, on or off AADs | Group 1: 8-mm | 20 | 32% | 90 | | | 0.03 (group 2 vs. group1 or group 3) 0.37 (group 1 vs. group 3)
| Arrhythmia recurrence | Implied including repeated procedure, on or off AADs | Group 2: irrigated tip (30 W) | 14 | 55% | 42 | | | 0.03 (group 2 vs. group1 or group 3) 0.37 (group 1 vs. group 3)
Group 3: irrigated tip (40 W) | 9 | 40% | 89

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | yes
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | 3 months

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Catheter tips | Matiello 2008 Spain 18515285 | Arrhythmia recurrence | Implied including repeated procedure, on or off AADs | Group 1: 8-mm Group 2: irrigated tip (30 W) Group 3: irrigated tip (40 W) | Group 1: 20 Group 2: 14 Group 3: 9 | | | Only irrigated tip (30 W) was a significant predictor HR=1.713* | 1.02–2.90 | 0.045
Anteroposterior atrial diameter | | | | | | | | HR= 1.105* | 1.05–1.19 | 0.001

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

* Unclear univariate or multivariate analyses. Variables that were not significant predictors were not reported.

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Matiello 2008 Spain 18515285 | Group 1: 8-mm | 20 | 0 (>50% narrowing) | 1/90 (1%) | | | | | Dysphagia | 0
Matiello 2008 Spain 18515285 | Group 1: 8-mm | 20 | 0 (>50% narrowing) | 1/90 (1%)
Matiello 2008 Spain 18515285 | Group 1: 8-mm | 20 | 0 (>50% narrowing) | 1/90 (1%) | | | | | Transient vascular accident | 1/90 (1%)
pericarditis | 4/90 (4%)
Transient ST elevation | 0
| Group 2: irrigated tip (30 W) | 14 | 0 | 0 | | | | | dysphagia | 0
| Group 2: irrigated tip (30 W) | 14 | 0 | 0
| Group 2: irrigated tip (30 W) | 14 | 0 | 0 | | | | | Transient vascular accident | 1/131 (0.8%)
pericarditis | 1/131 (0.8%)
Transient ST elevation | 1/131 (0.8%)
| Group 3: irrigated tip (40 W) | 9 | 0 | 0 | | | | | dysphagia | 1/89 (1%)
| Group 3: irrigated tip (40 W) | 9 | 0 | 0 | | | | | Transient vascular accident | 2/89 (2%)
| Group 3: irrigated tip (40 W) | 9 | 0 | 0
pericarditis | 3/89 (3%)
Transient ST elevation | 2/89 (2%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Matiello 2008 Spain 18515285 | no | NA | no | nd | nd | nd | yes | no | No | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | no | unclear | yes | no
Explanation for Overall Quality Grade: | | | | Non-concurrent groups. Poor and discrepant reporting.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Matiello 2008 Spain 18515285 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Matiello 2008 Spain 18515285 | Unclear univariate or multivariate analyses for results of clinical predictors of arrhythmia recurrence. Variables that were not significant predictors were not reported. Discrepant reporting of sample sizes in the tables..

Matsuo Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Matsuo, 2007 Japan 17506857 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Matsuo, 2007 Japan 17506857 | Symptomatic drug-refractory AF | nd | 04/2003–05/2006 04/2003–01/2005: ostial PVI only 01/2005–05/2006: ostial PVI + additional ablation targeting dormant PV conduction | None except for recurrence within a week after the procedure

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Matsuo, 2007 Japan 17506857 | nd | Ostial PVI ± additional ablation | 148 | 65 | 53 | 86 | 4.7 | nd | 3.8 | 66 | C | Wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Matsuo, 2007 Japan 17506857 | Yes | 100% inferred (except for PVs with diameter less than 12 mm) and those without arrhythmogenicity [Bidirectional conduction block between the LA and PV] | Additional ablation of the earliest PV activation if ATP- or CS pacing-induced dormant PV conduction | Yes | 8 mm (nd) | 30–35* | 50* | 31 min**

* When the ablation site was proximate to the esophagus, the power and the target temperatures was lowered to 25 W and 45 °C, respectively.

** Difference between ostial PVI only and ostial PVI + additional ablation was 2.1 min (30.7 vs.32.8, P<0.05)

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | No | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
No additional ablation | Matsuo, 2007 Japan 17506857 | Freedom from AF after the first procedure | Recurrence of AF was defined as sustained AF (>1 min) without AAD during the entire follow-up evaluated by the symptoms, regular ECG, and Holter ECG. Blanking period unclear. | Ostial PVI without or with additional ablation | 20 | 56 | 94 | 60% | | <0.05 (log-rank)
Additional ablation | 43 | 54 | 80%
No additional ablation | Matsuo, 2007 Japan 17506857 | Repeat procedure after the first procedure | Not explicitly described | Ostial PVI without or with additional ablation | 5.6 | 36 | 94 | 38% | | <0.05 (log-rank)
Additional ablation | 9 | 54 | 17%
No additional ablation | Matsuo, 2007 Japan 17506857 | Freedom from AF after the second procedure | Recurrence of AF was defined as sustained AF (>1 min) without AAD during the entire follow-up evaluated by the symptoms, regular ECG, and Holter ECG. Blanking period unclear. | Ostial PVI without or with additional ablation | ? | 29 | 36 | 81% | | nd
Additional ablation | 6 | 9 | 67%
No additional ablation | Matsuo, 2007 Japan 17506857 | Maintenance of NSR after the last procedure | Maintenance of NSR without AAD. Otherwise, not explicitly described. | Ostial PVI without or with additional ablation | 20? | 85 | 94 | 90% | | nd
Additional ablation | 49 | 54 | 91%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Matsuo, 2007 Japan 17506857 | Ostial PVI ± additional ablation | 20 | 2/148 (1%)* | 1/148 (1%)** | nd | nd | nd | Nd

* Asymptomatic PV stenosis (50–75% narrowing)

** Another one patient developed moderate pericardial effusion, which resolved without pericardiocentesis.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Matsuo, 2007 Japan 17506857 | No | NA | NA | nd | nd | NA | Yes | No | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Matsuo, 2007 Japan 17506857 | | | Wide
Explanation for Applicability Grade: | | No exclusion criteria.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Miyazaki Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Miyazaki 2008 Japan 18362429 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Miyazaki 2008 Japan 18362429 | Drug refractory paroxysmal or chronic AF | Patients who could not complete all the questionnaires | nd | 3 mo (chronic AF only) | LAD and LVEF were significantly worse for chronic group (P<0.01)

Chronic AF: lasting >6 mo despite the use of any AADs

Paroxysmal AF: AF spontaneously converting to normal sinus rhythm with or without AAD

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Miyazaki 2008 Japan 18362429 | nd | CPVI | 86 | 71 | 59 | 79 | nd | nd | 4.0 | 65 | C | Moderate

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Miyazaki 2008 Japan 18362429 | yes | 100% [The elimination of all PV potentials] | LA: WACA Roof line (2% vs. 12%) Mitral-isthmus line (0% vs. 56%) RA: Cavo-tricuspid isthmus line (100% for both) Other: SVC isolation (5% vs. 28%) Focal ablation (5% vs. 8%) | no | 8 mm (Japan Lifeline) | 35 (LA posterior wall), 40 (anterior aspect of PV) | 55 | nd

In the parentheses, patients with paroxysmal AF vs. chronic AF

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | nd | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Paroxysmal | Miyazaki 2008 Japan 18362429 | Free from recurrence | Free from recurrence (by symptoms, ECG, or Holter ECG) | CPVI | 6 | 48 | 61 | 76%
Chronic | Miyazaki 2008 Japan 18362429 | Free from recurrence | Free from recurrence (by symptoms, ECG, or Holter ECG) | CPVI | 6 | 15 | 25 | 60%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Paroxysmal AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Frequency of symptoms | AFQLQ | score | CPVI | 6 | 48 | 13.8 | 21.7 | 7.9 | Nd
Paroxysmal AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Severity of symptoms | AFQLQ | score | CPVI | 6 | 48 | 11.3 | 16.7 | 5.4 | Nd
Paroxysmal AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Limitations of activity and mental anxiety | AFQLQ | score | CPVI | 6 | 48 | 33.3 | 51.4 | 18.1 | Nd
Chronic AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Frequency of symptoms | AFQLQ | score | CPVI | 6 | 15 | 13.5 | 22.8 | 9.3 | Nd
Chronic AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Severity of symptoms | AFQLQ | score | CPVI | 6 | 15 | 12.5 | 16.9 | 4.4 | Nd
Chronic AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Limitations of activity and mental anxiety | AFQLQ | score | CPVI | 6 | 15 | 37.6 | 51.9 | 14.3 | Nd

Duplicate one row per outcome and per RFA intervention.

e.g. Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Miyazaki 2008 Japan 18362429

Not reported.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Miyazaki 2008 Japan 18362429 | n | na | na | Yes?/nd | nd | nd | nd | nd | no | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | no | yes | yes | nd
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Miyazaki 2008 Japan 18362429 | | Moderate
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Nilsson 2006a Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Nilsson 2006 Denmark 17043070 | | x | | | high output/short duration RF vs. low output/long duration RF; first 45 compared with second 45 patients; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Nilsson 2006 Denmark 17043070 | patients with paroxysmal or persistent AF, failed AAD and had one segmental PVI | EF<20%; NYHA class IV; prior ablation; significant valve disease; <18 yr; congenital heart disease | nd | 1 mo | possibly overlap with the ostial PVI arm in the Nilsson 2006 RCT

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Nilsson 2006 Denmark 17043070 | industry | low output | 45 | 71 | 51 | 80 | 6.4 | 9 | | | C | moderate
high output | 45 | 57 | 55 | 67 | 4.6 | 4.4

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Nilsson 2006 Denmark 17043070 | y | 96% [no potential] segmental ostial PVI | | nd | 5 mm irrigated | 30 | 50 | 36
45 | 55 | 19

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Nilsson 2006 Denmark 17043070 | outcome 1 | stable SR with no symptomatic recurrent AF | low output | 15 | | | 74%
| | | high output | | | | 76% | | NS
| outcome 2 | did not need additional AAD | low out put | 15 | | | 54%
| | | high output | | | | 56% | | NS

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | n
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 1 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Nilsson 2006 Denmark 17043070 | low output | | 0 | | TIA, 1/45 (2.2%)
| high output | | 0 | | TIA, 1/45 (2.2%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Nilsson 2006 Denmark 17043070 | n | NA | NA | NA | n | n | y | n | n | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | n | n | NA
Explanation for Overall Quality Grade: | | | | retrospective; no adjustment for possible confounding

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
| | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Nilsson 2006 Denmark 17043070 | possible that some of the patients in the high output group were also the same ones in the RCT of ostial vs. extra ostial study (UI 16923426)

Nilsson 2006b Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Miyazaki 2008 Japan 18362429 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Miyazaki 2008 Japan 18362429 | Drug refractory paroxysmal or chronic AF | Patients who could not complete all the questionnaires | nd | 3 mo (chronic AF only) | LAD and LVEF were significantly worse for chronic group (P<0.01)

Chronic AF: lasting >6 mo despite the use of any AADs

Paroxysmal AF: AF spontaneously converting to normal sinus rhythm with or without AAD

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Miyazaki 2008 Japan 18362429 | nd | CPVI | 86 | 71 | 59 | 79 | nd | nd | 4.0 | 65 | C | Moderate

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Miyazaki 2008 Japan 18362429 | yes | 100% [The elimination of all PV potentials] | LA: WACA Roof line (2% vs. 12%) Mitral-isthmus line (0% vs. 56%) RA: Cavo-tricuspid isthmus line (100% for both) Other: SVC isolation (5% vs. 28%) Focal ablation (5% vs. 8%) | no | 8 mm (Japan Lifeline) | 35 (LA posterior wall), 40 (anterior aspect of PV) | 55 | nd

In the parentheses, patients with paroxysmal AF vs. chronic AF

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | nd | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Paroxysmal | Miyazaki 2008 Japan 18362429 | Free from recurrence | Free from recurrence (by symptoms, ECG, or Holter ECG) | CPVI | 6 | 48 | 61 | 76%
Chronic | Miyazaki 2008 Japan 18362429 | Free from recurrence | Free from recurrence (by symptoms, ECG, or Holter ECG) | CPVI | 6 | 15 | 25 | 60%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Paroxysmal AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Frequency of symptoms | AFQLQ | score | CPVI | 6 | 48 | 13.8 | 21.7 | 7.9 | Nd
Paroxysmal AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Severity of symptoms | AFQLQ | score | CPVI | 6 | 48 | 11.3 | 16.7 | 5.4 | Nd
Paroxysmal AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Limitations of activity and mental anxiety | AFQLQ | score | CPVI | 6 | 48 | 33.3 | 51.4 | 18.1 | Nd
Chronic AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Frequency of symptoms | AFQLQ | score | CPVI | 6 | 15 | 13.5 | 22.8 | 9.3 | Nd
Chronic AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Severity of symptoms | AFQLQ | score | CPVI | 6 | 15 | 12.5 | 16.9 | 4.4 | Nd
Chronic AF (without recurrence) | Miyazaki 2008 Japan 18362429 | Limitations of activity and mental anxiety | AFQLQ | score | CPVI | 6 | 15 | 37.6 | 51.9 | 14.3 | Nd

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Miyazaki 2008 Japan 18362429

Not reported.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Miyazaki 2008 Japan 18362429 | n | na | na | Yes?/nd | nd | nd | nd | nd | no | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | no | yes | yes | nd
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Miyazaki 2008 Japan 18362429 | | Moderate
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Okada Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Okada 2007 Japan 17397672 | | x (retrospective) | | | PVI vs. CPVA; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Okada 2007 Japan 17397672 | symptomatic paroxysmal AF, failed AADs (excluding amiodarone) | | nd | | essentially a cohort study

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Okada 2007 Japan 17397672 | nd | PVI | 50 | 100 | 58 | 84 | 5 | nd | 3.41 | 67 | C | moderate
CPVA | 27

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Okada 2007 Japan 17397672 | y | 96.5% of veins in PVI; 99% of veins in CPVA [complete electrical dissociation and non-inducibility] | group 1: PVI group 2: CPVA | y | 8 mm | 30–40 | 55

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Okada 2007 Japan 17397672 | outcome 1 | free of symptomatic paroxysmal AF and no AADs | PVI | 6 mo | 25 | 50 | 50%
| | | CPVA | | 24 | 27 | 89% | | <0.001

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | n
Was a blanking period (time when AFib episodes were not recorded) used? | n | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Okada 2007 Japan 17397672 | PVI | | significant PV stenosis (asymptomatic), 2/50 (4%)
| CPVA | | significant PV stenosis (asymptomatic), 1/27 (3.7%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Okada 2007 Japan 17397672 | n | NA | nd | y | n | n | y | n | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | n | y | n
Explanation for Overall Quality Grade: | | | | essentially a cohort study with no adjustment for potential confounders

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Okada 2007 Japan 17397672 | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Oral 2003 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Oral, 2003 US 14557355 | X | | | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Oral, 2003 US 14557355 | Symptomatic paroxysmal AFib | CHF, EF<35%, LAD>5.5 cm, previous ablation | nd | nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Oral, 2003 US 14557355 | Ellen and Robert Thompson Atrial Fibrillation Research Fund | PVI segmental ostial oblation (4 mm) | 40 | 100% | 52 | 78% | 7 yr | 0% | 4.0 | 56% | B
PVI LA ablation (8 mm) | 40

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Oral, 2003 US 14557355 | Yes | 100% Inferred | None (Only segmental ostial RFA) | No | 4 mm (EP Technologies) | 35 W max | 52° target | 18 min
WACA Posterior LA line connecting circles Mitral isthmus line | 8 mm (Navistar) | 60 W max | e55° target | 42 min

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Oral, 2003 US 14557355 | Freedom from recurrent AFib | Absence of symptomatic AFib off AAD (without repeat procedure) | Segmental | 6 mo | 27 (67%) | 40 | | | .02 (log rank)
| | | LA Ablation | 6 mo | 35* (88%) | 40
| AFib recurrence | symptomatic | Segmental | 6 mo | 13 | 40
| | | LA Ablation | 6 mo | 4* | 40
| Repeat ablation | | Segmental | 6 mo | 7 | 40
| | | LA Ablation | 6 mo | 0 | 40

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

* Unclear about extra patient (35+4=39)

ALSO DATA ON FREEDOM FROM AFIB AFTER REPEAT PROCEDURE.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | No
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 1 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Oral, 2003 US 14557355 | | | No complications (other than AFL) No PV stenosis

PREDICTORS OF OUTCOMES

Multivariable Cox regression

LAD (presumably larger) and use of segmental ostial ablation were independent predictors of recurrent PAF (P<.01, both).

Age, sex, symptom duration, symptom frequency, structural heart disease, LVEF were NS (>.05)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Oral, 2003 US 14557355 | Yes | nd | nd | Yes (0%) | nd | Yes (0%) | Yes | Yes | No There seems to be a missing recurrent patient | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | No | No
Explanation for Overall Quality Grade: | | | | Symptomatic. Missing patient (35+4=39, not 40; 88%+10%=98%).

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Oral, 2003 US 14557355 | | Moderate
Explanation for Applicability Grade: | | Paroxysmal only.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Oral 2004a Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Oral, 2004 US 15089987 | | | | X | | TT/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Oral, 2004 US 15089987 | Symptomatic, drug-refractory paroxysmal AF | nd | nd | nd | The left superior, left inferior, and right superior PVs were targeted in all patients, but the right inferior PV was targeted in only 41% of patients.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Oral, 2004 US 15089987 | Ellen and Robert Thompson Atrial Fibrillation Research Fund | Segmental ostial ablation | 188 | 100 | 53 | 81 | 7.4 | nd | 3.9 | 0.55 | C | Moderate

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Oral, 2004 US 15089987 | yes | 96%* [nd] | nd | No | nd | nd | nd | nd

* Unit of analysis is most likely to be PV, not individual patient.

Of note, the methods refer to previous articles. I don't think that we can assume the same catheter tip. So, leaving the above blank is likely the correct thing to do.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | No*
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 1 mo

* An event recorder was provided only to patients with symptoms.

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Vagotonic paroxysmal AF | Oral, 2004 US 15089987 | Freedom from recurrent AF | Freedom from symptomatic AF relapse at 1 year | Segmental ostial ablation | 15 | nd | 22 | 50% | nd | -
Adrenergic paroxysmal AF | Oral, 2004 US 15089987 | Freedom from recurrent AF | Freedom from symptomatic AF relapse at 1 year | Segmental ostial ablation | 15 | nd | 30 | 83% | nd | 0.02 (?)
Random episode paroxysmal AF | Segmental ostial ablation | nd | 136 | 69% | nd | 0.05 (?)
Vagotonic paroxysmal AF | Oral, 2004 US 15089987 | Freedom from recurrent AF | Symptomatic AF | Segmental ostial ablation | 15 | nd | 22 | nd | nd | 0.04, 0.07, and 0.3* (Log-rank)
Adrenergic paroxysmal AF | Oral, 2004 US 15089987 | nd | Symptomatic AF | Segmental ostial ablation | 15 | 30 | | | nd | 0.04, 0.07, and 0.3* (Log-rank)
Random episode paroxysmal AF | | nd | 136

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

* Vagotonic vs. adrenergic, vagotonic vs. random, and random vs. adrenergic, respectively.

PREDICTORS OF OUTCOMES

Multivariable Cox regression

Vagotonic AF was the only independent predictors of recurrent PAF (P=0.03).

Age, sex, symptom duration, symptom frequency, structural heart disease, LVEF, and LAD were NS (>.05)

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)

No AEs reported.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Oral, 2004 US 15089987 | No | NA | NA | Yes (0%) | nd | nd | Yes** | Yes | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | No | No | nd | No | NA
Explanation for Overall Quality Grade: | | | | Retrospective study

* observational study cannot be an A, retrospective study is always a C

** Variable (especially statistical test is unclear about freedom of relapse AF at 1year)

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Oral, 2004 US 15089987 | | X
Explanation for Applicability Grade: | | Only paroxysmal AF included. Clearly not applicable to other categories.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Oral, 2004 US 15089987 | Overlap of 40 patients of the SOA arm in the Oral 2003 (RefID964, RCT of SOA vs. LACA) cannot completely be excluded but this study was considered to be independent.

Oral 2004b Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Oral 2004 US 15505091 | X | | | | | TT/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Oral, 2004 US 15505091 | Symptomatic, drug-resistant, paroxysmal AF inducible by atrial pacing | nd | nd | Class I or III (8 to 12 weeks) | Only patients with non-terminated or inducible AF after LACA were randomly assigned to no further ablation or additional ablation, which was repeated until AF was terminated and not inducible. Patients whose AF was terminated with LACA and not inducible were observed without further interventions.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Oral, 2004 US 15505091 | Ellen and Robert Thompson Atrial Fibrillation Research Fund; (Biosense-Webster (consultant)) | LACA only (terminated and non-inducible group) | 40 | 100 | 55 | 80 | 7 | nd | 4.3 | 57 | B | Moderate
Oral, 2004 US 15505091 | Ellen and Robert Thompson Atrial Fibrillation Research Fund; (Biosense-Webster (consultant)) | LACA + additional ablation (non-terminated or inducible group) | 30 | 100 | 55 | 80 | 7 | nd | 4.3 | 57 | B | Moderate
LACA only (non-terminated or inducible group) | 30

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Oral, 2004 US 15505091 | Yes | Nd (100% inferred) [>80% reduction in the local electrogram amplitude or reaching the predefined total ablation time of 40 sec. Additional RFAs performed within the circles wherever the local electrogram amplitude showed >0.2 mV] | LACA Posterior LA lines connecting circles and mitral isthmus line (all patients) LA septum (n=23), roof (n=14), posterior mitral annulus (n=7), anterior wall (n=21), and other additional lines (only patients assigned to the LACA + additional ablation arm) | Yes | 8 mm (Navistar) | 70 W max | 55° target | 43 min (LACA only) 25 min (additional lines)

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Oral, 2004 US 15505091 | Freedom from recurrent AF | Freedom from AF relapse in the absence of AAD at 6 mo | LACA only (terminated and non-inducible group) | 8 | Nd | 70 | 85% | Nd | 0.02 (Log-rank) | nd | nd | nd
Oral, 2004 US 15505091 | Freedom from recurrent AF | Freedom from AF relapse in the absence of AAD at 6 mo | LACA + additional ablation (non-terminated or inducible group) | | | | | | 0.02 (Log-rank) | nd | nd | nd
LACA only (non-terminated or inducible group) | 8 | nd | 30 | 67% | Nd
Oral, 2004 US 15505091 | Re-procedure | Nd | LACA only (terminated and non-inducible group) | 8 | 0 | 100 | 0% | nd
Oral, 2004 US 15505091 | Re-procedure | Nd | LACA + additional ablation (non-terminated or inducible group) | 8 | 0 | 100 | 0% | nd
LACA only (non-terminated or inducible group)

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | No*
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 6 weeks

* An event recorder was provided only to patients with symptoms.

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Oral, 2004 US 15505091 | LACA only (terminated and non-inducible group) | 8 | nd | nd | nd | nd | nd | nd | Atrial Flutter | 21/100 (21%)
Oral, 2004 US 15505091 | LACA + additional ablation (non-terminated or inducible group) | 8 | nd | nd | nd | nd | nd | nd | Atrial Flutter | 21/100 (21%)
LACA only (non-terminated or inducible group)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Oral, 2004 US 15505091 | Yes | nd | nd | Yes (0%) | nd | Yes | Yes | nd | Yes | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | Yes | No | NA
Explanation for Overall Quality Grade: | | | | No clear description on how they conduct the study. Only symptomatic relapse taken into account. Non randomized arm combined with a randomized arm in analysis, possibly making the results less straightforward. N<100

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Oral, 2004 US 15505091 | | X
Explanation for Applicability Grade: | | Only paroxysmal AF included. Clearly not applicable to other categories.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Oral, 2004 US 15505091 | 40 patients of LACA only look quite similar to the LACA arm in the Oral 2003 (RefID964, RCT of segmental ostial ablation vs. LACA) but the max energy used (70W vs. 60W in the RCT) and the adoption of inducibility to check procedure endpoint is different; thus, this is considered to be distinct.

Oral 2005 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Oral 2005 US 16253904 | X | | | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Oral 2005 US 16253904 | Chronic AFib | >75 yr, EF<25%, LA thrombus, LAD >6.5 cm | nd | Amiodarone 200 mg/d × 8–12 wk | Chronic AFib = ≥6 mo, no intervening SR, recurred within 1 mo after cardioversion Structural heart disease 16%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Oral 2005 US 16253904 | Ellen and Robert Thompson Atrial Fibrillation Research Fund | LA circumferential ablation | 40 | 0% | 53.5 | 84 | 4.5 yr | nd | 4.8 cm | 53% | C | Moderate
Nonencircling linear ablation | 40

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Oral 2005 US 16253904 | Yes (voltage abatement, WACA) | nd | WACA Lines in the posterior LA between encircling lesions* Line in the mitral isthmus | No, implied** | 8 mm quadripolar (Navistar) | 70* max | 55° target* | 46 min
No (lines only) | NA | Lines along the LA roof, septum, anterior wall, mitral isthmus, and atrial aspect of mitral annulus. Lines transected areas with complex electrograms. 3–5 lines (total) per patient | Yes (rapid atrial pacing) | 35 min P=.01

* To minimize atrioesophageal fistula, posterior line moved to the LA roof, power limited to 40–50 W, target temperature lowered to 45–50°

** In both if AF terminated during ablation, rapid atrial pacing was performed. (However) Termination and noninducibility of AF were not designated endpts of either ablation strategy.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Oral 2005 US 16253904 | AFib recurrence | Confirmed symptomatic (implied) | LACA | 10 | 15 | 40 | | | 0.7
| | | Segmental | | 20 | 40
| AFL (no AFib) | Confirmed symptomatic (implied) | LACA | 10 | 6 | 40 | | | 0.8
| | | Segmental | | 7 | 40
| “Freedom from recurrent AFib and AFL off AAD, 6 mo post-8 wk blanking” * | Confirmed symptomatic (implied) | LACA | 10* | 19 | 40 | | | 0.2
| | | Segmental | | 13 | 40
| Repeat ablation for AFib | | LACA | at 8±5 mo | 7 (of 15 w/AFib) | 40 | | | NS, implied
| | | Segmental | | 11 (or 20) | 40
| Repeat ablation for AFib or AFL | | LACA | nd | 13 | 40
| | | Segmental | | 15** | 40

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

* Primary outcome was “Freedom from recurrent AFib and AFL off AAD, 6 mo post-8 wk blanking” to be measured at 8 months (2 mo blanking + 6 mo), but results report recurrence of AFib and AFl data at a mean f/up of 10±3 mo.

** Plus one patient scheduled to undergo repeat ablation, at the time of writing

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | No, implied
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 8 wk

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Oral 2005 US 16253904 | Both | 10 | No complications

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Oral 2005 US 16253904 | Yes | nd | nd | 0% | nd | Y (all included) | Yes | NA | Yes, but Timing of reported primary outcome different than data reported | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | No. An event recorder used for symptoms | No
Explanation for Overall Quality Grade: | | | | Study stopped early, Asymptomatic AFib apparently not recorded

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Oral 2005 US 16253904 | | Moderate
Explanation for Applicability Grade: | | Size, (excluded >75 yr)

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Oral 2005 US 16253904 | Original assumptions yielded a power estimation of 74 patients in each group. An interim analysis post 40 patients in each group suggested a power estimation of 365 patients in each group. Therefore “a point of futility was reached” and enrollment was stopped.

Oral 2006a Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Oral, 2006 USA and Italy 16510747 | X | | | | Circumferential PV and additional lines ablation with transient concurrent anti-arrhythmics vs. Only [underlined: transient] AAD (crossover permitted) | TT/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Oral, 2006 USA and Italy 16510747 | Chronic AFib* | - Age < 18 or > 70 years; - Left atrial diameter > 55 mm; - Left ventricular ejection fraction < 30 percent; - Contraindication to amiodarone therapy or anticoagulation with warfarin; - Presence of a mechanical prosthetic valve; - History of a cerebrovascular accident; - Presence of left atrial thrombus on transesophageal echocardiography; - Prior attempt at catheter or surgical ablation for AFib | 11/2002–02/2004 | Amiodarone 200 mg per day (3 mo) | - Amiodarone 200 mg per day (plus cardioversion at 6 weeks for most of the patients) was also discontinued at 3 mo in the control arm.; - Cross-over design: 53 patients in the drug arm (77%) underwent RFA after relapse.

* Chronic AFib was defined as AFib that had been present for more than six moths without intervening spontaneous episodes of sinus rhythm and that recurred within one week after cardioversion.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Oral, 2006 USA and Italy 16510747 | Ellen and Robert Thompson Fibrillarion Research Fund* | LACA + additional lines | 77 | 0 | 56 | 65 | 4.5 | nd | 4.5 | 55 | B | Narrow
Amiodarone (for only 3 mo) | 69

* Other conflict of interest includes Ablation Frontier, Biosense Webster, St. Jude Medical, Guidant, and Medtronic.

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Oral, 2006 USA and Italy 16510747 | Yes | Nd (100% inferred) [Local electrogram amplitude 0.2 mV or less] | Encircling lesions of PVs Roof line Mitral isthmus line Cavotricuspid isthmus line* | No | 8 mm (Navistar) | 70 | 55 | 37**

* Performed in only 55 patients at the discretion of the operators. Unclear as to whether these 55 patients were only those in the RFA arm.

** Time for only circumferential PV ablation

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Oral, 2006 USA and Italy 16510747 | Maintaining Sinus rhythm | In sinus rhythm and free from AF or atrial flutter in the absence of AAD at 12 mo** | LACA + additional lines | 12 | 57 | 77 | 74% | Nd | <0.001 (Fisher's) | nd | nd | nd
Oral, 2006 USA and Italy 16510747 | Maintaining Sinus rhythm | In sinus rhythm and free from AF or atrial flutter in the absence of AAD at 12 mo** | Amiodarone for 3 mo only | 12 | 3 | 69 | 4%** | Nd | | nd | nd | nd
40 | 69 | 58%** | 0.05 (Fisher's)
Oral, 2006 USA and Italy 16510747 | Re-intervention | Re-procedure of ablation due to relapse of AF or atrial flutter | LACA + additional lines | 12 | 25 | 77 | 32%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

** The way to analyze the outcome seems quite different from other studies. Also, crossover to RFA in relapsed patients was allowed. It is unclear why relapse free (AF only instead of AF + Aflutter?) crude % without AAD for AAD arm is reported as 58% (40/69) in contrast with the 4% in analysis similar to others.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes*
Was a blanking period (time when AFib episodes were not recorded) used? | Nd/no | If yes, how long was it? | NA

* Event monitor for one year to record the rhythm for 3 min at least 5 days/week or if symptoms, regular ECG and echocardiogram at 3, 6, and12 mo.

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Oral, 2006 USA and Italy 16510747 | LAD size* | LAD size at 12 mo | cm | LACA + additional lines | 12 | 77 | 4.5 | 4.0 | Nd | <0.001 (t-test)*
Amiodarone for 3 mo only | 12 | 69 | 4.5 | 4.5
Oral, 2006 USA and Italy 16510747 | LVEF* | LVEF at 12 mo | % | LACA + additional lines | 12 | 77 | 55 | 62 | nd | <0.001 (t-test)*
Amiodarone for 3 mo only | 12 | 69 | 56 | 55

Duplicate one row per outcome and per RFA intervention.

* Only measured size at 12 mo was considered, not the difference between before procedure (baseline) and after 12 mo (final).

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Oral, 2006 USA and Italy 16510747 | LACA + additional lines | 12 | 0 | 0 | 0 | 0 | 0 | 0 | Atypical atrial flutter* | 5/77 (6%)
Oral, 2006 USA and Italy 16510747 | LACA + additional lines | 12 | 0 | 0 | 0 | 0 | 0 | 0 | Sick sinus syndrome** | 1/77 (1%)
Oral, 2006 USA and Italy 16510747 | Pneumonia** | 1/77 (1%)
Amiodarone (for only 3 mo) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | Sick sinus syndrome** | 1/69 (1%)

* The authors inferred that these atypical atrial flutters were associated with ablation procedure.

** The authors considered these adverse events to be unrelated with either ablation procedure or anti-arrhythmics. All the reported patients with SSS needed a permanent pacemaker, and the patients developing pneumonia, who had nonischemic cardiomyopathy, died of the pneumonia.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Oral, 2006 USA and Italy 16510747 | Yes | nd | nd | Yes, 0% | Yes | Yes | Yes | No | No# | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes** | No | Yes*** | Yes****
Explanation for Overall Quality Grade: | | | | Some item not reported and possible confounders not adjusted.

* observational study cannot be an A, retrospective study is always a C

# See rhythm control part (some unclear reporting's)

** More than three seconds recorded by event monitor evaluated by blinded interpreters.

*** Event monitor for one year to record the rhythm for 3 min at least 5 days/week or if symptoms, regular ECG and echocardiogram at 3, 6, and12 mo.

**** Compliance of 85%.

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Oral, 2006 USA and Italy 16510747 | X
Explanation for Applicability Grade: | | Only patients with chronic Afib.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Oral, 2006 USA and Italy 16510747 | - Re-procedure in 25 patients (32%) in the RFA arm and crossover RFA in 53 patients (77%) in the control arm.; - Crossover design.; - The way investigators calculated freedom from arrhythmia appears unique.; - One patient in the RFA arm and 25 patients in the control arm continued amiodarone after the predefined period.

Oral 2006b Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Oral, 2006 USA 16606789 | | | | X | A cohort study of Individualized stepwise RFA approach | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Oral, 2006 USA 16606789 | Symptomatic paroxysmal AF | Prior ablation | nd | 8 weeks*

* Only 90 out of 153 patients (59%) due to either prior use or early relapse.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Applicability
Oral, 2006 USA 16606789 | Ablation Frontiers (founder, stockholder, and consultant) and Biosense-Webster (consultant) | Tailored stepwise RFA* | 153 | 100 | 56 | 72 | 7 | nd | 4.1 | 57

* 1) PVI, targeted ablation of arrythmogenic fascicle, or WACA/LACA of tachycardia-inducible PV(s) by pacing in the PV(s), 2) Ablation of CFAEs in the LA, CS, and/or SVC if AF is still inducible by atrial pacing.

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Oral, 2006 USA 16606789 | No | NA ** | Ostial (focal or segmental) ablation or WACA/LACA (as a first step) CFAEs in the LA, CS, and/or SVC (as a second step) | Yes* | 8 mm (Navistar) | 35 (CS and critical sites near the esophagus in the LA) 70 (LA in general) | 45 (critical sites near the esophagus in the LA) 50 (CS and LA in general) | 32

* Endpoint of the procedure.

** Although complete isolation of PVS was not a required endpoint elimination of all PV tachycardias was required.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Oral, 2006 USA 16606789 | Freedom from AF and atrial flutter | Absence of recurrent AF or atrial flutter (not fully defined) in the absence of AAD from 8-week blanking period in which some took AAD) | Tailored stepwise RFA | 11 | 118 | 153 | 77%**
Oral, 2006 USA 16606789 | Repeat procedure | Not fully defined | Tailored stepwise RFA | 11 | 28 | 153 | 18%**

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

** Most likely crude estimates (no mention about K-M method).

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 8 weeks

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
AF non-inducible after procedure | Oral, 2006 USA 16606789 | Freedom from AF and atrial flutter | Absence of recurrent AF or atrial flutter (not fully defined) in the absence of AAD from 8-week blanking period in which some took AAD) | Tailored stepwise RFA | 11 | (77) | 88 | 88%* | Nd | 0.003 (Chi-squared)
AF inducible after procedure | (43) | 65 | 66%* | Nd

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

* Should be crude estimates (no mention about K-M method).

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Oral, 2006 USA 16606789 | Tailored stepwise RFA | 11 | nd | 2/180* (1%) | 2/180* (1%)** | nd | nd | nd | nd

* 180 procedures including 153 first procedures and 27 second procedures for relapse in total 153 patients.

** Transient neurological events without any sequelae at discharge.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Oral, 2006 USA 16606789 | No | NA | NA | Unclear** | nd | nd | No | No | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | Yes | Yes | Yes (30%)
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

** Explicitly stated as “no patient was lost to follow-up”; however, follow-up period was reported as 11 months with the SD of 4months.

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Oral, 2006 USA 16606789 | | Moderate
Explanation for Applicability Grade: | | Only those with paroxysmal AF

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Oral 2006c Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Oral, 2006 US 16908760 | | | | X | | TT/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Oral, 2006 US 16908760 | Patients with AF who underwent LA-RFA at the University of Michigan Medical Center from January 2003 to July 2005 | nd | 01/2003–07/2005 | ADD discontinued at 2 to 3 mo after ablation unless the patients were still having AF

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Oral, 2006 US 16908760 | Ablation Frontiers (stockholder and consultant), Biosense-Webster (consultant) | LACA or “tailored” approach* | 755 | 65 | 55 | 76 | 6 | nd | 4.3 | 0.56 | C | Wide

* 1) PVI, targeted ablation of arrythmogenic fascicle, or LACA of tachycardia-inducible PV(s) by pacing in the PV(s), 2) Ablation of CFAEs in the LA, CS, and/or SVC if AF is still inducible by atrial pacing.

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Oral, 2006 US 16908760 | Nd | Nd [nd] | Nd Circumferential PV ablation N 603 Left atrial RFA N 226 | nd | nd | nd | nd | nd

Details were described above (per previous reports).

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Oral, 2006 US 16908760 | Early ischemic stroke | Ischemic stroke with in 30 days from RFA | LACA or “tailored” approach | 25 | 7 | 755 | 0.9% | nd | nd | nd | nd | Nd
Oral, 2006 US 16908760 | Late ischemic stroke | Ischemic stroke after 30 days from RFA** | LACA or “tailored” approach | 25 | 1 | 755 | 0.1% | nd | nd | nd | nd | Nd
Oral, 2006 US 16908760 | Hemorrhagic stroke | Hemorrhagic stroke after RFA*** | LACA or “tailored” approach | 25 | 2 | 755 | 0.3% | nd | nd | nd | nd | Nd

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

** Renal infarct case (n=1) was excluded

*** Developed at 1 and 3 mo.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 2 months

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
1 or more risk factors for thromboembolic events | Oral, 2006 US 16908760 | Freedom from thromboembolic events | Freedom from thromboembolic events at 1 year from RFA | LACA or “tailored” approach | 25 | 6 | 411 | 99% | Nd | 0.69 (Log-rank)**
No risk factor for thromboembolic events | Oral, 2006 US 16908760 | Freedom from thromboembolic events | Freedom from thromboembolic events at 1 year from RFA* | LACA or “tailored” approach | 25 | 3 | 344 | 99% | Nd
Paroxysmal AF | Oral, 2006 US 16908760 | Freedom from relapse (1y) | Freedom from relapse of AF or atrial flutter in the absence of AAD at 1 year from RFA | LACA or “tailored” approach | 25 | nd | 490 | 77% | Nd | 0.001 (Log-rank)
Chronic AF | Oral, 2006 US 16908760 | Freedom from relapse (1y) | Freedom from relapse of AF or atrial flutter in the absence of AAD at 1 year from RFA | LACA or “tailored” approach | 25 | nd | 265 | 66% | Nd
Paroxysmal AF | Oral, 2006 US 16908760 | Freedom from relapse (2y) | Freedom from relapse of AF or atrial flutter in the absence of AAD at 2 year from RFA | LACA or “tailored” approach | 25 | nd | 490 | 73% | Nd | nd
Chronic AF | Oral, 2006 US 16908760 | Freedom from relapse (2y) | Freedom from relapse of AF or atrial flutter in the absence of AAD at 2 year from RFA | LACA or “tailored” approach | 25 | nd | 265 | 62% | Nd
Paroxysmal AF | Oral, 2006 US 16908760 | Freedom from relapse (2y) | Freedom from relapse of AF only in the absence of AAD at 2 year from RFA | LACA or “tailored” approach | 25 | nd | 490 | 77%*** | Nd | 0.01 (Log-rank)
Chronic AF | Oral, 2006 US 16908760 | Freedom from relapse (2y) | Freedom from relapse of AF only in the absence of AAD at 2 year from RFA | LACA or “tailored” approach | 25 | nd | 265 | 68%*** | Nd

Duplicate one row per outcome and per RFA intervention.

* Only one renal infarct case was included. Not freedom from stroke.

** Compared with hypothetical control group extrapolated from Framingham cohort.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

*** Relapse rates were reported in the paper but converted.

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Oral, 2006 US 16908760 | LACA or “tailored” approach | 25 | nd | nd | 10/755 (1%)* | nd | nd | nd

* 7 early ischemic strokes (<30 days), 1 late ischemic stroke (>30 days), and 2 hemorrhagic strokes (at 1 and 3 mo) were reported (see the results section).

AVOIDING ANTICOAGULATION (maybe not relevant question in this study; not compared to ADD per final work plan)

Cox regression analysis found age>65 and prior stroke/TIA were independent factors not to predict discontinuation of anticoagulation therapy (p<0.001)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Oral, 2006 US 16908760 | No | NA | NA | No** | Nd/NA | Nd/NA | Yes | No | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | No | Yes | Nd** | Yes | No
Explanation for Overall Quality Grade: | | | | Retrospective design

* observational study cannot be an A, retrospective study is always a C

** reported minimum follow-up period was 10 mo.

*** Inferred yes as definition of outcome was freedom from recurrent AF (and atrial flutter).

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Oral, 2006 US 16908760 | | | X
Explanation for Applicability Grade: | | 755 patients probably from the institutional registry including paroxysmal and chronic

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Oral, 2006 US 16908760 | Unclear if there is overlap with studies from the University of Michigan Medical Center (at least Oral 2003 (Ref ID 964), Oral 2006 (Ref ID 483), and Oral 2006 (Ref ID 459)

Pak Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Pak 2008 Korea 18284506 | | x | | | KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Pak 2008 Korea 18284506 | PAF; identified arrhythmogenic PVs | PAF with bilateral or non-detectable arrhythmogenic PVs; non-PV foci; and others | nd | none; AADs in those with recurrences after 2 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Pak 2008 Korea 18284506 | Frontier R&D grant | selective or all 4 PVI | 77 | 100 | 52 | 74 | 5 | | 3.9 | 57 | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Pak 2008 Korea 18284506 | y | Selective PVI only in PV with triggering AF vs. PVI in all 4 PVs (elimination of all potentials confirmed) | | y | 5 mm (EP Technology) | 35 | 55 | 51 (Se) vs. 127 (all 4)

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Pak 2008 Korea 18284506 | Freedom from AF recurrence (after 1 ablation, not on AAD?) | | Selective PVI | 39 mo (total followup duration) | 26 | 42 | 62%
| | | All 4 PVI | | 26 | 35 | 74% | | NS
| Reablation | | Selective PVI | | 13 | 42 | 31%
| | | All 4 PVI | | 8 | 35 | 23%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 2 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Pak 2008 Korea 18284506 | Selective PVI | | 60% stenosis, 1/42 (2.4%) | | TIA, 1/42 (2.4%)
| All PVI | | | 2/35 (5.7%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Pak 2008 Korea 18284506 | n | NA | NA | y | nd | n | y | n | n | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | y | y | n
Explanation for Overall Quality Grade: | | | | C; unclear how patients were selected into respective groups

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Pappone 2003 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Pappone, 2003 Italy 12875749 | | | | X* | Circumferential PV ablation vs. Medical management | TT/AG

* Patients' data were “prospectively’ recorded (but most likely analyzed retrospectively). Also, includes Pappone 2001 (RefID 1211) and Pappone 2001 (RefID 1230)

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Pappone, 2003 Italy 12875749 | - Two or more previous ineffective trials with antiarrhythmic drugs; - More than 2 AF-related hospital admissions during the 2 years before entering the study; - Two or more years of AAD treatment | - Contraindication to anticoagulation; - New York Heart Association functional class IV; - Myocardial infarction or cardiac surgery within the past three moths; - Sick sinus syndrome or atrioventricular conduction disturbances without an artificial pacemaker; - Ventricular tachyarrhythmias; - Thyroid dysfunction; - Unsuccessful cardioversion to SR by drugs and/or electroshock | 01/1998–03/2001 | 3 mo (only 115 patients (20%) who had in-hospital Afib and/or needed DC cardioversion after the procedure were prescribed) | “RFA” group had less favorable patient profiles than “medical” group: longer duration of AFib (5.5 years vs. 3.6 years, p<0.001) and more AADs tried (3.1 vs. 2.3, P<0.001).

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Pappone, 2003 Italy 12875749 | nd | Circumferential PV ablation | 589 | 70 | 65 | 58 | 4.6* | Nd** | 4.6 | 54 | C | Moderate
Medical | 582

* Significantly different (5.5 for RFA and 3.6 for Medical, p<0.001(t-test)).

** Mean NYHA class 1.3 for RFA and 1.2 for medical.

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Pappone, 2003 Italy 12875749 | Yes | Nd (100% inferred)* [Elimination of PV ostial potentials and absence of discrete electrical activity inside the lesion during pacing outside the ablation line, or voltage abatement inside and around the encircled areas] | Nd** | No | nd | Nd*** | Nd**** | 59

See Pappone et al. Circulation 1999, 2000, and 2001for more details per report.

* 75% for post-procedure remapping (1: low peak-to-peak bipolar potentials (<0.1 mV) inside the lesion and 2: a local activation time > 30 ms between contiguous points lying in the same axial plane across the line) although the target to terminate energy delivery was reduction of the local potential amplitude by 80% (Pappone 2001 (RefID 1230)) and 82% for electrical activity (< 0.01 mV) in which unit of analysis was each PV (Pappone 2001 (RefID 1211))

** None (Pappone 2001 (RefID 1230))

*** 50 W (Pappone 2001 (RefID 1211))

**** 60°C (Pappone 2001 (RefID 1211 and RefID 1230))

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Pappone, 2003 Italy 12875749 | AF-free survival | Symptomatic AF lasting more than 10 min confirmed by ECG | Circumferential PV ablation | 30** | 469 | 589 | HR=0.30*** | 0.24–0.37 | <0.001 | nd | nd | nd
Medical | 30** | 242 | 582
Pappone, 2003 Italy 12875749 | Congestive heart failure | nd | Circumferential PV ablation | 30** | 32 | 589 | Nd**** | nd | nd | nd | nd | nd
Medical | 30** | 57 | 582
Pappone, 2003 Italy 12875749 | Stroke | TIA, ischemic stroke, and hemorrhagic stroke | Circumferential PV ablation | 30** | 14 | 589 | Nd**** | nd | nd | nd | nd | nd
Medical | 30** | 49 | 582
Pappone, 2003 Italy 12875749 | Overall survival | Survival from any cause of death | Circumferential PV ablation | 30** | 551# | 589 | Nd***** | nd | <0.001 | nd | nd | nd
Medical | 30** | 499# | 582
Pappone, 2003 Italy 12875749 | Adverse event-free survival | Survival free from any adverse event (unclear about how death was dealt with) | Circumferential PV ablation | 30** | 523# | 589 | HR=0.45****** | 0.31–0.64 | <0.001 | nd | nd | nd
Medical | 30** | 484# | 582

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

** Median

*** Freedom from recurrent AF at 1, 2, and 3 years were: 84%, 79%, and 78% for ablation, respectively, and 61%, 47%, and 37% for medical management, respectively.

**** Neither crude estimate nor Kaplan-Meier estimate reported.

***** Overall survival at 1, 2, and 3 years were: 98%, 95%, and 92% for ablation, respectively, and 96%, 90%, and 86% for medical management, respectively.

****** Adverse event-free survival at 1, 2, and 3 years were: 97%, 94%, and 91% for ablation, respectively, and 93%, 87%, and 81% for medical management, respectively.

# Either death or adverse event was reported in the paper.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes*
Was a blanking period (time when AFib episodes were not recorded) used? | No | If yes, how long was it?

* Standard ECG, echocardiogram, and Holter at 1, 3, 6, 9, and 12, 18, 24... mo or on symptom. Also, transtelephonic monitoring.

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Pappone, 2003 Italy 12875749 | Arrhythmia burden | The number of relapse episodes after the first recurrence | Times/patient-year | RFA | nd | Nd | 0 | 2.1 | RR=0.38 (95%CI, 0.32–0.56) (Poisson distribution) | nd
Medical | Nd | nd | 0 | 5.4
Pappone, 2003 Italy 12875749 | QOL | SF-36, physical component summary score | Score | RFA | 12 | 109 | 39 | 49 | Nd | Nd*
Medical | 12 | 102 | 40 | 41
Pappone, 2003 Italy 12875749 | QOL | SF-36, mental component summary score | Score | RFA | 12 | 109 | 42 | 50 | nd | Nd*
Medical | 12 | 102 | 42 | 43

Duplicate one row per outcome and per RFA intervention.

* Adjusted p<0.01 (statistical test unclear)

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
LAD > 4.5 cm | Pappone, 2003 Italy 12875749 | Recurrence | Symptomatic episode lasting more than 10 min confirmed by ECG | RFA | 30** | nd | nd | nd | nd | nd | HR=3.37 | 2.19–5.19
Reduced encircled ablation area | Pappone, 2003 Italy 12875749 | Recurrence | Symptomatic episode lasting more than 10 min confirmed by ECG | RFA | 30** | nd | nd | nd | nd | nd | HR=3.58 | 2.41–5.32

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Recurrent Afib | Pappone, 2003 Italy 12875749 | Changes in hospitalization | Changes in hospitalization rates from 2 years before entering the study | Times/patient-year | RFA | nd | Nd | Nd | Nd | -0.7 (95%CI, -1.9 to 0.2)* | 0.04*
Medical | nd | nd | Nd | Nd | 0.5 (95%CI, -0.7 to 2.8)* | 0.43*
Non-recurrence | Pappone, 2003 Italy 12875749 | Changes in hospitalization | Changes in hospitalization rates from 2 years before entering the study | Times/patient-year | RFA | nd | Nd | Nd | Nd | -1.8 (95%CI, -4.7 to -0.7)* | <0.001*
Medical | nd | nd | nd | Nd | -1.2 (-2.9 to -0.8)* | 0.01*
Recurrent Afib | Pappone, 2003 Italy 12875749 | Changes in LAD size | Changes in LAD size between before and after therapy | cm | RFA | nd | Nd | Nd | Nd | -0.5 (95%CI, -1.0 to 0.1)* | Nd*
Medical | nd | nd | Nd | Nd | -0.2 (95%CI, -0.5 to 0.1)* | Nd*
Non-recurrence | Pappone, 2003 Italy 12875749 | Changes in LAD size | Changes in LAD size between before and after therapy | cm | RFA | nd | Nd | Nd | Nd | -1.1 (95%CI, -1.5 to -0.8)* | <0.01*
Medical | nd | nd | nd | Nd | -0.3 (95%CI, -0.5 to -0.04)* | <0.01*

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

* Difference between before and after therapy in each subgroup in each therapy, not net difference between RFA and medical.

Although this is not a subgroup analysis (but rather one of the data explorations by multiple univariate analyses), in patients with permanent AF, those without relapse had statistically significantly smaller LAD than those with relapse at baseline and follow-up (<0.001 for both; however, statistically significance not shown in the other report (Pappone 2001 (RefID1211))). Age, AF duration, number of patients with structural heart disease, and EF had no statistically significant difference between relapse (+) group and relapse (-) group. (Pappone 2001 (RefID1230)).

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Pappone, 2003 Italy 12875749 | RFA | 30* | 0 | 4/589 (1%) | 0 | nd | nd | nd

* Median

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Pappone, 2003 Italy 12875749 | No | NA | NA | Yes, 2% | nd | NA | Yes | Yes** | No | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | No | Yes | Nd (inferred yes) | Yes | No
Explanation for Overall Quality Grade: | | | | Observational study

* observational study cannot be an A, retrospective study is always a C

** Some (not for recurrence of AFib, etc.)

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Pappone, 2003 Italy 12875749 | | X
Explanation for Applicability Grade: | | Unclear about why included patients were sent to this institution

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Pappone, 2003 Italy 12875749 | A large multi-center observational (retrospective case series) study. Survival and morbidity were mainly featured (some of which did not apply to our focused question). Unclear about blanking period.

Pappone 2004a Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Pappone, 2004 Italy 14707026 | | | | X | | TT/AG

NOTE: should partially overlap the Pappone 2003 (RefID 1015), which includes the Pappone 2001 and 2001 (RefID 1211 and 1230)

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Pappone, 2004 Italy 14707026 | Paroxysmal AF | Sinus node disease, AV block, or permanent pacing 5% premature complexes on Holter monitoring Recent myocardial infarction (< 6 moths) LVEF < 45%. Beta-blocker therapy, Diabetes mellitus, renal failure, or thyroid dysfunction | 01/1999–04/2002 | Nd | 297 (63%) out of 470 consecutive patients with paroxysmal AF who underwent circumferential PV ablation

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Pappone, 2004 Italy 14707026 | nd | Circumferential PV ablation | 297 | 100 | 49 | nd | 7.0 | nd | 3.9 | 58 | C | Moderate

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Pappone, 2004 Italy 14707026 | nd | nd | CPVA Two additional LA lines - posterior LA and Mitral isthmus line Ablation of autonomic targets (only if identified)* (n=102) Pts with h/o AFL - RFA | nd | nd | 40–85 | 60 | 61

* Vagal target sites were identified through the induction of vagal reflex during ablation, at which RF energy was delivered until such reflexes were abolished or for up to 30 seconds. Complete denervation was achieved in 98% (100/102). CPVA details previously described (2001 article).

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Pappone, 2004 Italy 14707026 | Freedom from recurrent AF | AF lasted at least 30 sec, after 1 week blanking period | Circumferential PV ablation | 12 | 267 | 297 | 90% | nd | nd | nd | nd | Nd

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes*
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 1 week

* Transtelephonic ECG once monthly until 12 mo.

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Circumferential PV ablation + denervation | Pappone, 2004 Italy 14707026 | Freedom from recurrent AF | AF lasted at least 30 sec, after 1 week blanking period | Circumferential PV ablation + denervation | 12 | 101 | 102 | 99% | nd | <0.001 (log-rank) | nd | nd | Nd
Circumferential PV ablation only | Circumferential PV ablation only | 12 | 166 | 195 | 85% | nd | nd | nd | Nd

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

Success of denervation (complete denervation) and %LA isolation were two statistically significant predictive factors to predict success of ablation (no relapse) in multivariate analysis by the Cox regression (p=0.025, HR=0.025 (95% CI, 0.014–0.750) and p<0.001, HR=0.72 (CI, 0.66–0.80), respectively). Age, Sex, AF duration, EF, LAD, %LA isolation, complete denervation, and structural heart disease were the analyzed covariates.

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)

Not reported

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Pappone, 2004 Italy 14707026 | No | NA | NA | Yes (0%) | NA | NA | Yes | Yes | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | No | Yes | Nd** | Yes | No
Explanation for Overall Quality Grade: | | | | Observational study

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

** Data on prior procedure or re-procedure not provided; thus unclear.

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Pappone, 2004 Italy 14707026 | | Moderate
Explanation for Applicability Grade: | | 297 (63%) out of 470 consecutive patients with paroxysmal AF who underwent circumferential PVI; thus some patients were excluded.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Pappone 2004b Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Pappone 2004 Italy 15520310 | x | | | | Circumferential Pulmonary Vein Ablation (CPVA) vs. modified CPVA; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Pappone 2004 Italy 15520310 | 18–70 y; symptomatic AF; NYHA I or II | Left atrial size>55 mm; LVEF <30%; recent MI; preexisting atrial tachycardia (AT) or flutter; and others | 1/2002–1/2003 | none

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Pappone 2004 Italy 15520310 | nd | CPVA | 280 | 63% | 56.5 | 52 | 7.2 | nd (?) | 3.95 | nd | A | moderate
CPVA-mod | 280

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Pappone 2004 Italy 15520310 | n | | CPVA: encircling lines at a distance >15 mm from PV ostia when possible with ipsilateral intravenous lines CPVA-mod: above + 2 additional lines (posterior LA connecting the contralateral superior & inferior PVs; along mitral isthmus between inferior aspect of left encircling line and the mitral annulus) Endpoint was voltage abatement of the local atrial electrogram by 80% or <0.1 mV. Completion of connecting lines assessed pre and post ablation activation and voltage maps. | n | 8 mm | 100 | 60 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Pappone 2004 Italy 15520310 | primary | freedom from symptomatic incessant AT (continuous sequence of atrial activation; activation times >90% of the tachycardia cycle length; demonstration of entrainment by pacing) | CPVA | 12 mo | 252 | 280 | 90%
| | | CPVA-mod | | 269 | 280 | 96% | | 0.005 (log rank)
| secondary | freedom from recurrent AF | CPVA | 12 mo | | | 85.7%
| | | CPVA-mod | | | | 87.1% | | 0.57

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 6 wk

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
The presence of multiple gaps (gaps in a single PV were defined as a single gap and as multiple gaps if >1 PV) and chronic AF were the strongest predictors of AT: CPVA adj HR 3.84 (95%CI 1.86– 7.89); multiple gaps adj HR 25.19 (95%CI 11.01–57.30); chronic AF adj HR 22.28 (6.72–73.87); all P<0.001

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Pappone 2004 Italy 15520310 | CPVA | | 0/280 | 2/280 (0.7%) | 0/280 | | | | access site hematoma | 3/280 (1.1%)
| CPVA-mod | | 0/280 | 2/280 (0.7%) | 0/280 | | | | access site hematoma | 2/280 (0.7%)
| CPVA or CPVA-mod | | | | | | | | AT leading to syncope | 8/560 (1.4%)
| CPVA or CPVA-mod | | | | | | | | AT leading to syncope leading to cardioversion | 5/560 (0.9%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Pappone 2004 Italy 15520310 | y | y | y | y | y | y | y | NA | y | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | unclear | y | y
Explanation for Overall Quality Grade: | | | | result included patients with reablation

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Pappone 2004 Italy 15520310 | | X
Explanation for Applicability Grade: | | relatively young patients, NYHA I or II

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Pappone 2006 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Pappone 2006 Italy 17161267 | X | | | | CPVA vs. AAD; KQ 1, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Pappone 2006 Italy 17161267 | Paroxysmal AF with failed AADs; >18 or <70 y; creatinine <1.5 mg/dL; AF history > 6 mo; AF > 2 episodes/mo in the last 6 mo | LAD >65 mm; LVEF <35%; CHF>NYHA class II; prior amiodarone, flecainide, or sotalol; prior catheter or surgical ablation; and others (see text) | 2005 | 6 wk | patients could be considered for crossover to CPVA after 2 trials of AAD

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Pappone 2006 Italy 17161267 | nd | circumferential pulmonary vein ablation | 99 | 100% | 56 | 67 | 6 | nd | 3.9 | 61 | B | moderate
| | flecainide 100 mg q12h; sotalol 80 mg q8h; amiodarone 200 mg/d (maintenance dose) | 99

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Pappone 2006 Italy 17161267 | n* | assessed completeness across mitral isthmus lines (?) Yes - as previously described | circumferential pulmonary vein ablation (CPVA) (Including roof and mitral line) + cavotricuspid isthmus ablation (right sided empiric atrial flutter ablation) | n | 8 mm (50) | 60–100 | 50–65 | 35
irrigated 3.5 mm (49) | 25–40 | 35–40

* Of note, pre and post ablation bipolar voltage maps of LA performed. (as previously described)

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Pappone 2006 Italy 17161267 | primary end point (Kaplan-Meier analysis) | freedom from documented recurrent atrial tachyarrhythmia (lasted ≥ 30 s) | CPVA | 12 mo | 85 | 99 | 86%
| | | AAD | 12 mo | 24 | 99 | 22% | | <0.001
“Among patients assigned to CPVA, 9 summed up 24 hospital admissions for cardiovascular causes, including repeat procedures. In the ADD group, 167 cardiovascular event-related hospital admissions occurred, not including the hospitalizations for crossover to CPVA (p<0.001).”

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 6 wk

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
No independent predictors of AF recurrences were found in the ablation group.
LVEF (HR 1.08, 95% CI 1.03–1.13, P=0.003); HTN (HR 2.31, 95% CI 1.34–3.97, P=0.003); AF duration (HR 1.03, 95%CI 1.01–1.11, P=0.015) were independent predictors of drug failure in AAD group.

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Pappone 2006 Italy 17161267 | 8 mm CPVA | | | | mild TIA 1/99 (1%)
| irrigated tip CPVA | | | | | | | | small pericardial effusion | 1/99 (1%)
| flecainide | | | | | | | | pro-arrhythmia | 3/33 (9%)
| amiodarone | | | | | | | | thyroid dysfunction | 7/33 (2.1%)
| sotalol | | | | | | | | sexual dysfunction | 11/33 (33%)
| | | | | | | | | permanent drug withdrawal 2° to adverse events | 23/99 (23%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Pappone 2006 Italy 17161267 | y | nd | nd | y | n | n | y | NA | y | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | y | y | n
Explanation for Overall Quality Grade: | | | | No descriptions on appropriate randomization technique and allocation concealment

* observational study cannot be an A, retrospective study is always a C

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Pappone 2006 Italy 17161267 | | x
Explanation for Applicability Grade: | | relatively young patients with low NYHA classification

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Piorkowski Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Piorkowski 2008 Germany 18684284 | | | | | “case-control study”: patients (controls) treated with circumferential left atrial PV ablation between October 2004 and December 2005 were matched with subsequent patients (cases) ablated between Jan 2006 and October 2006 | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Piorkowski 2008 Germany 18684284 | Patients (controls) treated with circumferential left atrial PV ablation between October 2004 and December 2005 using a conventional nonsteerable transseptal sheath (Mullins; Cook Inc., Bloomington, IN, USA) were matched with subsequent patients (cases) ablated between Jan 2006 and October 2006 with a similar line concept but mapping and ablation performed with a manually controlled steerable sheath (Agilis, St. Jude Medical, St. Paul, MN, USA). The matching criteria included patient's age, patient's gender, paroxysmal or persistent AF, duration of AF history, previous AF ablations, and underlying cardiac disease. | nd | Controls: October 2004 and December 2005 Cases: Jan 2006 and October 2006 | AAD was discontinued and patients received a beta-blocker (if tolerated) after ablation. In case of early postinterventional AF recurrences within the 2 postinterventional in hospital days, cardioversion was performed and AADs (flecainide or amiodarone) were added for at least 3 months. Afterward the medication was adapted on an individual basis. | Persistent AF=20% Lone AF=53% Prior AF ablation=12%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Piorkowski 2008 Germany 18684284 | nd | circumferential left atrial PV ablation using a conventional nonsteerable transseptal sheath (controls) or a manually controlled steerable sheath (cases) | 166 | 80 | 55 | 73 | 4.4 | nd | 3.7 | 61 | C | Moderate

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Piorkowski 2008 Germany 18684284 | yes | 100% [endpoint of the procedure was the completion of the intended lesion lines with either complete PVI or conduction delay into the PVs] | In patients with persistent AF, additional ablation lines were placed between the circular lesions and along the roof of the left atrium as well as between the circular lesion and the mitral annulus | no | Irrigated tip (F-Type, Navi-Star ThermoCool, Biosense Webster) | Standard: 40 At the posterior LA near to the esophagus: 25 At the anterior aspects of circumferential ablation: 50 | Standard: 50 | Cases: 42 min Controls: 40 min

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Piorkowski 2008 Germany 18684284 | AF recurrences | On or off AADs. Exclude repeat procedures | circumferential left atrial PV ablation using a manually controlled steerable sheath (cases) | 6 | 19 | 79 | | | 0.0009
| | | circumferential left atrial PV ablation using a conventional nonsteerable transseptal sheath (controls) | 6 | 35 | 83

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | yes
Was a blanking period (time when AFib episodes were not recorded) used? | no | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Piorkowski 2008 Germany 18684284 | circumferential left atrial PV ablation using a conventional nonsteerable transseptal sheath (controls) or a manually controlled steerable sheath (cases) | | 0 | 2/166 (1.2%) | | 0 | Vascular access complications = 3/166 (1.8%) | | Phrenic nerve palsy | 0
| | | | | | | | | Thromboembolic event | 1/166 (0.6%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Piorkowski 2008 Germany 18684284 | no | NA | NA | yes | nd | no | yes | yes | yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | yes | yes | yes | no
Explanation for Overall Quality Grade: | | | | Prospective study, non-concurrent control so cannot exclude learning effects

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Piorkowski 2008 Germany 18684284 | | x
Explanation for Applicability Grade: | | Matching controls

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Piorkowski 2008 Germany 18684284 | 4 of the 83 patients (4.8%) underwent reablation between 3 and 6 months of follow-up. They were excluded from the analyses at 6 month of follow-up. The original study compared AE between cases and controls. However the rates of AE reported in this form were re-calculated using all 166 patients (both cases and controls).

Proclemer Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Proclemer 2008 Italy 18667447 | | | | X (only PVI data were extracted; AVJ did not meet inclusion criterion) | KQ 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Proclemer 2008 Italy 18667447 | drug refractory AF | | 2002-2006 | AAD for 3 mo; continued past 3 mo in those with AF recurrences | only used data on adverse events

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Proclemer 2008 Italy 18667447 | nd | PVI | 144 | 65 | 56 | 75 | nd | NYHA III-IV: 6% | | 59 | not rated

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Proclemer 2008 Italy 18667447 | y (implied) | ostial PVI | CVT ablation in pts with AFL | n | 3.5 mm irrigated (7% used 4 mm tip) | 40 | 45 | 39

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Proclemer 2008 Italy 18667447 | Freedom from symptomatic AF | Freedom from symptomatic AF (14% had redo and 40% on AAD) | PVI | 25 mo (median) | 113 | 144 | 78%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 1 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Proclemer 2008 Italy 18667447 | ostial PVI | 25 mo (median) | | 5/144 (3.5%) | 0/144 (0%) | | | 0/144 (0%) | metabolic coma At 5 mo (unrelated to PVI) | 1/144 (0.7%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Proclemer 2008 Italy 18667447 | n | NA | NA | NA | n | n | y | n | n
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | n | n | y | n
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Richter Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Richter, 2008 Richter, 2006 Austria 18328850 17038349 | | | | X (no concurrent comparative groups; comparing 2 cohorts with different recruitment periods) | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Richter, 2008 Richter, 2006 Austria 18328850 17038349 | Patients undergoing catheter ablation of either symptomatic drug-resistant paroxysmal or persistent AF. | Pregnancy, ongoing infections, intracardiac thrombosis, inadequate anticoagulation prior to admission, contraindications to anticoagulation, history of MI or cardiac surgery within the last 3 months, and refusal to give informed consent. Received RFA but excluded from analyses: Post-ablation stimulation test could not be carried out because of inability to achieve stable sinus rhythm despite repeat transthoracic cardioversion after ablation or respiratory failure precluding continuation of the procedure. | May 2002 to April 2004 (Lasso) After April 2004 (CARTO) | Class I or III antiarrhythmic drugs (amiodarone, sotalol, flecainide, and propafenone), if present before ablation, were continued for ≥3 months | Structural heart disease= 22% Mean BMI= 26.6

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Richter, 2008 Richter, 2006 Austria 18328850 17038349 | No financial support for this study | Lasso-guided PVI (n=83) | 234* | 92 | 57 | 72 | 6.1 | nd | 4.5 | 61 | C | Wide
CARTO-guided WACA (n=151) | 57

* No breakdown patient characteristics per intervention was reported

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Richter, 2008 Richter, 2006 Austria 18328850 17038349 | yes | Lasso-guided RFA (n=83): 100% [elimination of all ostial vein potentials and complete entrance block into PVs] | none | yes | 4 mm tip (Biosense Webster Inc.) | 30 | 55 | 22
yes | CARTO-guided RFA (n=151): 100% [80% reduction in the amplitude of the local bipolar electrogram or a total of 40 s of energy delivery] | WACA, Roof line and mitral isthmus line 37 patients with a history or inductility of isthmus-dependent right atrial flutter also underwent ablation of the cavotricuspid isthmus | yes | 8 mm tip (Navistar, Biosense Webster Inc.) | 50 | 55 | 32

Inducible if duration greater than 1 minute.

AF> 5 min DCCV

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Richter, 2006 Austria 17038349 | Freedom from recurrent AF | | Lasso-guided RFA | 6 | 53 | 83
| | | CARTO-guided RFA | 6 | 91 | 151

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes (24 or 48 hr Holter monitoring at follow-up visits)
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | 2 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Early recurrence of AF (within the first 48 hours after ablation) | Richter, 2008 Austria 18328850 | AF-free survival analysis | Multivariate Cox regression analysis (variables included early recurrence of AF, type of AF, sex, age, BMI, antiarrhythmic drug use during follow up, applied ablation technique, structural heart disease, LVEF, left atrial size) | Lasso- or CARTO-guided RFA | 12.7 | | | HR: 2.29 | 1.54–3.42 | <.001 | 2.17 | 1.45–3.25 | <.001
Type of AF (paroxysmal vs. persistent AF) | Richter, 2008 Austria 18328850 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | HR: 1.94 | 1.28–2.93 | .002 | 1.79 | 1.19–2.69 | .006
Sex | Richter, 2008 Austria 18328850 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | HR: 0.9 | 0.57–1.41 | .65 | nd | nd | ns
Age | Richter, 2008 Austria 18328850 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | HR: 0.99 | 0.98–1.01 | .48 | nd | nd | ns
BMI | Richter, 2008 Austria 18328850 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | HR: 1 | 0.95–1.05 | .92 | nd | nd | ns
Antiarrhythmic drug use during follow-up (class I or III) | Richter, 2008 Austria 18328850 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | HR: 0.81 | 0.53–1.27 | .33 | nd | nd | ns
Applied ablation technique | Richter, 2008 Austria 18328850 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | HR: 1.27 | 0.83–1.95 | .28 | nd | nd | ns
Structural heart disease | Richter, 2008 Austria 18328850 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | HR: 0.93 | 0.57–1.53 | .79 | nd | nd | ns
LVEF | Richter, 2008 Austria 18328850 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | HR: 0.97 | 0.59–1.6 | .92 | nd | nd | ns
Left atrial size | | | HR: 1 | 0.97–1.03 | .98 | nd | nd | Ns
Type of AF (paroxysmal vs. persistent AF) | Richter, 2006 Austria 17038349 | AF-free survival analysis | Multivariate Cox regression analysis (variables included type of AF, inducibility of AF, sex, age, BMI, antiarrhythmic drug use during follow up, applied ablation technique, structural heart disease, LVEF, left atrial size) | Lasso- or CARTO-guided RFA | 12.7 | | | HR: 1.94 | 1.28–2.93 | .002 | 1.77 | 1.17–2.67 | .007
Inducibility of AF (inducibility of AF > duration of 1 min) | Richter, 2006 Austria 17038349 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | HR: 2.32 | 1.56–3.47 | <.001 | 2.19 | 1.46–3.27 | <.001
Sex | Richter, 2006 Austria 17038349 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | Same as data reported in Richter, 2008 Austria 18328850 (above)
Age | Richter, 2006 Austria 17038349 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | Same as data reported in Richter, 2008 Austria 18328850 (above)
BMI | Richter, 2006 Austria 17038349 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | Same as data reported in Richter, 2008 Austria 18328850 (above)
Antiarrhythmic drug use during follow-up (class I or III) | Richter, 2006 Austria 17038349 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | Same as data reported in Richter, 2008 Austria 18328850 (above)
Applied ablation technique | Richter, 2006 Austria 17038349 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | Same as data reported in Richter, 2008 Austria 18328850 (above)
Structural heart disease | Richter, 2006 Austria 17038349 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | Same as data reported in Richter, 2008 Austria 18328850 (above)
LVEF | Richter, 2006 Austria 17038349 | AF-free survival analysis | | Lasso- or CARTO-guided RFA | 12.7 | | | Same as data reported in Richter, 2008 Austria 18328850 (above)
Left atrial size
Paroxysmal AF | Richter, 2008 Austria 18328850 | Freedom from recurrent AF | | Lasso- or CARTO-guided RFA | 12.7 | 105 | 165 | | | nd
Persistent AF | 31 | 69
Paroxysmal AF with early AF recurrence | Richter, 2008 Austria 18328850 | Ablation failure | Long-term AF recurrence | Lasso- or CARTO-guided RFA | 12.7 | 30 | 64 | HR: 2.05 | 1.24–3.41 | .005
Paroxysmal AF without early AF recurrence | 30 | 101
Persistent AF with early AF recurrence | Richter, 2008 Austria 18328850 | Ablation failure | Long-term AF recurrence | Lasso- or CARTO-guided RFA | 12.7 | 25 | 37 | HR: 2.35 | 1.2–4.6 | .013
Persistent AF without early AF recurrence | 13 | 32
Early AF recurrence | Richter, 2008 Austria 18328850 | Ablation failure | Long-term AF recurrence | Lasso- guided RFA | 12.7 | 17 | 31 | HR: 2.29 | 1.16–4.55 | .017
Without early AF recurrence | 16 | 52
Early AF recurrence | Richter, 2008 Austria 18328850 | Ablation failure | Long-term AF recurrence | CARTO-guided RFA | 12.7 | 38 | 70 | HR: 2.25 | 1.39–3.69 | .001
Without early AF recurrence | 27 | 81
Paroxysmal AF | Richter, 2006 Austria 17038349 | Freedom from recurrent AF | | Lasso- guided RFA | 6 | 51 | 76 | | | nd
Persistent AF | 2 | 7
Paroxysmal AF | Richter, 2006 Austria 17038349 | Freedom from recurrent AF | | CARTO- guided RFA | 6 | 60 | 89 | | | nd
Persistent AF | 31 | 62

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Richter, 2008 Richter, 2006 Austria 18328850 17038349 | no | NA | NA | Yes (assumed) | nd | Yes (0% dropout) | yes | yes | yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | yes | no | yes | no
Explanation for Overall Quality Grade: | | | | Retrospective. Lasso and CARTO groups were not comparable. However, multivariate analyses controlling for ablation techniques and other confounders are useful.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Richter, 2008 Richter, 2006 Austria 18328850 17038349 | | | x
Explanation for Applicability Grade: | | Wide for CARTO group only. Moderate (due to 92% paroxysmal AF and N<100) for Lesso group (but should be excluded, see reviewer's comment). Wide for both groups combined.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Richter, 2008 Richter, 2006 Austria 18328850 17038349 | No breakdown patient characteristics per intervention were reported. Much more patients in Lasso group were paroxysmal AF than CARTO group (92 vs. 57%). Data applied to Lasso-guided group only should be excluded for our review purpose because 4-mm tip was used in this group.

Rossillo Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Rossillo, 2008 Italy 18268419 | | X | | | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Rossillo, 2008 Italy 18268419 | PVI group: consecutive patients who were referred for ablation of symptomatic drug-refractory AF AAD: age-, sex- and heart disease-matched patients with persistent AF who underwent electrical cardioversion between May 2002 and July 2003. *The risk for stroke (% of medium- and high-risk patients) are similar in both groups. | None reported | PVI group: 2002 to 2004 AAD: 2002 to 2003 | PVI group: no patients received anti-arrhythmic drugs unless arrhythmic recurrences developed during follow-up Controls: all patients were pre-treated with anti-arrhythmic drug, and the treatment was continued or stopped during follow-up according to the referring physician's indications. 29 (34%) patients stopped anti-arrhythmic drug Rx at least 1 month after electrical cardioversion. | 19% vs. 6% (PVI vs. AAD) were low risk for stroke (i.e. age<65, no HTN, DM, CHF or previous CVA), p<0.01

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Rossillo, 2008 Italy 18268419 | nd | PVI | 85 PVI group | 32** | 62 | 84 | 8 (range 1–24) | 72% high risk for stroke* | 4.4 | 58 | C | moderate
85 AAD group | 0 | 62 | 84 | unknown | 76% high risk for stroke* | 4.2 | 56

* High risk: age>65, plus hypertension or diabetes or CHF or previous cerebrovascular accident

** 51% persistent AF; 18% permanent AF

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Rossillo, 2008 Italy 18268419 | yes | 100% [all 4 pulmonary veins were disconnected (Lasso)]* | 72 pts: SVC isolation | no | 8 mm tip catheter (Biosense-Webster) | Energy was controlled by progressively increasing power until scattered microbubbles were observed by ICE | nd | nd

* In addition, complete electrical isolation of the superior vena cava was achieved in 72 patients (85%). The other 13 patients, disconnection was not possible owing to stimulation of the phrenic nerve or proximity of the sinus node to the ablation site.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Rossillo, 2008 Italy 18268419 | Stable sinus rhythm | nd | PVI | 15 | 70** | 85 | | | nd
AAD (antiarrhythmic Rx; electrical cardioversion) | 16 | 34 | 85

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

** In 10 patients, a previous ineffective anti-arrhythmic drug was necessary to maintain stable sinus rhythm

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes, asymptomatic AF was evaluated by means of monthly 24-h Holter recording during the first 3 months of follow-up and daily pulse check.
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | 8 wk

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Rossillo, 2008 Italy 18268419 | PVI | 15 | | | 1/85 (1%)*
AAD (anti-arrhythmic Rx; electrical cardioversion) | 16 | | | 5/85 (5.8%)** | | | 1/85 (1%)***

* stoke occurred just after electrical cardioversion at the end of the PVI procedure in a 74-year-old patient with permanent AF and history of transient ischemic attack

** Intraprocedural stroke (not related to anti-arrhythmic drug discontinuation) is not considered in the analysis. The difference in stroke event between cases and controls were statistically significant (0/84 vs. 5/85, p=0.03). In 2 of the 5 patients had stoke among the controls, the stroke was fatal. See specific comment section for the characteristics of these 5 patients who has stoke.

*** one patient with stroke happened <30 days and died from the stroke

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Rossillo, 2008 Italy 18268419 | no | NA | NA | nd | nd | nd | no | no | no | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | no | yes | no | yes | no
Explanation for Overall Quality Grade: | | | | Week study design for clinical outcomes, PVI and AAD groups were not comparable, poor reporting (except for the adverse events); statistical analyses for adverse events only

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Rossillo, 2008 Italy 18268419 | | x
Explanation for Applicability Grade: | | Mixed types of AF patients for AF but n<100

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Rossillo, 2008 Italy 18268419 | Clinical characteristics of the patients with stroke
Rossillo, 2008 Italy 18268419 | Patient | Group | Age | Gender | Time to Stoke | Rx | ECG at recovery | Death
Rossillo, 2008 Italy 18268419 | 1 | AAD | 70 | Female | <30 days | Warfarin | AF | Yes
Rossillo, 2008 Italy 18268419 | 2 | AAD | 64 | Male | >30 days | Aspirin | AF | No
Rossillo, 2008 Italy 18268419
Rossillo, 2008 Italy 18268419 | 3 | AAD | 70 | Female | >30 days | Warfarin | Sinus rhythm | No
4 | AAD | 71 | Female | >30 days | Warfarin | AF | No
5 | AAD | 73 | Male | >30 days | Aspirin | Sinus rhythm | Yes

Rotter 2005a Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Rotter, 2005 France 16403060 | | | | X (data were collected prospectively per report) | Only adverse events-related data were relevant to our project. | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Rotter, 2005 France 16403060 | - Symptomatic drug-refractory paroxysmal AF; - Paroxysmal AF; - Duration of episode <7 days; - No previous ablation for AF; - No use of amiodarone (< 3 mo) | nd | nd | nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Rotter, 2005 France 16403060 | - Swiss National Foundation for Scientific Research; - Neil Hamilton Fairley and Ralph Reader Fellowship; - National Health and Medical Research Council; - National Heart Foundation of Australia | PV antrum? ablation + additional lines | 181 | 100 | 54 | 85 | 6 | nd | 4.2 | 68 | C | Wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Rotter, 2005 France 16403060 | Yes | 100% [nd] | Cavo-tricuspid isthmus line (n=181)* Mitral isthmus line (n=57)* Roof line (n=58)* | Yes | 3.5 mm irrigated-tip (Celsius ThermoCool or Navistar) | 25–35 (PV antrum ablation) | 50 | 59**
35–40 (additional lines)

* Not mutually excusive

** Difference between with and without additional substrate modification was 20 min (69 and 49, respectively, P<0.001)

Inducibility - three predefined sites: midcoronary sinus, left and right atrial appendage. Patients with AF > 10 min and pts with persisting AF

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

No clinical results of interest reported except for adverse events.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Rotter, 2005 France 16403060 | PV antrum? ablation + additional lines | nd | nd | 2/181 (1%)* | nd | nd | nd | Nd

* Both two cases underwent additional substrate modification.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Rotter, 2005 France 16403060 | No | NA | NA | nd | nd | nd | NA | NA | NA | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | NA | NA | NA | NA
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Rotter, 2005 France 16403060 | | | Wide
Explanation for Applicability Grade: | | Only paroxysmal AF

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Rotter 2005b Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Rotter 2005 France 15741228 | y | | | | Primary endpoint is the reduction of fluoroscopy time by 30% | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Rotter 2005 France 15741228 | Drug refractory symptomatic AF | nd | nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Rotter 2005 France 15741228 | Swiss National Foundation for Scientific Research, National Health Research Council of Australia, National Heart Foundation of Australia | Fluoroscopy-guided PVAI | 37 | Nd^#^ | 52 | 88 | nd | nd | 4.3 | 66 | B | Moderate
Fluoroscopy+NavX-guided PVAI | 35

# Persistent AF was reported as 7%, otherwise, unclear.

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min^#^
Rotter 2005 France 15741228 | y | Elimination or dissociation of the PV potentials as determined by circumferential mapping | Roof-line (LA) if persistent or inducible sustained AF after PVAI (n=18 for NavX arm and n=21 for fluoroscopy arm) | y | 4 mm irrigated | 25–35 (PVAI), 35–40 (Roof-line) | 50 | 33 for PVAI and 10.2 for Roof-line (NavX arm)
35 for PVAI and 12.8 for Roof-line (fluoroscopy arm)

# P=0.3 (PVAI) and P=0.2 (Roof-line), respectively, between the two arms.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Rotter 2005 France 15741228 | Freedom from arrhythmia | Any atrial arrhythmia after single procedure (7 of each arms with AAD) | Fluoroscopy-guided PVAI | 6.2 | 29 | 37 | 78% (KM) | | 0.87 (Log-rank)
Fluoroscopy+NavX-guided PVAI | 7.2 | 26 | 35 | 74% (KM)
Rotter 2005 France 15741228 | Reprocedure | Nd | PVAI | 6.7 | 17 | 72 | 24% (Crude?)
Rotter 2005 France 15741228 | “Arrhythmia free” | Any atrial arrhythmia after necessary procedures (mean 1.24 procedure) with or without AAD | PVAI | 6.7 | 65 | 72 | 90% (Crude?)

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Y
Was a blanking period (time when AFib episodes were not recorded) used? | nd | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Rotter 2005 France 15741228 | PVAI | 6.7 | No events observed

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Rotter 2005 France 15741228 | y | nd | nd | y | nd | y | y | n | y | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | n | y | y | N
Explanation for Overall Quality Grade: | | | | Poor reporting on methodology and definition used downgraded the rating.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Rotter 2005 France 15741228 | | Moderate
Explanation for Applicability Grade: | | Inclusion criteria were not fully reported.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Saad Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Saad 2003 USA 12693885 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Saad 2003 USA 12693885 | Symptomatic drug-refractory AF | nd | nd | nd | May overlap other studies conducted at the Cleveland Clinic Foundation

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Saad 2003 USA 12693885 | none | Ostial PVI | 335 | 52 | 54 | 78 | 5.4 | nd | 4.2 | 53 | C | Wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Saad 2003 USA 12693885 | Yes* | Nd [entrance block] | nd | nd | 4 mm 8 mm (Biosense Webster) Cooled-tip (Chilli) | nd | nd | nd

* Ablation energy for PVI was delivered inside the PVs (during only early period) or at the PV-LA junction identified by ICE or PV angiography (vast majority). For patients who underwent electroanatomical mapping, only elimination of ectopic activity initiating AF, instead of PVI, was considered procedure endpoint in some patients. In patients in whom the electro anatomic system was used, only the superior PVs were targeted unless firing from other veins was noted.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Circular mapping-guided | Saad 2003 USA 12693885 | Cure | Cure of AF after the first procedure without AAD (detailed definition of relapse and blanking period unclear) | Ostial PVI | 6 mo | 212 | 264 | 80%
Circular mapping-guided | Saad 2003 USA 12693885 | Cure | Cure of AF after the last procedure without AAD (detailed definition of relapse and blanking period unclear) | Ostial PVI | 6 mo | 243 | 264 | 92% | | nd
Electro anatomically guided | 21 | 71 | 30%
Circular mapping-guided | Saad 2003 USA 12693885 | Re-procedure | Second procedure (details unclear) | Ostial PVI | 6 mo | 35 | 264

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes (inferred)
Was a blanking period (time when AFib episodes were not recorded) used? | nd | If yes, how long was it? | NA

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Saad 2003 USA 12693885 | Ostial PVI | 5.2 | 18/335 (5%)* | nd | nd | nd | nd | nd

* All patients developed at least one severe stenosis (>70%) by CT. Eight patients (44%) were asymptomatic.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Saad 2003 USA 12693885 | No | NA | NA | Yes (inferred) | nd | nd | nd | nd | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | No | No | Yes | Yes (inferred) | No
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Saad 2003 USA 12693885 | | | Wide
Explanation for Applicability Grade: | | No clear exclusion criteria, inferring wide applicability.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Sauer 2006a Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Sauer, 2006 US 16945795 | | | x | | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Sauer, 2006 US 16945795 | All patients referred to UPHS for ablation of symptomatic drug refractory AF | None | Nov 2000 to Aug 2004 | 6 weeks for paroxysmal AF patients; 6 months for persistent and permanent AF patients | Persistent AF: 33% Permanent AF: 5% CAD: 11.6%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Sauer, 2006 US 16945795 | nd | PVI | 424 | 60 | 53.5 | 76 | nd | nd | 4.4 | 59 | B | wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Sauer, 2006 US 16945795 | yes | 100% [elimination of all provocable AF triggers, Lasso] | nd | yes | 4-mm (74%) or 8-mm tip (26%) NaviStar mapping/ablation catheter (Biosense Webster, Diamond Bar, CA) | 4-mm: 50 8-mm: 70 | 50–52 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Sauer, 2006 US 16945795 | AF cure | No recurrent AF and no use of any AAD | PVI | 21.7 | 243 | 424
| Maintenance of sinus rhythm after a single procedure | Including those who continued previously ineffective AAD | PVI | 21.7 | 301 | 424

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | no
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 6 weeks

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Acute PV reconnection (conduction entry or exit was observed at any time during the procedure after initial vein disconnection) | Sauer, 2006 US 16945795 | AF cure | No recurrent AF and no use of any AAD | PVI | 21.7 | 119 | 213 | | | 0.97
No acute PV reconnection | 124 | 211
Acute PV reconnection | Sauer, 2006 US 16945795 | Maintenance of sinus rhythm after a single procedure | Including those who continued previously ineffective AAD | PVI | 21.7 | 153 | 213 | | | 0.52
No acute PV reconnection | 148 | 211
Acute PV reconnection | Sauer, 2006 US 16945795 | AF control | AF cure and no recurrent AF on AADs that were previously ineffective | PVI | 21.7 | | | | | | RR= 1.27 | 0.83–1.93 | 0.28
No acute PV reconnection

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Sauer, 2006 US 16945795 | mo | NA | NA | 0% | nd | yes | yes | yes | yes | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | yes | yes | no | No
Explanation for Overall Quality Grade: | | | | Data were prospectively collected but post hoc analyses

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Sauer, 2006 US 16945795 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Sauer, 2006 US 16945795 | Data were prospectively collected. 4-mm tip catheter was used in most patients but no separate analyses for 8-mm

Sauer 2006b Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Sauer, 2006 US 16831982 | | | x | | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Sauer, 2006 US 16831982 | Patients referred to UPHS | nd | Nov 1998 to March 2005 | 6 weeks for paroxysmal AF patients; 6 months for persistent and permanent AF patients. Typically class IC drug if patient was without structural heart disease or sotalol if they had heart disease | Persistent AF: 35% Permanent AF: 4% CAD: 9%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Sauer, 2006 US 16831982 | nd | PVI | 629 | 61 | 54.6 | 73 | 6.9 | 1.9 | 4.4 | 58 | C | wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Sauer, 2006 US 16831982 | yes | 100% [isolation of all PVs was performed if no trigger identified. Entry and exit block confirmed] | AVNRT was ablated if discovered to be an AF trigger. | yes | nd (~70% 4mm; ~30% 8mm inferred from other articles in the same cohort) | nd | nd | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Sauer, 2006 US 16945795 | Freedom from AF | No recurrent AF without use of any AAD | PVI | 21.4 | 350 | 624

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | no
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | 6 weeks

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Patients with atrioventricular nodal reentrant tachycardia (AVNRT) | Sauer, 2006 US 16945795 | Freedom from AF | No recurrent AF without use of any AAD | PVI | 21.4 | 21 | 24*** | | | <.01 | OR=3.58 | 1.31–6.18 | 0.03
Patients without AVNRT | 329 | 602
Patients with atrioventricular nodal reentrant tachycardia (AVNRT) | Sauer, 2006 US 16945795 | Maintenance of sinus rhythm after a single procedure | Including those who continued previously ineffective AAD | PVI | 21.4 | 21 | 24***
Patients without AVNRT | 427 | 602 | | | 0.12

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Sauer, 2006 US 16831982 | PVI (~70% 4-mm tip; ~30% 8-mm tip) | | | | | | | | “major complications” | 2.5%

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Sauer, 2006 US 16945795 | no | NA | NA | 0 | nd | yes | yes | yes | no | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | no | yes | yes | no | no
Explanation for Overall Quality Grade: | | | | Data were prospectively collected but post hoc analyses. Ablation procedure was not described in detail.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Sauer, 2006 US 16945795 | | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Schwartzman Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Schwartzman 2003 US 14574043 | | x | | | KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Years of enrollment | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Schwartzman 2003 US 14574043 | symptomatic drug resistant AF; ≥ 3 episodes of sustained AF solely from PV myocardium during EP study | inadequate number of sustained AF; extra-venous origin | nd | | non-concurrent comparison; last group (vestibule encircling) had significantly smaller proportion of patients with prior amiodarone therapy

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Schwartzman 2003 US 14574043 | nd | focal | 47 | nd | 55 | 81 | nd | nd | 4.0 | 56 | C | narrow
Schwartzman 2003 US 14574043 | nd | vein encircling | 42 | nd | 55 | 81 | nd | nd | 4.0 | 56 | C | narrow
vestibule encircling | 23

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Schwartzman 2003 US 14574043 | | y | 100% of all patients in vein encircling and vestibule encircling group [entrance block during sinus rhythm] | y | nd | 30 | 50 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Schwartzman 2003 US 14574043 | clinical success | absence of detectable AF without type I or III AAD in the 6^th^ post-procedure mo | focal | 6 mo | | | 47%
| | | vein encircling | | | | 69%
| | | vestibule encircling | | | | 87% | | <0.05

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | n
Was a blanking period (time when AFib episodes were not recorded) used? | n | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Schwartzman 2003 US 14574043 | focal or vein encircling or vestibule encircling | 6 mo | | | | | femoral pseudoaneurysm, 3/112 (2.7%); AV fistula, 2/112 (1.8%); | | femoral bleeding requiring transfusion | 1/112 (0.9%)
| | | | | | | | | transient non-cardiogenic pulmonary edema | 1/112 (0.9%)
| focal | | | | | | | | *stenosis of targeted zone | 4/47 (9%)
| vein encircling | | | | | | | | stenosis of targeted zone | 2/42 (5%)
| vestibule encircling | | | | | | | | stenosis of targeted zone | 0/23

* “Significant” stenosis of targeted zone.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Schwartzman 2003 US 14574043 | n | NA | NA | nd | n | n | y | n | n | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | no | no | no | yes(?) | no
Explanation for Overall Quality Grade: | | | | incomplete reporting; non-concurrent comparison; not totally comparable baseline characteristics

* observational study cannot be an A, retrospective study is always a C

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Schwartzman 2003 US 14574043 | X
Explanation for Applicability Grade: | | relatively few patients; single center experience

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Shah Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Shah 2007 Switzerland 17655668 | | x | | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Shah 2007 Switzerland 17655668 | Drug refractory symptomatic AFib | LA thrombi | nd | No, unless recurrence | 15% structural heart disease

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality
Shah 2007 Switzerland 17655668 | Medtronic, Biosense Webster, Guidant (and consultancy for others) | PVI Linear LA ablation PRN | 113 | 64% | 56 | 81 | 6 yr | | 4.3 | <40%: 6%
PVI Linear LA ablation PRN Cavotricuspid isthmus (CTI) ablation | 75 | 85% (P<.001) | 4.0 (P=.02)

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Shah 2007 Switzerland 17655668 | Yes | 100% | Supplemental LA lines if persistent or permanent AFib or AFib after PV isolation: L to R superior PV ostia (roof line); L inferior PV ostium to posterolateral mitral annulus (mitral line) (9 patients) | No (except for Aflutter if necessary) | Irrigated 7F (ThermoCool) | 35 | nd | 43
Also CT isthmus ablation Supplemental LA lines in 48 patients | 48

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Shah 2007 Switzerland 17655668 | AFib recurrence | unclear (probably including asymptomatic holter AFib) | PVI | 30 (16–55 range) | 28% (32) | 113 | | | NS
| | | PVI + CTI ablation | | 25% (19) | 75
| AFib-free survival | Off AAD | PVI | 30 (16–55 range) | | 113 | | | NS by KM plot
| | | PVI + CTI ablation | | | 75
| SR without AFib, Aflutter, or AAD at end of followup | (including additional ablations) | PVI | 30 (16–55 range) | 79% (89) | 113 | | | NS
| | | PVI + CTI ablation | | 82% (61.5) | 75
| SR without AFib or AAD at end of followup | (including additional ablations) | PVI | 30 (16–55 range) | 84% (95) | 113 | | | NS
| | | PVI + CTI ablation | | 88% (66) | 75
| Arrhythmia free (including on AAD) at end of followup | (including additional ablations) | PVI | 30 (16–55 range) | 86% (97) | 113 | | | NS
| | | PVI + CTI ablation | | 89% (67) | 75

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 2 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Shah 2007 Switzerland 17655668 | PVI | 30 (16–55 range) | 2.6% (3/113, 150 procedures) >50%, asymptomatic, no treatment | 0.8% (1/113, 150 procedures) | | | | | Embolic events (not defined | 0.8% (1/113, 150 procedures)
| PVI + CTI ablation | | 0% (0/75, 98 procedures) | 2.6% (2/75, 98 procedures) | | | | | | 0% (0/75, 98 procedures)

NS for all comparisons

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Shah 2007 Switzerland 17655668 | No | NA | NA | Yes | No | Yes | Yes | No | No | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No (unclear if asymptomatic included) | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | Reported % not n, which led to 1 discrepancy

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Shah 2007 Switzerland 17655668 | 4 lost to follow-up and 2 died of noncardiac, nonembolic causes. ITT analysis implied

Sheikh Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Sheikh, 2006 US 17318445 | X | | | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Sheikh, 2006 US 17318445 | AFib refractory to AAD | Prior ablation Chronic or persistent AFib | nd | AAD × 1 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Sheikh, 2006 US 17318445 | nd | PVI | 50 | 100% | 59 | 63 | nd | nd | 4.1 | 54 | C | Moderate
PVI+ ablation lines | 50

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Sheikh, 2006 US 17318445 | Yes | Yes Lasso used in first 20 pts and then basket catheter used in 80 until PVs were electrically silent. | WACA | No | nd | nd | Goal: 50–55° | nd
WACA + Lines: Left inferior PV to the MV annulus Connecting superior PVs (roof line)

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Sheikh, 2006 US 17318445 | NSR off AAD | | PVI alone | 9 mo | 14 (41–27**) | 50
| | | PVI+ Lines | | 14 (45–31) | 50

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

3 patients with post-procedure AFL (within first 3 months, implied) had AFL ablation.

** # in NSR minus # using AAD

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Only partially*
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 3 mo

* Holters done only if symptomatic or if rhythm strip in clinic was suggestive.

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Sheikh, 2006 US 17318445 | PVI alone | | 0/50 | 1/50 (2%) surgical pericardial window | 1/50 (2%) TIA | | | | Small pericardial effusion with pericarditis, resolved with Rx | 1/50
| PVI+ Lines | | 0/50 | 0/50

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Sheikh, 2006 US 17318445 | Yes | nd | nd | Yes (0%) | No (nd) | Yes | Yes | No | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | No Catheter tip not described | Yes | Essentially (AFL ablation was done) | Only partially | No
Explanation for Overall Quality Grade: | | | | Unknown catheter. Only partial assessment for asymptomatic AFib

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
| | Moderate
Explanation for Applicability Grade: | | Small

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Shimano Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Shimano 2008 Japan 18550508 | | | X | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Shimano 2008 Japan 18550508 | Paroxysmal or persistent AF | Valvular heart disease, HD, previous RFA | 2004-2005 | nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Shimano 2008 Japan 18550508 | Gov't and Foundation | RFA | 62 | 69% | 59 | 77 | 4.8 | | 4.0 | 63 | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Shimano 2008 Japan 18550508 | Yes | Ostial, guided by lasso catheter complete elimination of electrical conduction into PV | | Yes | nd | 30W | 55° | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Shimano 2008 Japan 18550508 | Recurrent AF | (unclear how maintenance on AAD counted) | RFA | 2.1 yr | 15 | 62 | 24%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | No? | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
| nd

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Shimano 2008 Japan 18550508 | No | NA | NA | Yes | NA | ~Yes | OK | No | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | No | No | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | Unclear procedure and outcome.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Spragg Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Spragg 2008 US 18462327 | | | | X | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Spragg 2008 US 18462327 | Catheter ablation for AF | None | 2001-2007 | n/a | only complications

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Spragg 2008 US 18462327 | nd Senior author does industry consulting | RFA | 517 (641 procedures) | 54% | 57 | 78 | nd | nd | 4.7 | 57 | B

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Spragg 2008 US 18462327 | Yes (endpoint since 2004) | 2001-03: Segmental ablation targeting PV ostia (17%) 2003-07: Wide, circumferential linear ablation (83%) | | No | 8 mm (38%) or 4 mm irrigated (62%) | Segmental: 50W (target) Wide: 30 W anterior, 20 W posterior | nd | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | NA
Was a blanking period (time when AFib episodes were not recorded) used? | NA | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Spragg 2008 US 18462327 | RFA | | 1/641* (0.2%) | 8/641* (1.2%) | 7/641* (1.1%) | 0/641* | “Vascular injury” 11/641* (1.7%) 4 required surgery | 0/641* | Hemothorax | 1/641* (0.2%)
| | | | | | | | | Heart block | 1/641* (0.2%)
| | | | | | | | | Lung injury | 1/641* (0.2%)
| | | | | | | | | MV injury | 1/641* (0.2%)

* 641 procedures in 517 patients

There are analyses of temporal trends and of complication predictors

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Spragg 2008 US 18462327 | No | NA | NA | No | NA | ~Yes | OK | No | Yes | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | OK | NA | NA | NA | NA
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Spragg 2008 US 18462327
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Spragg 2008 US 18462327

Sra Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Sra 2007 US 17284262 | x | | | | | MC

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Sra 2007 US 17284262 | Documented, symptomatic AF prior to the procedure; refractory to >1 AAD. | nd | nd | All AADs were discontinued within the 1st month | 8 patients (5 in CT-fluoro guided group) had undergone 1 prior catheter ablation procedure for AF. Structural heart disease=26%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Sra 2007 US 17284262 | nd | RFA with or without the CT-fluoro guidance system | 50 | 64 | 55 | 82 | 3.5 | nd | 4.5 | 47 | C | Moderate

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Sra 2007 US 17284262 | yes | 100% [no PV potentials] | For both groups, in the LA: (1) roof line, (2) circumferentially around the left and right PV antrum posteriorly, (3) mitral annulus to left inferior PV, and (4) anteriorly. For patients in persistent AF, the catheter was dragged along the posterior mitral annulus. Cavo-tricuspid lesions were also delivered in patients with inducible isthmus-dependent right atrial flutter and in those with persistent AF. Cardioversion was used to convert to sinus rhythm if AF still present after ablation. | no | nd | 30–35 | 50–55 | CT-fluoro-guided: 86 min Control: 95 min P=0.18

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Sra 2007 US 17284262 | Free of AF | No recurrence of AF or atrial flutter after a single ablation (unclear on or off AADs) | CT-fluoro-guided RFA (3D) | 9 | 21 | 25 | | nd
| | | RFA without CT-fluoro-guided | 9 | 16 | 25

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | 1 month

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Persistent AF | Sra 2007 US 17284262 | Free of AF | No recurrence of AF or atrial flutter after a single ablation | RFA with or without the CT-fluoro guidance system | 9 | 12 | 18 | | | nd
Paroxysmal AF | | | | | 9 | 25 | 32

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Sra 2007 US 17284262 | yes | nd | nd | 0% | nd | NA | no | no | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | yes | yes | yes | no
Explanation for Overall Quality Grade: | | | | no information on use of AAD after the 1st month (blanking period); 8 patients (5 in CT-fluoro-guided group) had undergone 1 prior entering to the study.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Sra 2007 US 17284262 | | x
Explanation for Applicability Grade: | | 8 patients (5 in CT-fluoro-guided group) had undergone 1 prior entering to the study.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Sra 2007 US 17284262 | 8 patients (5 in CT-fluoro-guided group) had undergone 1 prior entering to the study. 8 patients (2 in CT-fluoro-guided group) have undergone a 2nd procedure since their last follow-up.

Stabile Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Stabile, 2006 Italy 16214831 | X | | | | Circumferential PV and additional lines ablation with continuous concurrent anti-arrhythmics vs. only (continuous) anti-arrhythmics | TT/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Stabile, 2006 Italy 16214831 | Paroxysmal* or persistent** AFib Intolerant of AADs or refractory to two or more anti-arrhythmics | - Age < 18 or > 80 years; - Permanent AFib***; - AFib secondary to a transient or correctable abnormality, including electrolyte imbalance, trauma, recent surgery, infection, toxic ingestion, and endocrinopathy; - Persistence of AFib episodes triggered by another uniform arrhythmia (i.e. atrial flutter or atrial tachycardia) despite previous supraventricular tachycardia ablation; - Intra-atrial thrombus, tumor, or other abnormality precluding catheter insertion; - Wolff-Parkinson-White syndrome; - Heart failure with NYHA class III or IV or EF ≤ 35%; - Unstable angina or acute myocardial infarction within 3 moths; - Cardiac revascularization or other cardiac surgery within 6 moths or with prior atrial surgery; - Renal failure requiring dialysis, or hepatic failure; - An implanted device (pacemaker or cardioverter-defibrillator); - Left atrial diameter > 60 mm. | 02/2002–06/2003 | Continued

* Paroxysmal AFib was defined as the occurrence, in the previous 6 moths, of one or more episodes of AFib a moth, each lasting more than 60 min but less than 7 days, with all episodes terminating spontaneously.

** Persistent AFib was defined as the occurrence, in the previous 12 moths, of two or more episodes of AFib, each lasting more than 7 days before being terminated pharmacologically or by electrical cardioversion, or lasting less than 7 days but necessitating early cardioversion owing to intolerable symptoms or hemodynamic compromise, with sinus rhythm maintained for 60 min or more, after termination.

*** Permanent AFib was defined as AFib, the sole rhythm for the last 12 moths.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Stabile, 2006 Italy 16214831 | Biosense-Webster, Italy | Circumferential PV ablation + AAD* | 68 | 67 | 62 | 57 | 6.1 | nd | 4.6 | 58 | B | Moderate
AAD* only | 69

* Amiodarone. A class Ic anti-arrhythmic was used if patients had a history of side effects or intolerance to amiodarone. Dosing schedule not provided in detail but reported mean doses were amiodarone of 209 mg, flecainide of 191 mg, propafenone of 750mg, sotalol of 184 mg, and dysopyramide of 500mg.

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Stabile, 2006 Italy 16214831 | Yes | nd (100% implied) [Low peak-to-peak bipolar potentials (<0.1 mV) inside the lesion by local electrogram analysis and voltage maps] | Circumferential lines around each PV Mitral isthmus line Cavotricaspid isthmus line (if conduction in this region was detected) | No | 8 mm* (nd) | 100** | 60 | nd
3.5 mm, cooled* (nd) | 50** | 45

* 8 mm tip catheter was used only in the first 17 patients, and was replaced with 3.5 mm cooled-tip catheter in the remaining patients.

** The half of the energy (50 W and 25 W) was used when ablation was performed in the posterior wall.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Stabile, 2006 Italy 16214831 | Atrial arrhythmia-free survival | Atrial arrhythmia lasting > 30 s in the 1-year follow-up period after 1-moth blanking period | Circumferential PV ablation + AAD | 12 | 38 | 68 | nd | nd | <0.001 (Log-rank?) | HR=3.2 | 2.0–5.1 | Nd
AAD only | 12 | 6 | 69

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

The number of arrhythmia was reported in the paper but converted.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes*
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 1 mo

* 30 s ECG everyday and irregularly obtained ECG in the event of symptoms by transtelephonic ECG, and routine standard ECG, Holter, and echocardiography at 1, 4, 7, 10, 13 mo.

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
Stabile, 2006 Italy 16214831 | Re-admission | Per-patient number of hospitalization (including that for ablation) | Time | Circumferential PV ablation + AAD | 12 | 68 | 0 | Median 1 | nd | 0.34 (unclear)
AAD only | 12 | 69 | 0 | Median 2

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Different tips in Circumferential PV ablation + AAD | Stabile, 2006 Italy 16214831 | Atrial arrhythmia-free survival | Atrial arrhythmia lasting > 30 s in the 1-year follow-up period after 1-moth blanking period | 8 mm | 12 | 9 | 17 | nd | nd | 0.64 (Log-rank?) | nd | nd | nd
3.5 mm, cooled | 12 | 29 | 51

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

The number of arrhythmia was reported in the paper but converted.

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Stabile, 2006 Italy 16214831 | Circumferential PV ablation + AAD | 12 | 0/68 | 1/68 (1%) | 1/68 (1%)* | | | 0 | Transient phrenic paralysis | 1/68 (1%)
Stabile, 2006 Italy 16214831 | Circumferential PV ablation + AAD | 12 | 0/68 | 1/68 (1%) | 1/68 (1%)* | | | 0 | AAD-related*** | 2/68 (3%)
Stabile, 2006 Italy 16214831
Stabile, 2006 Italy 16214831 | Coronary artery disease**** | 1/68 (1%)
AAD only | 12 | 0 | 0 | TIA, 1/69 (1%)** | 0 | 0 | 0 | Cancer***** | 2/69 (3%)
Sudden death****** | 1/69 (1%)

* This patient developed “stroke” during RFA procedure and died of brain hemorrhage 9 mo later.

** Timing not reported.

*** These two patients developed some unclear side effects of anti-arrhythmics leading to “intolerance” at 4 and 6 mo after randomization necessitating change of drug.

**** This patient underwent PTCA 3 moth after ablation. Unclear about the relation with ablation.

***** Unclear about the relation with intervention. One of the two died of cancer (timing not reported).

****** Unclear about the relation with intervention. Timing also unclear.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Stabile, 2006 Italy 16214831 | Yes | Yes | Nd | Yes, 2% (1% in ablation arm and 3% in drug alone arm) | Yes | Yes | Yes | Yes | Yes | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Nd** | Yes*** | Yes****
Explanation for Overall Quality Grade: | | | | Was rated as A but changed to B; outcomes were assessed while the patients were on AADs (combined modality therapy)

* observational study cannot be an A, retrospective study is always a C

** No clear description as to whether second procedure was performed, inferring that only single procedure was considered.

*** 30 s ECG everyday and irregularly obtained ECG in the event of symptoms by transtelephonic ECG, and routine standard ECG, Holter, and echocardiography at 1, 4, 7, 10, 13 mo.

**** Only one patient in the drug only arm refused transtelephonic ECG.

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Stabile, 2006 Italy 16214831 | | X
Explanation for Applicability Grade: | | N<100, many exclusion criteria (not applicable especially to patients with underlying heart disease or moderate to severe CHF.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Stabile, 2006 Italy 16214831 | - Overall excellent conduct and detailed reporting except for some minor omissions on statistical tests applied.; - NOTE: Clinical outcomes were evaluated while patients were continuously taking an anti-arrhythmic (for good?).

Tamborero Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Tamborero 2005 Spain 16311935 | | x | | x | PVI vs. CPVA; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Tamborero 2005 Spain 16311935 | symptomatic AF, failed AADs; only included patients who had a MRA to evaluate PV stenosis (?) | did not have MRA (?) | nd | 1 mo | Patients with suspected focal origin AF received PVI; others received CPVA; 78 consecutive patients, only results from 73 who received MRA to evaluate PV stenosis were included

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Tamborero 2005 Spain 16311935 | government? | PVI | 32 | 85 | 50 | 75 | 5.2 | | 3.7 | 58 | C | moderate
CPVA | 41 | 66 | 52 | 80 | 6 | | 4.2 | 53

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Tamborero 2005 Spain 16311935 | yes in group 1 | ? [eliminated or dissociated PV potentials] | group 1 - PVI (see Silva 2003, UI 12689570) group 2 - CPVA used CARTO; endpoint to reduce potential <0.15 mV | n | 4 mm | 40–50 | 50
8 mm | 50–60 | 55

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Tamborero 2005 Spain 16311935 | | free from AF (?) recurrence | PVI | 14.7 mo | 23 | 32 | 72%
| | | CPVA | | 31 | 41 | 76% | | NS

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | nd
Was a blanking period (time when AFib episodes were not recorded) used? | n | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Tamborero 2005 Spain 16311935 | PVI | 4 mo | stenosis >70%; 6/32 (19%)
| CPVA | 4 mo | stenosis >70%; 0/41

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Tamborero 2005 Spain 16311935 | n | NA | NA | NA | y | n | n | n | n | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | n | n | y | y
Explanation for Overall Quality Grade: | | | | incomplete reporting

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Tamborero 2005 Spain 16311935 | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Tamborero 2005 Spain 16311935 | indications for PVI were different from indications for CPVA; the two groups were therefore not comparable; better to assess this report as individual cohorts rather than a comparative study

Tang 2006 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Tang 2006 China 17235682 | | x | x | | pts with DM vs. without DM; KQ 2, 4 | SI/AG

Almost definite partial overlap with separately extracted Liu 2005 528, Ma 2006 458, Dong 2005 603.

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Tang 2006 China 17235682 | AF; ±DM | previous RFA; intra atrial thrombus | 2004-2006 | 2 mo | two groups not totally comparable at baseline (pts with DM older, longer history of Af, larger Lad)

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Tang 2006 China 17235682 | government | RFA in pts with type 2 DM | 31 | 81 | 62 | 74 | 9.6 | | 4.11 | 63
RFA in pts without type 2 DM | 232 | 75 | 56 | 71 | 6.7 | | 3.83 | 63.6

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Tang 2006 China 17235682 | y | nd [electrical isolation of all PVs] | CPVA; isthmus was also ablated if there were preprocedural AFL, or macro-reentrant AT during procedure | n | 3.5 mm irrigated (ThermoCool) | 35 | 43

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Tang 2006 China 17235682 | recurrence | any episode of AT ≥ 30 s | RFA in pts with type 2 DM | 13.4 | | | 32.3%
| | | RFA in pts without type 2 DM | | | | 22.4% | | 0.24
| complication was an independent risk factor for AF recurrence (OR 2.888, 95%CI 1.056–7.900, P=0.039)

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 1 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Tang 2006 China 17235682 | RFA in pts with type 2 DM | | 0 | 1/31 (3.2%) | 2/31 (6.5%) | | | | pneumothorax | 1/31 (3.2%)
hematoma | 5/31 (16%)
| RFA in pts without type 2 DM | | 50% stenosis: 2/232 (0.9%) | 2/232 (0.9%) | 1/232 (0.4%) | | | | cardiac arrest (VF) (survived) | 1/232 (0.4%)
| RFA in pts without type 2 DM | | 50% stenosis: 2/232 (0.9%) | 2/232 (0.9%) | 1/232 (0.4%) | | | | hematoma | 6/232 (2.6%)
| RFA in pts without type 2 DM | | 50% stenosis: 2/232 (0.9%) | 2/232 (0.9%) | 1/232 (0.4%) | | | | *pericardial effusion | 4/232 (1.7%)
| RFA in pts without type 2 DM | | 50% stenosis: 2/232 (0.9%) | 2/232 (0.9%) | 1/232 (0.4%) | | | | femoral pseudoaneurysm | 1/232 (0.4%)
femoral vein thrombosis | 1/232 (0.4%)

* One pericardial effusion leading to pericardiocentesis in a patient with low BP

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Tang 2006 China 17235682 | n | NA | n | nd | n | n | y | n | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | n | y | n
Explanation for Overall Quality Grade: | | | | two groups not totally comparable at baseline

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Tang 2006 China 17235682 | | X
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Tang 2008 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Tang 2008 China 18364135 | x | | | | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Tang 2008 China 18364135 | Drug refractory paroxysmal AF | nd | nd | nd | Complicated atrial flutter=33%

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Tang 2008 China 18364135 | Non-profit | CartoMerge guided versus CartoXP guided circumferential PVI | 81 | 100 | 59.8 | 67 | 3.1 | nd | 3.8 | 61 | B | Narrow

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Tang 2008 China 18364135 | yes | 100% [abolishment or dissociation of PVPs confirmed by Lasso catheter] | Linear ablation of the cavotricuspid isthmus would be performed routinely until bidirectional block was achieved at the isthmus if patient had previous history of typical atrial flutter | no | Irrigated tip (Biosense Webster Inc, CA) | 30–40 | 43 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Tang 2008 China 18364135 | Success of ablation | No recurrence of atrial tachyarrhythmias according to the symptoms, ECG and Holter monitoring during the follow up periods from the 4^th^ month of post ablation procedure | CartoMerge (3-D) guided circumferential PVI | 11.9 | 33 | 42 | | | >0.50
| | | CartoXP (3-D) guided circumferential PVI | 12.4 | 29 | 39

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | yes | If yes, how long was it? | 4 months

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Tang 2008 China 18364135 | CartoMerge guided versus CartoXP guided circumferential PVI | | 0 (severity not defined) | 2/81 (2.5%) | 0 | 0 | | 0

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Tang 2008 China 18364135 | yes | nd | nd | yes | nd | yes | yes | no | yes | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | no | no | yes | No
Explanation for Overall Quality Grade: | | | | Unclear if repeated procedures were accounted for

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Tang 2008 China 18364135 | x
Explanation for Applicability Grade: | | 100% paroxysmal AF patients only

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Tao Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Tao 2008 China 18855350 | | | | x | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Antiarrhythmics (Time) | Other Important Characteristics
Tao 2008 China 18855350 | AF, first time RFA 20–80 y, symptomatic AF refractory to ≥2 AAD, NYHA I or II | EF<45%, contraindication to anticoagulation, LA thrombus, previous AF ablation <12 mo follow-up | <2007 | Amiodarone (propafenone if amiodarone contraindicated) × 3 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Tao 2008 China 18855350 | nd | Circumferential pulmonary vein ablation | 259 | Persistent: 30% | 57 | 70 | 6.8 | nd | 3.85 | 63 | C

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Tao 2008 China 18855350 | Y | (additional ablation if necessary to achieve isolation) | Tricuspid annulus isthmus, if AFL | Y | External Irrigated, 3.5 mm (ThermoCool) | 35 W | 43° | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Tao 2008 China 18855350 | Late recurrence | Between 1–12 mo ATachy >30 sec (Sxic) or >5 min (ASxic) | RFA | 18.2 | 66 | 249 | 26.5%
| Very late recurrence | >12 mo (not 0–12 mo) | RFA | 18.2 | 14 | 249 | 5.6%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Y
Was a blanking period (time when AFib episodes were not recorded) used? | Y | If yes, how long was it? | 1 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Tao 2008 China 18855350 | RFA | 18.2 | 0/249 | 0/249 | [TIA 2/249 (0.8%) | 0/249 | Severe hematoma requiring transfusion 1/249 (0.4%) | 0/249

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Tao 2008 China 18855350 | N | NA | NA | Y | NA | N | Y | Y | Y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Y | Y | Y | Y | N
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Themistoclakis Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Themistoclakis 2008 US & Italy 18325850 | | | X | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Antiarrhythmics (Time) | Other Important Characteristics
Themistoclakis 2008 US & Italy 18325850 | PV antrum isolation (symptomatic, drug resistant, parox, persistent, or permanent AF) Single ablation (only) | nd | 2001-2005 | If persistent or permanent AF AAD for 2 mo. Usually sotalol or dofetilide.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Themistoclakis 2008 US & Italy 18325850 | nd | RFA | 1298 | 54% | 56 | 78% | 6.6 | | 4.4 cm >4 cm 69% | 54% <40% 9% | B

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Themistoclakis 2008 US & Italy 18325850 | Yes | 100% | SVC isolation (78%) if SVC potentials and no phrenic nerve capture during pacing Non-PV antrum/SVC foci ablation (7.5%) when identified | Yes | 8 mm (Celsius DS) | nd | nd (microbubbles) | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Themistoclakis 2008 US & Italy 18325850 | “Late” atrial tachyarrhythmia (vs no AAD) | post-3 mo | RFA | 41 mo (21–63 mo) | 292 (288 Sxic; 4 ASx) | 1298 | 22%
| AF recurrence | post-3 mo | RFA | 41 mo (21–63 mo) | 252 | 1298 | 19%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 3 months

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Parox | Themistoclakis 2008 US & Italy 18325850 | “Late” atrial tachyarrhythmia (vs no AAD) | post-3 mo | RFA | 41 mo (21–63 mo) | 107 | 699
Persistent | | | | | | 65 | 230 | 2.21 | 1.55–3.16 | <.001 | 2.17 | 1.33–3.53 | .002
Permanent | | | | | | 120 | 369 | 2.68 | 1.98–3.61 | <.001 | 2.28 | 1.51–3.46 | <.001

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Themistoclakis 2008 US & Italy 18325850 | nd on AE

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Themistoclakis 2008 US & Italy 18325850 | No | NA | NA | No | NA | Yes | Yes | Yes (multivariable) | Yes | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | Yes (implied, 48 hr Holter) | Yes
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Themistoclakis 2008 US & Italy 18325850
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Themistoclakis 2008 US & Italy 18325850 | Very likely large overlap with multiple other articles from Cleveland Clinic and Umberto I hospital

Thomas Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Thomas 2004 Australia 15172657 | | x | | | open irrigated vs. non-irrigated tip PVI; KQ 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Thomas 2004 Australia 15172657 | severely (interrupted normal activities) symptomatic AF who had PVI | | ND | | Last 48 compared to the first 31 patients; extracted adverse events data only, outcomes reported were less than 6 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Thomas 2004 Australia 15172657 | nd | open irrigated (ThermoCool, Cordis-Webster) | 48 | 69 | 56 | 77 | 6.2 | | 4.21
4 mm tip (Cordis-Webster or Boston Scientific, Blazer) | 31 | 77 | 55 | 81 | 6.7 | | 4.26

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Thomas 2004 Australia 15172657 | y | 98% of veins (239/244) PVI | | n | irrigated | 30–40 | 50
4 mm

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Thomas 2004 Australia 15172657

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Thomas 2004 Australia 15172657 | irrigated tip | | moderate stenosis (50–70%) 2/158 veins (1.3%); symptomatic : 0 | | 1/48
| 4 mm | | moderate stenosis (50–70%) 4/81 (5%) veins; symptomatic : 0 | 1/31

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Tondo 2005 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Tondo, 2005 Italy 15683472 | x | | | | RCT of guidance systems (EnSite NavX vs fluoroscopic). | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Tondo, 2005 Italy 15683472 | Symptomatic paroxysmal or persistent, drug refractory AFib | nd | nd | Pre-RFA anti-arrhythmic (implied) continued × 3 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Tondo, 2005 Italy 15683472 | nd | Irrigated, 4 mm (ThermoCool) | 60 | 63% | 56 | 52% | nd | nd | 4.0 | 57% | C | Moderate
Tondo, 2005 Italy 15683472 | nd | Group 1: PVI guided by EnSite NavX | 60 | 63% | 56 | 52% | nd | nd | 4.0 | 57% | C | Moderate
Group 2: PVI guided by fluoroscopic

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Tondo, 2005 Italy 15683472 | Yes | 100% [“keeping the loop-shaped multipolar catheter at the PV ostium to ascertain complete electrical isolation”] | Left isthmus line between the mitral annulus and the inferior left PV (if AFib at time of procedure). Linear lesion at the roof of the LA (in 5 patients). Inferior VC-tricuspid annulus lesion (in all). | No | Irrigated 4 mm | nd | nd | 7.5 min (5 min with 3D mapping; 10 min with fluoroscopy)

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Tondo, 2005 Italy 15683472 | Recurrence | Including 1st 3 months | 4 mm | 7 | 9* | 60
Tondo, 2005 Italy 15683472 | 2nd ablation | | 4 mm | 7 | 2 | 60
Tondo, 2005 Italy 15683472 | AF recurrence | | PVI guided by EnSite NavX | 7 | 3 | 30 | 10% | | nd
| | | PVI guided by fluoroscopic | 7 | 6 | 30 | 20%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

* In group 1: 3/30 with recurrence prior to 3 months requiring increased medication dosages. In group 2: 6/30 (timing not reported), 4 of which self-terminated.

Probably ignore this outcome.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Implied. Used 24 hr ECGs
Was a blanking period (time when AFib episodes were not recorded) used? | No (see highlight above) | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Tondo, 2005 Italy 15683472 | Irrigated, 4 mm

“No procedure-related complications occurred.”

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Tondo, 2005 Italy 15683472 | Yes (but not for our purposes) | nd | nd | 0% | nd | NA | NA | No | No | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | No (see comments) | No. Implied. And included early events | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | No data on RCT design methods. Included events during blanking period. Incomplete reporting of recurrence. Eligibility criteria unclear.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Tondo, 2005 Italy 15683472 | | Moderate
Explanation for Applicability Grade: | | N=60. Eligibility criteria unclear.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Tondo, 2005 Italy 15683472 | RCT of two guidance systems: EnSite NavX nonfluoroscopic mapping system that creates a 3-D reconstruction of the LA and PV structure vs. conventional fluoroscopy. Incomplete reporting of recurrence outcome (timing) without use of blanking period. Cannot assess for our purposes. Incomplete data on procedure (energy, temperature). Unclear why ablation time differed by guidance system. Other items vaguely reported. Study population (esp eligibility criteria) unclear.

Tondo 2006 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Tondo, 2006 Italy 16981920 | | | X? (per report) | | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Tondo, 2006 Italy 16981920 | paroxysmal or persistent AF refractory to AAD | nd | nd | 3 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Tondo, 2006 Italy 16981920 | nd | PV vestibular circumferential ablation and additional lines | 105 | 10% | 56 | 82% | 3.6 | 38* | 4.6 | 52% | C | Moderate

* symptomatic CHF (mean NYHA 2.8)

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Tondo, 2006 Italy 16981920 | Yes | 100% [complete elimination of PV potentials] | Left mitral isthmus line (between the mitral annulus and the inferior left PV) IVC-tricuspid annulus blocking line | No | Irrigated 3.5 mm (Cordis ThermoCool) | 30–35* | 42–45*

* 40W (mitral-isthmus line) and 15–25W (CS)

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Nd/No | If yes, how long was it? | NA

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
With CHF | Tondo, 2006 Italy 16981920 | Sinus rhythm | No explicit definition on recurrence or blanking period | PV vestibular circumferential ablation and additional lines | 14 | 35 | 40 | 87% | | NS (exact test)
Without CHF | 60 | 65 | 92%
With CHF | Tondo, 2006 Italy 16981920 | Re-procedure for AF | No explicit definition | PV vestibular circumferential ablation and additional lines | 14 | 3 | 40 | 8% | | NS (exact test)
Without CHF | 7 | 65 | 11%
With CHF | Tondo, 2006 Italy 16981920 | Re-procedure for atrial flutter | No explicit definition | PV vestibular circumferential ablation and additional lines | 14 | 10 | 40 | 13% | | NS (exact test)
Without CHF | 7 | 65 | 11%
With CHF | Tondo, 2006 Italy 16981920 | Free from anticoagulation | No explicit definition | PV vestibular circumferential ablation and additional lines | 14 | 40 | 40 | 100% | | <0.001 (exact test)
Without CHF | 15 | 65 | 23%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between
With CHF | Tondo, 2006 Italy 16981920 | QOL | Time (tolerable) for exercise | min | PV vestibular circumferential ablation and additional lines | 14 | 40? | 9 | 14 | 5 | <0.001 (t-test)
Without CHF | 65? | 15 | 17 | 2 | NS
With CHF | Tondo, 2006 Italy 16981920 | LVEF | Improvement of LVEF evaluated for patients in sinus rhythm | % | PV vestibular circumferential ablation and additional lines | 14 | ? | 33 | 47 | 14 | <0.01 (t-test)
Without CHF | nd | nd | nd | nd | Nd
With CHF | Tondo, 2006 Italy 16981920 | QOL | SF-35, physical functioning | score | PV vestibular circumferential ablation and additional lines | 6 | 40? | 27.6 | 86.4 | | <0.05 (t-test)
Without CHF | 65? | 26.4 | 59.6 | | <0.05 (t-test)
With CHF | Tondo, 2006 Italy 16981920 | QOL | SF-35, social functioning | score | PV vestibular circumferential ablation and additional lines | 6 | 40? | 42.3 | 83.2 | | <0.05 (t-test)
Without CHF | 65? | 45.4 | 85.3 | | <0.05 (t-test)
With CHF | Tondo, 2006 Italy 16981920 | QOL | SF-35, emotional well-being | score | PV vestibular circumferential ablation and additional lines | 6 | 40? | 37.8 | 75.0 | | <0.05 (t-test)
Without CHF | 65? | 38.7 | 76.0 | | <0.05 (t-test)
With CHF | Tondo, 2006 Italy 16981920 | QOL | SF-35, energy/fatigue | score | PV vestibular circumferential ablation and additional lines | 6 | 40? | 23.4 | 63.2 | | <0.05 (t-test)
Without CHF | 65? | 25.5 | 64.3 | | <0.05 (t-test)
With CHF | Tondo, 2006 Italy 16981920 | QOL | SF-35, limitation due to physical health | score | PV vestibular circumferential ablation and additional lines | 6 | 40? | 7.6 | 64.6 | | <0.05 (t-test)
Without CHF | 65? | 8.2 | 66.7 | | <0.05 (t-test)
With CHF | Tondo, 2006 Italy 16981920 | QOL | SF-35, general functioning | score | PV vestibular circumferential ablation and additional lines | 6 | 40? | 46.4 | 74.8 | | <0.05 (t-test)
Without CHF | 65? | 47.4 | 76.7 | | <0.05 (t-test)

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

NOTE: all analyses were before-after comparisons within each subgroup, not net difference between subgroups.

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Tondo, 2006 Italy 16981920 | PV vestibular circumferential ablation and additional lines | 14 | nd | 1/105 (1%) | 0/105 | nd | 5/105 (5%) | nd

Complication rates in patients with CHF were statistically significantly higher than those without CHF (P<0.01).

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Tondo, 2006 Italy 16981920 | No | NA | NA | ?nd | Yes (all patients followed at least 12 mo per report) | NA | NA | No | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | No data on clear inclusion/exclusion criteria (really a prospective study?). Probably Included events during blanking period. Incomplete reporting of recurrence.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Tondo, 2005 Italy 15683472 | | Moderate
Explanation for Applicability Grade: | | Eligibility criteria unclear.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Turco Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Turco 2007 Italy 17302684 | | | X | | adverse events only; RCT of RFA vs. RFA+AAD does not address KQs; the two arms of the RCTs are treated as one cohort | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Turco 2007 Italy 17302684 | PAF or persistent AF; intolerant or failed AADs | <18 or >75 y; permanent AF; persistent AF triggered by AFL or atrial tachycardia; WPW; NYHA III or IV; EF≤35%; pacemaker or ICD; LAD > 6 cm | 2004-2005 | 50% received AAD

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Turco 2007 Italy 17302684 | nd | Circumferentia PVIl+ cavo-tricuspid + MIL | 107 | 60 | 57 | 65 | 4.5 y | nd | 4.8 | 57

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Turco 2007 Italy 17302684 | y | Nd (Endpoint was <0.1mv potentials inside the lesions as determined by local electrogram analysis and voltage maps.) | circumferential lines around each PV + cavo-tricuspid + MIL | n | 3.5 mm cooled tip | 42 25 W posterior wall | 45 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Turco 2007 Italy 17302684 | circumferential PVI + cavo-tricuspid + MIL | | | 1/107 (0.9%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Verma 2005 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Verma, 2005 USA 15653029 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Verma, 2005 USA 15653029 | - Symptomatic any type of AF refractory to at least two AADs; - First-time PVAI | - Previous PVAI; - Any previous catheter ablation; - Previous cardiac surgery | 01/2002–08/2003 | 2 mo | Patients with LA scar (defined as a complete absence of electrogram by the Lasso or an absence of voltage or of bipolar voltage amplitude of ≤ 0.05 mV indistinguishable from noise) had statistically significantly larger LA size and lower LVEF than those without scar.

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Verma, 2005 USA 15653029 | Heart and Stroke Foundation of Canada | PVAI | 700 | 39 | 53 | nd | 6.1 | nd | 4.0 | 54 | C | Wide

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Verma, 2005 USA 15653029 | Yes | [complete electrical disconnection of the PV antrum from the LA (=no PV potentials by the Lasso)] | PVAI with the assessment of PVI SVC isolation | No | 8 mm | 70 | 55 | 45

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Verma, 2005 USA 15653029 | Freedom from AF | AF or atypical atrial flutter occurring beyond 2-moth post-PVAI based on patient reporting, rhythm-transmitter, Holter, and/or ECG | PVAI | 15.8 | 553 | 658
Verma, 2005 USA 15653029 | Repeat procedure | Not clearly defined** | PVAI | 15.8 | 134 | 700

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

** 18 patients did not undergo a repeat procedure although they developed relapse.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 2 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Patients with LAS | Verma, 2005 USA 15653029 | Freedom from AF | AF or atypical atrial flutter occurring beyond 2-moth post-PVAI based on patient reporting, rhythm-transmitter, Holter, and/or ECG (only the first procedure was taken into account) | PVAI | 15.8 | 18 | 42 | 43% | | 0.003 (Log-rank)
Patients without LAS | 535 | 658 | 81%
Patients with LAS | Verma, 2005 USA 15653029 | Freedom from AF | AF or atypical atrial flutter occurring beyond 2-moth post-PVAI based on patient reporting, rhythm-transmitter, Holter, and/or ECG (second procedure was also taken into account)* | PVAI | 15.8 | nd | 42 | 52% | | nd
Patients without LAS | nd | 658 | 90%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

* All patients with recurrence were assumed to undergo a second procedure although 18 of them did not in reality.

Multivariate analyses by the Cox regression showed only LA scar was a statistically significant independent predictor of late AF recurrence (HR=3.4, 95% CI, 1.3–9.4; P=0.01). Other factors taken into account in the analyses were age, non-paroxysmal AF, gender, duration of AF, the number of previous AADs, structural heart disease, LA size, LVEF, C-reactive protein, and brain natriuretic peptide. Univariate analyses showed age and non-paroxysmal AF were also statistically significant factors.

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)

No AEs reported.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Verma, 2005 USA 15653029 | No | NA | NA | Unclear | Nd/NA | Nd/NA | Yes | Yes | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Verma, 2005 USA 15653029 | | | Wide
Explanation for Applicability Grade: | | Provided exclusion criteria would be considered minor

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Verma 2007 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Verma, 2007 USA 17338763 | | | | X? | | TTe/AG

“randomly selected”???

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Verma, 2007 USA 17338763 | Symptomatic AF refractory to at least one AAD; - PVAI + ablation of CFAEs (randomly consecutively selected cases); - PVAI alone (randomly selected matched controls) | nd | nd | 2 mo

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Verma, 2007 USA 17338763 | Hear and Stroke Foundation of Canada (fellowship) | PVAI + CFAEs | 100 | 40 | 57 | 63 | 5.2 | nd | 4.3 | 53 | C | Wide
PVAI alone | 100

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Verma, 2007 USA 17338763 | Yes | 100% [All PV potentials surrounding the vein were abolished (by the Lasso) during sinus rhythm or coronary sinus pacing] | - PVAI followed by assessment of PVI (for all 200 patients); - SVC (except for patients at risk of phrenic nerve injury); - Ablation of CFAEs in the septum and anterior LA wall (for 100 patients as adjuvant therapy) | Yes* | 8 mm | 70 | 50 | 57 (PVAI + CFAEs)
44 (PVAI alone)

* 90% of adjuvant CFAEs group

Inducibility - Isuprel and CS pacing

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Verma, 2007 USA 17338763 | Freedom from AF | AF or atypical atrial flutter occurring beyond 2-moth post-PVAI based on patient reporting, rhythm-transmitter, Holter, and/or ECG | PVAI + CFAEs | 12 | 85 | 100 | 80% | | 0.054 (log-rank)
PVAI alone | 80 | 100 | 85%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

** Originally reported as recurrence rates

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 2 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Paroxysmal AF | Verma, 2007 USA 17338763 | Freedom from AF | AF or atypical atrial flutter occurring beyond 2-moth post-PVAI based on patient reporting, rhythm-transmitter, Holter, and/or ECG | PVAI + CFAEs | 12 | 52 | 60 | 87% | | 0.39 (log-rank)
PVAI alone | 51 | 60 | 85%
Persistent/Permanent AF | Verma, 2007 USA 17338763 | Freedom from AF | AF or atypical atrial flutter occurring beyond 2-moth post-PVAI based on patient reporting, rhythm-transmitter, Holter, and/or ECG | PVAI + CFAEs | 12 | 33 | 40 | 82% | | 0.047 (log-rank)
PVAI alone | | 29 | 40 | 72%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

* Originally reported as recurrence rates

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Verma, 2007 USA 17338763 | PVAI +/- ablation of CFAEs | 12 | 0/200 | 0/200 | 0/200 | nd | nd | nd | Peripheral vein hematoma (no transfusion)* | 3/200 (2%)

* Two at the femoral venous site and one at the internal jugular vein site.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Verma, 2007 USA 17338763 | No | NA | NA | Yes (0%) | nd | NA/nd | Yes | nd | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | No | Yes | Yes (83%)
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Verma, 2007 USA 17338763 | | | Wide
Explanation for Applicability Grade: | | The reported patient spectrum sounds (no exclusion criteria).

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Walczak Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Walczak 2006 Poland 16444625 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Walczak, 2006 Poland 16444625 | Highly symptomatic drug-refractory AF | nd | nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Walczak, 2006 Poland 16444625 | nd | Selective PVI (0–3 PVs)* | 60 | 70 | 48 | 64 | Nd | nd | 3.8 | 64 | C
All PVI (4 or 5 PVs)** | 20

* Three PVIs were performed in 19 patients, two PVIs in 23 patients, and only one PVI in 7 patients.

* The fifth vein was either middle vein or accessory vein.

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Walczak, 2006 Poland 16444625 | Yes | Nd [Assessed by pacing but not explicitly defined] | - Cavo-tricuspid isthmus line*; - LA roof line**; - Focal isolation or single ablation in another vein (CS, SVC, or ligament of Marshall) or in the LA or RA (crista terminalis, septum, or isthmus)*** | Yes**** | nd | 30–35 | 50–55

* 18 patients (18 in Group 1 but also 6 in Group II - reference Table II)

** 5 patients (5 patients in Group II and 1 patient I Group I)

*** Eight patients in “selective PVI” group did not undergo any PVI. 5-focal isolation or ablation in another single vein (CS...etc) and in the remaining 3 - single focal isolation in the atrium.

**** Only 30 patients

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Walczak, 2006 Poland 16444625 | Effective Rhythm Control | No or only single transient palpitation episode or atrial tachyarrhythmia lasting > 30 s | Selective PVI (0–3 PVs)* | 17 | 54 | 60 | 90% | Nd | nd
All PVI (4 or 5 PVs)** | 16 | 20 | 80% | Nd

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Nd
Was a blanking period (time when AFib episodes were not recorded) used? | nd | If yes, how long was it? | NA

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Walczak, 2006 Poland 16444625 | PVI (in 0–5 PVs) + additional ablation | 17 | 5/183 (3%)*

* The unit of analysis is each PV as explicitly reported descriptions may not necessarily be patient-based analysis. Only 4 out of 5 were symptomatic (possibly four PVs in only one patient?). Significant stenosis was defined as 70% or greater.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Walczak, 2006 Poland 16444625 | No | NA | NA | nd | nd | nd | ? | No | No | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
Explanation for Overall Quality Grade: | | | | Retrospective

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Walczak, 2006 Poland 16444625 | X
Explanation for Applicability Grade: | | Some patients did not undergo PVI

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Wang 2007 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Wang, 2007 China 17522081 | X | | | | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Wang, 2007 China 17522081 | Paroxysmal AFib | LA thrombi | 2006 | Amiodarone or class IC AAD × 1 mo | HTN 39%; CAD 4%

POPULATION

Author Year Country UI | Funding source | Intervention(s)* | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Wang, 2007 China 17522081 | nd (“No conflict of interest”) | PVI (no observation time) | 28 | 100% | 56 | 57% | 4.2 yr | nd | 3.8 cm | nd
Wang, 2007 China 17522081 | nd (“No conflict of interest”) | PVI (30 min observation) | 32 | 100% | 56 | 57% | 4.2 yr | nd | 3.8 cm | nd
PVI (60 min observation) | 30

* In groups B&C, catheter left in for observation and re-testing for isolation. All recovered PV potentials were “re-isolated by closing the gaps along the initial circular ablation lines.”

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Wang, 2007 China 17522081 | Yes | 100% implied | Circumferential PV antrum ablation encircling PVs | No | Irrigated 3.5 mm (ThermoCool Navistar) | 40 W (anterior wall) 30 W (posterior wall) | 45° max (anterior wall) 43° max (posterior wall) | 50 min
Wang, 2007 China 17522081 | Yes | 100% implied | Circumferential PV antrum ablation encircling PVs | No | Irrigated 3.5 mm (ThermoCool Navistar) | 40 W (anterior wall) 30 W (posterior wall) | 45° max (anterior wall) 43° max (posterior wall) | 84 min
94 min

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Wang, 2007 China 17522081 | Recurrence | Any atrial tachyarrhythmia (symptomatic or asymptomatic) lasting >30 secs (documented) | PVI, no observation | 6 (actual) | 7 | 18 | | | .03
| | | PVI, 30 min | | 3 | 21 | | | .03
| | | PVI, 60 min | | 1 | 21
| Recurrence | | PVI, no observation | 6.7 mo (mean) | 11 | 28 | | | .04
| | | PVI, 30 min | | 5 | 32 | | | .04
| | | PVI, 60 min | | 4 | 30

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Complete data (all patients) at 4 mo. Also data each month to mo 8 (n≥10/arm) and mo 9 (but only 14 total).

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 1 month

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Wang, 2007 China 17522081 | Circumferential PVI | | | 0/90 | 0/90 | | | | Pseudoaneurysm (treated conservatively) | 2/90

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Wang, 2007 China 17522081 | Yes | nd | nd | Yes (0%) | nd | Essentially | OK. But survival curve analysis would have been more meaningful | NA | Yes | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | Yes | No
Explanation for Overall Quality Grade: | | | | Reported data too early (incomplete data at 6 mo). ND on RCT methods.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Wang, 2007 China 17522081 | | Moderate
Explanation for Applicability Grade: | | N~30 per arm (although less at exactly 6 mo)

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Wang 2008 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Wang 2008 China 18256124 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Wang 2008 China 18256124 | Symptomatic drug refractory AF | nd | 2005-2006 | | 43 (10%) had previous procedure (ostial PVI or CPVI)

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Applicability
Wang 2008 China 18256124 | none | CPVI (WACA) | 452 | 72 | 63 | 60 | 5.2 | nd | 3.7 | nd

WACA at 35W 0.5 cm away (30W 1 cm away if posterior wall was concerned) from the ostia by 3.5 mm cooled tip (Navi-Star ThermoCool) with PV isolation as the endpoint of the procedure. No addition lines or targeted ablation by induction. Isolation was achieved at 96% (RPVs) and 93.6% (LPVs).

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Wang 2008 China 18256124 | CPVI (WACA) | Nd (just after the procedure, inferred) | nd | 4/452 (0.9%) | 2/452 (0.4%) | nd | 2/452 (0.4%) AVF 2/452 (0.4%) PA | nd

AVF=AV fistula, PA=pseudo-aneurysm

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Wang 2008 China 18256124 | | | X
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Wazni 2003 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Wazni 2003 US Germany Italy 14610012 | x | | | | PVI-left atrial isthmus ablation with or without cavotricuspid isthmus (CTI) ablation in patients with AF and AFL; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Wazni 2003 US Germany Italy 14610012 | 1 documented episode of typical AFL while not on AAD; AF and AFL, failed or could not tolerate AADs | intracardiac thrombi | 2000-2002 | nd | all patients have AFL and AF

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Wazni 2003 US Germany Italy 14610012 | nd | PV-LAJ disconnection + CTI | 49 | 59 | 55 | 81 | 5.5 | nd | 4.2 | 53 | B | moderate
PV-LAJ disconnection | 59

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Wazni 2003 US Germany Italy 14610012 | y | 100% (?) [not defined] In Marrouche 2003: PV isolation: abolition of all ostial PV potentials recorded on the circular mapping catheter during SR or CS and RA pacing | PV-LAJ disconnection (described in Marrouche 2003); For CTI: protocol to assess bidirectional block (prove the existence of double potentials along the ablation line separated by ≥100 ms during sinus rhythm; also assessed during pacing from both sides of the ablation line) | n | cool-tipped 4mm (EP Technologies) | nd | 35 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Wazni 2003 US Germany Italy 14610012 | AF recurrence | nd | PV-LAJ disconnection + CTI | >8 Wk | 7 | 49 | 14%
| | | PV-LAJ disconnection | | 6 | 59 | 10% | | NS
| AF recurrence | KM analysis | PV-LAJ disconnection + CTI | 12 mo | 0 | 42 | 0
| | | PV-LAJ disconnection | | 0 | 53 | 0 | | NS
| AFL recurrence only | nd | PV-LAJ disconnection + CTI | >8 Wk | 0 | 49 | 0
| | | | | 3 | 59 | 5% | | NS

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y (not defined)
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 2 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Wazni 2003 US Germany Italy 14610012 | PV-LAJ disconnection + CTI | | moderate (50–70%) asymptomatic, 1/49 (2%) | | 0/49
| PV-LAJ disconnection | | moderate (50–70%) asymptomatic, 1/59 (1.7%) | | 0/59

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Wazni 2003 US Germany Italy 14610012 | y | nd | n | y | n | nd | y | nd | y | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | n | y | y | nd
Explanation for Overall Quality Grade: | | | | randomization technique not reported; recurrence not fully defined

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Wazni 2003 US Germany Italy 14610012 | | X
Explanation for Applicability Grade: | | N <100 per arm

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

Wazni 2005 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Wazni 2005 Germany Italy 15928285 | x | | | | PVI (first line therapy) vs. AAD (first line therapy); KQ 1, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Wazni 2005 Germany Italy 15928285 | monthly symptomatic AF ≥ 3 mo | <18 y or > 75 y, hx of AF ablation, open heart surgery, AAD, contraindication to long-term anticoagulants, atrial flutter | 2001-2002 | nd | warfarin initiated in all pts in ADD and maintained throughout the study; warfarin in PVI group for ≥ 3 mo (continued if AF recurrence, or ≥ 50% PV narrowing); target INR 2–3

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Wazni 2005 Germany Italy 15928285 | Industry | PVI (First line therapy) | 33 | 96 | 54 | nd | 0.4 | nd | nd | 54 | B (from A) | Moderate
AAD (First line therapy) (max tolerable dose; flecainide 100–150 mg or sotalol 120–160 mg bid, or propafenone 225–300 mg tid) | 37

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Wazni 2005 Germany Italy 15928285 | Yes | 100% [no PV potential or electrical dissociation] | none | No | 8 mm | nd | nd | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Mean Follow-up, mo | Intervention | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Wazni 2005 Germany Italy 15928285 | symptomatic AF recurrence | >15 s during Holter or event monitoring | 12 mo | PVI | 4 | 32
| | | | AAD | 22 | 35 | | | <0.001
| hospitalization | | 12 mo | PVI | 3 | 32
| | | | AAD | 19 | 35 | | | <0.001
| thromboembolic events | TIA, stroke, DVT, or PE | | PVI | 0 | 32
| | | | AAD | 0 | 35 | | | N/A
| PV stenosis | mild <50%; moderate 50–70%; severe >70% | 12 mo | PVI | 1 mild; 1 moderate | 32
| | | | AAD | 0 | 35 | | | 0.50

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 2 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference btw groups | P between
Wazni 2005 Germany Italy 15928285 | QOL | SF-36 physical functioning subscale | score (1–100) | PVI | 6 mo | 32 | 71 | 97 | 20 (95%CI 13.2 to 24.2) | 0.001
AAD | | 35 | 69 | 75
| | SF-36 mental health subscale | score (1–100) | PVI | 6 mo | 32 | 65 | 65 | -4 (95%CI -3.5 to -7.5) | 0.62
AAD | | 35 | 64 | 68

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | PV Stenosis, n/N | Cardiac Tamponade, n/N (%) | Stroke, n/N | Esophageal Perforation, n/N | Peripheral Vascular Complications, n/N | 30-Day Mortality, n/N | Other Major AE, n/N
Wazni 2005 Germany Italy 15928285 | PVI | moderate 1/32 | | 0/32 | | | | bleeding (not defined) | 2/32
| AAD | 0/35 | | 0/35 | | | | bleeding | 1/35

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Wazni 2005 Germany Italy 15928285 | Yes | Yes | No | Yes | nd | Yes | Yes | NA | Yes | B (from A)
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | Yes | Yes | Yes | Yes
Explanation for Overall Quality Grade: | | | | Discrepant descriptions on rhythm control on the text and the presented K-M curves

* observational study cannot be an A, retrospective study is always a C

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Wazni 2005 Germany Italy 15928285 | | X
Explanation for applicability grade | relatively small sample size in each arm

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Wazni 2005 Germany Italy 15928285 | only 2/8 SF-36 subscales presented here; 5/8 subscales significantly better in the PVI group

Wazni 2007 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Wazni 2007 US 17998456 | | x | | | after RFA: Enoxaparin 1 mg/kg bid vs. 0.5 mg/kg bid vs. usual warfarin dose; KQ 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Wazni 2007 US 17998456 | consecutive patients with persistent AF undergoing PV antrum isolation | nd | nd | | all pts have persistent AF; adverse events only

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Wazni 2007 US 17998456 | nd | post RFA Enoxaparin 1 mg/kg bid vs. 0.5 mg/kg bid vs. warfarin (to keep INR 2–3.5) | 105 | 0 | 55 | 78 | nd | nd | 4.4 | 54 | not rated | moderate
Wazni 2007 US 17998456 | nd | post RFA Enoxaparin 1 mg/kg bid vs. 0.5 mg/kg bid vs. warfarin (to keep INR 2–3.5) | 100 | 0 | 55 | 78 | nd | nd | 4.4 | 54 | not rated | moderate
150 | 0

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Wazni 2007 US 17998456 | nd | Nd [abolition of all ostial PV potentials recorded on the circular mapping catheter during sinus rhythm or coronary sinus and right atrial pacing(see Marrouche 2003] | see Marrouche 2003 and Wazni 2005 | n | 8 mm | nd | nd | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed?
Was a blanking period (time when AFib episodes were not recorded) used? | | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Wazni 2007 US 17998456 | post RFA Enoxaparin 1 mg/kg bid | | | | 1/105 (1%) | | | | mild pericardial effusion | 1/105 (1%)
Wazni 2007 US 17998456 | post RFA Enoxaparin 1 mg/kg bid | | | | 1/105 (1%)
Wazni 2007 US 17998456 | post RFA Enoxaparin 1 mg/kg bid | | | | 1/105 (1%) | | | | bleeding requiring hospitalization | 10/105 (10%)
bleeding requiring transfusion | 9/105 (9%)
pseudo aneurysms requiring thrombin | see footnote*
| post RFA Enoxaparin 0.5 mg/kg bid | | | | 2/100 (2%) | | | | symptomatic pericardial effusion requiring pericardiocentesis | 2/100 (2%)
| post RFA Enoxaparin 0.5 mg/kg bid | | | | 2/100 (2%)
| post RFA Enoxaparin 0.5 mg/kg bid | | | | 2/100 (2%) | | | | bleeding requiring hospitalization | 10/105 (10%0
bleeding requiring transfusion
pseudo aneurysms requiring thrombin | see footnote*
| post RFA usual warfarin (to keep INR 2–3.5) | | | | 0/150 (0%) | | | | mild pericardial effusion | 1/150 (0.6%)
| post RFA usual warfarin (to keep INR 2–3.5) | | | | 0/150 (0%) | | | | bleeding requiring hospitalization | 2/150 (1.3%)
| post RFA usual warfarin (to keep INR 2–3.5) | | | | 0/150 (0%)
bleeding requiring transfusion
pseudo aneurysms requiring thrombin | 2/150 (1.3%)

* post RFA Enoxaparin 1 mg/kg bid group and post RFA Enoxaparin 0.5 mg/kg bid combined had 3/205 patients with pseudo aneurysms requiring thrombin

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Wazni 2007 US 17998456 | no | NA | NA | | n | n | nd | n | y
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | nd | nd | nd | nd | nd
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Wazni 2007 US 17998456 | | x
Explanation for Applicability Grade: | | all with persistent AF

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Willems Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Willems, 2006 Germany 16782716 | X | | | | RCT of PVI vs. PVI+ Substrate modification (additional lines) | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Willems 2006 Germany 16782716 | >2 failed attempts of an anti-arrhythmic drug therapy for symptomatic AF episodes; persistent AF lasting for >1 month | Patients with concomitant severe heart disease and impaired systolic left ventricular function (LVEF<40%) and/or LA enlargement >55 mm | nd | Flecainide (n=6), propafenone (n=1), sotalol (n=3) for up to 8 weeks | 8 patients (4 in each group) had CAD

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Willems, 2006 Germany 16782716 | nd | PVI: circumferential (Lasso) PVI plus cavotricuspid isthmus ablation (right atrial isthmus ablation). | 62 | 0 | 59 | nd | 6 (range 1.5–10) | nd | 4.8 | ≥40 | A | Moderate
PVI+SM (substrate modification): same as PVI group following additional left linear ablation connecting the posterior ablation line of the left and right superior PV at the posterior part of the superior LA.

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Willems, 2006 Germany 16782716 | yes | (1) PVI group: 100% [Completely PV block indicated by elimination or dissociation of all PV potentials during sinus rhythm. This was validated by pacing at coronary sinus or LA appendage.] | Cavotricuspid isthmus RFA | no | Open irrigated tip (Celsius ThermoCool, Biosense Webster Inc.) | 30 | nd | 32.3
| yes | (2) PVI+SM group: 100% PVI, 72% linear ablation in the LA, 44% block for the roof-line [Same as group 1 in addition to complete conduction block for linear ablation in the LA. Evaluation of the roof-line was performed by mapping a corridor of double potentials along the line during LA appendage pacing] | Cavotricuspid isthmus RFA Roof line: line connecting the posterior ablation line of the left and right superior PV at the posterior part of the superior LA Mitral line: LIPV to MA Validation of lines via activation sequence | no | Open irrigated tip (Celsius ThermoCool, Biosense Webster Inc.) | PVI: 30 SM: 50; 40* | 50 | PVI: 35.7 SM: 23.7

* The maximum power level was adjusted from 50 W to 40 W after 4 patients following the reports of cases with cardiac tamponade during linear LA ablation.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Willems, 2006 Germany 16782716 | Sinus rhythm | Lack of any symptomatic or asymptomatic AF episode (>30 s) documented by conventional or Tele-ECG recording. Suspected LA flutter was also considered as recurrence due to the fact that the differentiation using Tele-ECG criteria can be impossible | PVI | Median 16 (range 14–18) | 6 | 30 | | | 0.0001 (log-rank test)
PVI+SM | Median 17 (range 15–19) | 22 | 32

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes (each patient received a Tele-ECG recorder that could record an ECG for a 1-min duration. Patients were advised to record and transmit at least one ECG per day irrespective of the symptoms. ECGs were transmitted to a central lab using a regular telephone)
Was a blanking period (time when AFib episodes were not recorded) used? | no | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Willems, 2006 Germany 16782716 | PVI+SM | nd | | 1/32 (3%)* | 1/32 (3%)**

* During LA isthmus ablation with 50 W, which was immediately drained without further complication. After limiting the maximum power level to 40 W for LA isthmus ablation, neither cardiac tamponade nor pericardial effusion occurred.

** minor ischemic stroke accompanied by dizziness occurring the day after ablation.

Note: The two patients who had procedure-related complications recovered subsequently without sequelae. No procedure-related complications in PVI group.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Willems, 2006 Germany 16782716 | Yes (not for our report purpose) | yes | nd | 0% | nd | yes (0% dropout) | yes | yes | yes | B
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | yes | yes | yes | no
Explanation for Overall Quality Grade: | | | | unclear what proportion of patients remained on AADs at followup

* observational study cannot be an A, retrospective study is always a C

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Willems, 2006 Germany 16782716 | | X
Explanation for Applicability Grade: | | N<100; persistent AF only

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Willems, 2006 Germany 16782716 | In 9/10 patients with recurrences in the PVI+SM group, ablation of .1 line was incomplete including 4 patients with 2 incomplete lines (mitral isthmus: n=5, roof-line: n=8). Only 1 patient with 2 incomplete lines was in sinus rhythm during follow-up (mean 17 months). Repeat MRI and transesophageal echo did not reveal narrowing or enhanced flow velocity in any of the investigated patients.

Yamada Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Yamada, 2006 Japan 16607049 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Yamada, 2006 Japan 16607049 | Symptomatic paroxysmal AF refractory to AADs | nd | nd | No (all AADs were discontinued)

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Yamada, 2006 Japan 16607049 | Ministry of Health, Labour, and Welfare, Japan | Segmental ostial PVI | 108 | 100 | 57 | 90 | 4 | nd | 3.5 | 66 | C | Moderate

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Yamada, 2006 Japan 16607049 | Yes | Nd [the abolition or dissociation of the distal PV potentials] | (SOCA) Additional RF to the gaps between periostial ablation sites in the PVs to prevent the recovery of electrical connections (only for patients to whom RF was delivered by a 8 mm catheter) | No | 4 mm (nd) | 30 | 55
8 mm (Blazer II) | 40 | 55

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Yamada, 2006 Japan 16607049 | Re-procedure | Unclear definition | Segmental ostial PVI | 6 | 27 | 108

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes
Was a blanking period (time when AFib episodes were not recorded) used? | nd | If yes, how long was it? | NA

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Segmental ostial PVI (4 mm) | Yamada, 2006 Japan 16607049 | Freedom from recurrence at 6 mo | No explicit definition of recurrence and post-procedure blanking period (after first procedure) | Segmental ostial PVI | 6 | 25 | 47 | 53% | | nd
Segmental ostial PVI (8 mm) | 41 | 61 | 68%
Segmental ostial PVI (4 mm) | Yamada, 2006 Japan 16607049 | Re-procedure | Unclear definition | Segmental ostial PVI | 6 | 8 | 47 | | | nd
Segmental ostial PVI (8 mm) | 10 | 61
Segmental ostial PVI (4 mm) | Yamada, 2006 Japan 16607049 | Freedom from recurrence at 6 mo | No explicit definition of recurrence and post-procedure blanking period (after multiple procedure) | Segmental ostial PVI | 6 | 25 | 47 | 66% | | <0.05 (log-rank)
Segmental ostial PVI (8 mm) | 41 | 61 | 84%

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Yamada, 2006 Japan 16607049 | Segmental ostial PVI | 6 | 0/108 | 0/108 | 0/108 | nd | nd | nd

“No critical complications occurred in any cases.”

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Yamada, 2006 Japan 16607049 | No | NA | NA | Yes (100%) | NA | NA | Yes | nd | Yes | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | Yes | Yes | No
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Yamada, 2006 Japan 16607049 | | moderate
Explanation for Applicability Grade: | | Only patients with paroxysmal AF

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Yamane 2002 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Yamane, 2002 France 11955852 | | | | X | | TTe/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Yamane, 2002 France 11955852 | Multidrug-resistant paroxysmal daily AF | nd | Nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Yamane, 2002 France 11955852 | nd | Ostial PVI* | 157 | 100 | 54 | 60 | 4.7 | nd | 3.7 | nd | C | Wide

* Earliest activation site(s) in the first 113 patients and electrogram polarity reversal site(s) in addition to earliest activation site(s) in the second 44 patients.

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Yamane, 2002 France 11955852 | Yes | 99%* [elimination of PV muscle conduction distal to the ablation site(s) by abolition or dissociation of distal potentials] | nd | Yes | Irrigated and non-irrigated (nd) | 20–30 | 50 | Nd**

* only (each) PV-based analysis available (patient-based not available).

** 8 min(/PV?) per report.

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Yamane, 2002 France 11955852 | Free from AF | Free from AF without AAD. Recurrent AF and blanking period not explicitly defined**. | Ostial PVI | 9 | 106 | 157 | 74%
Yamane, 2002 France 11955852 | Re-procedure | No reasons to undergo a re-procedure reported | Ostial PVI | 9 | 60 | 157
Yamane, 2002 France 11955852 | Free from AF | Free from AF. Recurrent AF and blanking period not explicitly defined***. | Ostial PVI | 9 | 93 | 157 | 59%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

** Inferring re-procedures were also included in the analysis.

*** Inferring only first procedure was taken into account.

All results were crude estimates.

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Nd
Was a blanking period (time when AFib episodes were not recorded) used? | nd | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
1 mapping approach* | Yamane, 2002 France 11955852 | Free from AF | Free from AF. Recurrent AF and blanking period not explicitly defined**. | Ostial PVI | 9 | Nd | 113 | 42% | | NS (chi-squared)
2 mapping approaches* | nd | 44 | 39%
With cardiovascular disease | Yamane, 2002 France 11955852 | Free from AF | Free from AF. Recurrent AF and blanking period not explicitly defined**. | Ostial PVI | 9 | Nd | 23 | 39% | | NS (chi-squared)
Without cardiovascular disease | Nd | 134 | 52%

Duplicate one row per outcome and per RFA intervention.

Eg, Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

* Earliest activation site(s) in the first 113 patients and electrogram polarity reversal site(s) in addition to earliest activation site(s) in the second 44 patients were targeted.

** inferring only first procedure was taken into account.

NOTE: all results were crude estimates

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Yamane, 2002 France 11955852 | Ostial PVI | 9 | 0/157* | Nd* | nd | nd | nd | nd

* Two moderate acute stenosis (55% narrowing) and two non-severe pericardial effusions (not requiring drainage) were reported.

* no drainage, thus not hemodynamically unstable, thus NOT tamponade.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Yamane, 2002 France 11955852 | No | NA | NA | nd | NA/nd | NA/nd | No? | No | No | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | Yes | No | unclear | Unclear/no | NA
Explanation for Overall Quality Grade: | | | | Retrospective. Details on statistical analyses were not provided.

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Yamane, 2002 France 11955852 | | | WIDE
Explanation for Applicability Grade: | | No exclusion criteria infer that patient spectrum should be similar to general patients with parox AF in clinical practice.

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Yamane 2007 Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Yamane 2007 Japan 17457004 | | x | | | ostial vs. antrum PVI; KQ 3, 4 | SI/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Yamane 2007 Japan 17457004 | AF resistant to AADs, observed for ≥12 mo | persistent AF >12 mo | nd | not on AADs | non-concurrent comparison; ostial followed up for 2.8 y; antrum followed up for 1.8 y; esophagus monitored during procedure in 50% of patients in the antral group

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Yamane 2007 Japan 17457004 | nd | ostial PVI | 70 | 63 | 52 | 74 | | | 3.85
antral PVI | 117 | 68 | 53 | 79 | | | 3.95

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Yamane 2007 Japan 17457004 | y (exclude PV <12mm and no arrhythmogenicity) | 99% in each group [bidirectional block between LA and PV] | ostial PVI - 15 or 20 mm Lasso for mapping antral PVI - 25 or 30 mm Lasso for mapping | y | 8 mm | 30–35 | 50 | 22
36

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Yamane 2007 Japan 17457004 | success | freedom from AF after 3 mo in patients with paroxysmal AF | after initial procedure: ostial PVI | 2.8 y | | | 58.7%
| | | after initial procedure: antral PVI | 1.8 y | | | 61.4% | | NS
| | freedom from AF after 3 mo in patients with persistent AF | after initial procedure: ostial PVI | | | | 32.4%
| | | after initial procedure: antral PVI | | | | 36.2% | | NS
| success | freedom from AF after 3 mo in patients with paroxysmal AF | after final procedure: ostial PVI | | | | 76%
| | | after final procedure: antral PVI | | | | 93% | | 0.015
| | freedom from AF after 3 mo in patients with persistent AF | after initial procedure: ostial PVI | | | | 48%
| | | after initial procedure: antral PVI | | | | 78% | | 0.032

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | y
Was a blanking period (time when AFib episodes were not recorded) used? | y | If yes, how long was it? | 1 mo

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Yamane 2007 Japan 17457004 | ostial PVI | | (single vein) 3/70 (4.3%) | | | | | | left atrial flutter | 1/70 (1.4%)
| antral PVI | | 0 | | | | | | left atrial flutter | 4/117 (3.4%)

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Yamane 2007 Japan 17457004 | n | NA | NA | NA (?retrospective) | n | n | y | n | y | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | y | y | y | y | y
Explanation for Overall Quality Grade: | | | | two groups not totally comparable; non-concurrent and different durations of followup

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Yamane 2007 Japan 17457004 | | x
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments

Zado Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Zado 2008 US 18462325 | | | | X | | EB/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Zado 2008 US 18462325 | Drug refractory AF | nd | 2000-2007 | Some amiodarone, mostly class IC Parox 6–12 weeks Persistent 6 mo But allowed to continue based on patient/MD preferences | 1st and repeat procedures

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Zado 2008 US 18462325 | nd (1 author reports grant money from industry) | High risk* : All 4 PV Remaining: arrhythmogenic PVs only | 1165 (1506 procedures) | 64% | 55 | 77 | nd | nd | 4.4 | <50% 11% | C

* Persistent AF, no provocable triggers, HTN, LAE, >50 y.

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Zado 2008 US 18462325 | Yes | 100% (endpoint) Defined as loss of PV potentials (entrance block) and failure to capture LA when pacing each electrode pair of circular mapping catheter (exit block) | selected non-PV triggers (13%) CTI (h/o or induced typical atrial flutter) Macro reentrant AT if identified | Yes | nd | nd | nd | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Zado 2008 US 18462325 | AF control | on or off AAD (per pt/MD preference or for previous recurrence), some with rare (≤6 episodes, 1 cardioversion max, >95% improvement) | RFA | ~28 | ~688 | 781 (67% f/up) | 88%
| No AF off AAD | (underestimates because excludes those who chose to remain on AAD despite no AF) | RFA | ~28 | ~496 | 781 (67% f/up) | 63%

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | Yes, but minimal attempt to capture ASx
Was a blanking period (time when AFib episodes were not recorded) used? | Yes | If yes, how long was it? | 8 wk

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Data reported by age group (<65, 65–74, ≥75) though no differences by age. | Zado 2008 US 18462325

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Zado 2008 US 18462325 | RFA | | 1/1506* (0.07%) | 12/1506* (0.8%) | CVA/TIA 6/1506* (0.4%) | 1/1506* (0.07%) Fistula | 0 major | nd | Phrenic nerve injury (resolved) | 2/1506* (0.13%)
| | | | | | | | | Anaphylaxis | 2/1506* (0.13%)
| | | | | | | | | Retroperitoneal bleed | 1/1506* (0.07%)

* in 1165 patients

25 major complications in 1506 procedures in 1165 patients.

* Six patients had PV stenosis >70% detected on CT or MRI but only one required intervention because of symptoms.

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Zado 2008 US 18462325 | No | NA | NA | No | No | No | No | No | +/- | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | No | Yes | No | Marginally | No
Explanation for Overall Quality Grade:

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Zado 2008 US 18462325
Explanation for Applicability Grade:

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments
Zado 2008 US 18462325 | Very likely large overlap with multiple other articles from UPenn

Zhou Evidence Tables

STUDY DESIGN

Author Year Country UI | RCT | Non-randomized comparative | Prospective cohort | Retrospective cohort | Others (Explain) | Extractor
Zhou, 2007 China 17624261 | | | x | | | MC/AG

ELIGIBILITY CRITERIA AND OTHER CHARACTERISTICS

Author Year Country UI | Inclusion | Exclusion | Enrollment Years | Post RFA Anti-Arrhythmics (Time) | Other Important Characteristics
Zhou, 2007 China 17624261 | Patients with persistent or paroxysmal AF who received PVI who had >1 risk factor for atrial thrombus formation received routine anticoagulation therapy prior and post ablation. The risk factors for atrial thrombus formation were as follows: (1) ≥65 years of age; (2) hypertension; (3) diabetes; (4) history of transient ischemic attack or stroke; (5) history of congestive heart failure or left ventricular end-diastolic diameter (LVED) >56 mm | None reported | July 2004 to January 2006 | nd

POPULATION

Author Year Country UI | Funding source | Intervention(s) | N enrolled | % Paroxysmal AF | Mean Age, yr | Male, % | Mean Symptom Duration, yr | CHF, % | Mean LAD, cm | Mean LVEF, % | Quality | Applicability
Zhou, 2007 China 17624261 | National natural Science Foundation of China | Circumferential PVI | 148 | 56.8 | 61 | 64 | Paroxysmal AF=2.3 Persistent AF=3.6* (p<.05 compared to paroxysmal AF) | nd | Paroxysmal AF=4.4 Persistent AF=4.8* (p<.002 compared to paroxysmal AF) | nd

RADIOFREQUENCY ABLATION CHARACTERISTICS

Author Year Country UI | PVI (y/n) | Isolation % Success (percent of patients) [Defn of Isolation] | Others (WACA, CFAE, Other Lines, Ganglionic Plexi) | Checked Inducibility (y/n) | Catheter Tip | Energy
Watts | Max Temp, °C | Total Ablation Time, min
Zhou, 2007 China 17624261 | yes | 100% [disappearance of potential of all PVs on the pulmonary circling electrode (Lasso), or disassociation of the PV potential and atrial electrical activity] | none | no | 8-mm or irrigated tip (Navistar, Biosense Webster) | 50 | 8-mm: 55 Irrigated: 40 | nd

RESULTS (dichotomized or categorical outcomes)

Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Zhou, 2007 China 17624261 | AF recurrence | nd | Circumferential PVI | 7.4 | 11 | 148

Duplicate one row per outcome and per RFA intervention.

* Type in metric. For example: “OR=1.7” or “HR=0.9”

Did the (recurrence) outcome include asymptomatic AFib? e.g., Was 24 hour or greater ECG screening performed? | nd
Was a blanking period (time when AFib episodes were not recorded) used? | nd | If yes, how long was it?

RESULTS (continuous measures)

Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

SUBGROUP ANALYSIS (dichotomized or categorical outcomes)

Subgroup | Author Year Country UI | Outcome | Definition | Intervention | Mean Follow-up, mo | n Event | N Total | Unadjusted | | | Adjusted
Result* | 95% CI | P btw | Result* | 95% CI | P btw
Paroxysmal AF | Zhou, 2007 China 17624261 | AF recurrence | nd | Circumferential PVI | 7.4 | 4 | 84 | | | 0.21
Persistent AF | | | | | | 7 | 64

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

SUBGROUP ANALYSIS (continuous measures)

Subgroup | Author Year Country UI | Outcome | Definition | Unit | Intervention | Mean Follow-up, mo | No. Analyzed | Baseline | Final | Net difference | P between

Duplicate one row per outcome and per RFA intervention.

e.g., Subgroups = male/female; age group (<50, 50–70, >70); CHF (+/-); chronic/persistent/paroxysmal; others

ADVERSE EVENTS

Author Year Country UI | Intervention | Mean Follow-up, mo | PV Stenosis (Severity), n/N (%) | Cardiac Tamponade, n/N (%) | Stroke, n/N (%) | Esophageal Perforation, n/N (%) | Peripheral Vascular Complications, n/N (%) | 30-Day Mortality, n/N (%) | Other Major AE, n/N (%)
Zhou, 2007 China 17624261 | Circumferential PVI | | | | | | | 1/148 (0.7%)** | Thrombus formation | Persistent AF: 4/64 (6.3%) Paroxysmal AF: 0/84 (0%)* (p=.033 compared to persistent AF)

** 72-year-old male paroxysmal AF patient with hypertension, CHD and history of PCI, died of pulmonary infection 3 weeks post PVI

The following information will not be in the summary tables.

QUALITY

Author Year Country UI | RCT (y/n) | Appropriate Randomization Technique (y/n/nd/NA) | Allocation Concealment (y/n/nd/NA) | Dropout Rate <20% | Blinded Outcome Assessment (y/n/nd) | Intention to Treat Analysis (y/n/nd) | Appropriate Statistical Analysis (y/n) | Assessment for Confounding (y/n/nd/NA) | Clear Reporting with No Discrepancies (y/n) | OVERALL Grade*
Zhou, 2007 China 17624261 | no | NA | NA | 0 (assumed) | nd | Yes (0% dropout) | yes | yes | no | C
| | Was RFA Procedure Adequately Described? | Were the Recurrence Outcomes Fully Defined? | Was Success Rate After a Single Procedure (not including redo) Reported? | Was Asymptomatic AFib Screened For? | Was Compliance with Screening Reported?
| | yes | no | no | no | no
Explanation for Overall Quality Grade: | | | | No data on AAD use, no data on ablation time, poor outcome reporting

* observational study cannot be an A, retrospective study is always a C

N must be ≥100 per intervention for quality to be an A

APPLICABILITY ASSESSMENT

Author Year Country UI | Applicable to study population only (Narrow)* | Applicable to study population and others with some difficulty (Moderate) | Applicable to study population and others with ease (Wide)**
Zhou, 2007 China 17624261 | | x
Explanation for Applicability Grade: | | Targeting a specific group of patients (see inclusion criteria)

* If N<30 per intervention, then applicability is narrow

** N must be ≥100 per intervention for applicability to be wide

SPECIFIC COMMENTS CONCERNING THE STUDY

Author Year Country UI | Comments