# Search Strategy

Database: MEDLINE^®^ and Cochrane Central Trials Registry (CCTR) (1995-December 2008)

Number | Search History
1 | atrial fibrillation.mp. or exp Atrial Fibrillation/
2 | pulmonary vein$.mp. or exp Pulmonary Veins/
3 | 1 or 2
4 | exp Catheter Ablation/ or radiofrequency ablation.mp.
5 | radiofrequency catheter ablation.mp. or exp Catheter Ablation/
6 | ablation.mp.
7 | radiofrequency.mp.
8 | (catheter adj ablation).mp. [mp=ti, ot, ab, nm, hw, sh, kw]
9 | or/4–8
10 | 3 and 9
11 | limit 10 to (humans and yr=“1995 - 2008”) [Limit not valid in CCTR; records were retained]
12 | limit 11 to (addresses or bibliography or biography or case reports or comment or editorial or lectures or legal cases or letter or news or newspaper article or “review”) [Limit not valid in CCTR; records were retained]
13 | 11 not 12