# Appendixes

Appendix A Search Strategy

Appendix B List of Excluded Studies

Appendix C Evidence Tables

Appendix D Panel of Expert Reviewers