# References

1 Lalakea ML, Messner AH. Ankyloglossia: does it matter?. Pediatr Clin North Am. Apr. 2003;50(2):381-97. [pmid: 12809329].
2 Suter VG, Bornstein MM. Ankyloglossia: facts and myths in diagnosis and treatment. J Periodontol. Aug. 2009;80(8):1204-19. [pmid: 19656020].
3 Hong P, Lago D, Seargeant J, et al. Defining ankyloglossia: a case series of anterior and posterior tongue ties. Int J Pediatr Otorhinolaryngol. Sep. 2010;74(9):1003-6. [pmid: 20557951].
4 Messner AH, Lalakea ML. Ankyloglossia: controversies in management. Int J Pediatr Otorhinolaryngol. Aug. 31. 2000;54(2-3):123-31. [pmid: 10967382].
5 Rowan-Legg A. Canadian Paediatric Society position statement: ankyloglossia and breastfeeding. Canadian Paediatric Society. 2014. www.cps.ca/en/documents/position/ankyloglossia-breastfeeding. March 23, 2015.
6 Fiorotti RC, Bertolini MM, Nicola JH, et al. Early lingual frenectomy assisted by CO2 laser helps prevention and treatment of functional alterations caused by ankyloglossia. Int J Orofacial Myology. Nov. 2004;30:64-71. [pmid: 15832863].
7 Buryk M, Bloom D, Shope T. Efficacy of neonatal release of ankyloglossia: a randomized trial. Pediatrics. Aug. 2011;128(2):280-8. [pmid: 21768318].
8 Emond A, Ingram J, Johnson D, et al. Randomised controlled trial of early frenotomy in breastfed infants with mild-moderate tongue-tie. Arch Dis Child Fetal Neonatal Ed. Nov. 18. 2013;99(3):F189-95. [pmid: 24249695].
9 Baghurst P, Pincombe J, Peat B, et al. Breast feeding self-efficacy and other determinants of the duration of breast feeding in a cohort of first-time mothers in Adelaide, Australia. Midwifery. Dec. 2007;23(4):382-91. [pmid: 17126967].
10 Pollard D, Guill M. The relationship between baseline self-efficacy and breastfeeding duration. Southern Online Journal of Nursing Research. 2009;9(4):8p.
11 Matthews MK. Developing an instrument to assess infant breastfeeding behaviour in the early neonatal period. Midwifery. Dec. 1988;4(4):154-65. [pmid: 3210979].
12 Jensen D, Wallace S, Kelsay P. LATCH: a breastfeeding charting system and documentation tool. J Obstet Gynecol Neonatal Nurs. Jan. 1994;23(1):27-32. [pmid: 8176525].
13 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(12)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014.
14 Agency for Healthcare Research and Quality. Ankyloglossia Systematic Review Protocol. Effective health care program. Rockville, MD. Agency for Healthcare Research and Quality. http://www.effectivehealthcare.ahrq.gov/ehc/products/558/1931/Ankyloglossia-protocol-140630.pdf. December 17, 2014.
15 Eunice Kennedy Shriver National Institute of Child Health and Human Development, National Institutes of Health (NIH), Department of Health & Human Services (DHHS). Preterm Labor and Birth: Condition Information [Internet]. Bethesda, MD. National Institute of Child Health and Human Development, National Institutes of Health. 2014. http://www.nichd.nih.gov/health/topics/preterm/conditioninfo/Pages/default.aspx. December 17, 2014.
16 Higgins JPT, Green S. Cochrane Handbook for Systematic Reviews of Interventions. The Cochrane Collaboration. 2011.
17 Viswanathan M, Berkman ND, Dryden DM. Assessing Risk of Bias and Confounding in Observational Studies of Interventions or Exposures: Further Development of the RTI Item Bank [Internet]. Rockville, MD. Agency for Healthcare Research and Quality. 2013.
18 Santaguida P, Raina P. McMaster Quality Assessment Scale of Harms (McHarm) for primary studies: Manual for use of the McHarm.
19 Berkman ND, Lohr KN, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). 2008.
20 Berry J, Griffiths M, Westcott C. A double-blind, randomized, controlled trial of tongue-tie division and its immediate effect on breastfeeding. Breastfeed Med. Jun. 2012;7(3):189-93. [pmid: 21999476].
21 Dollberg S, Botzer E, Grunis E, et al. Immediate nipple pain relief after frenotomy in breast-fed infants with ankyloglossia: a randomized, prospective study. J Pediatr Surg. Sep. 2006;41(9):1598-600. [pmid: 16952598].
22 Heller J, Gabbay J, O'Hara C, et al. Improved ankyloglossia correction with four-flap Z-frenuloplasty. Ann Plast Surg. Jun. 2005;54(6):623-8. [pmid: 15900148].
23 Hogan M, Westcott C, Griffiths M. Randomized, controlled trial of division of tongue-tie in infants with feeding problems. J Paediatr Child Health. May-Jun. 2005;41(5-6):246-50. [pmid: 15953322].
24 Walls A, Pierce M, Wang H, et al. Parental perception of speech and tongue mobility in three-year olds after neonatal frenotomy. Int J Pediatr Otorhinolaryngol. Jan. 2014;78(1):128-31. [pmid: 24315215].
25 Steehler MW, Steehler MK, Harley EH. A retrospective review of frenotomy in neonates and infants with feeding difficulties. Int J Pediatr Otorhinolaryngol. Sep. 2012;76(9):1236-40. [pmid: 22704670].
26 Dollberg S, Manor Y, Makai E, et al. Evaluation of speech intelligibility in children with tongue-tie. Acta Paediatr. Sep. 2011;100(9):e125-7. [pmid: 21401716].
27 Srinivasan A, Dobrich C, Mitnick H, et al. Ankyloglossia in breastfeeding infants: the effect of frenotomy on maternal nipple pain and latch. Breastfeed Med. Winter. 2006;1(4):216-24. [pmid: 17661602].
28 Blenkinsop A. A measure of success: audit of frenulotomy for infant feeding: problems associated with tongue-tie. MIDIRS Midwifery Digest. 2003;13(3):389-92.
29 Ridgers I, McCombe K, McCombe A. A tongue-tie clinic and service. Br J Midwifery. 2009;17(4):230-3.
30 Edmunds JE, Fulbrook P, Miles S. Understanding the experiences of mothers who are breastfeeding an infant with tongue-tie: a phenomenological study. J Hum Lact. 2013;29(2):190-5. [pmid: 23515085].
31 O'Callahan C, Macary S, Clemente S. The effects of office-based frenotomy for anterior and posterior ankyloglossia on breastfeeding. Int J Pediatr Otorhinolaryngol. May. 2013;77(5):827-32. [pmid: 23523198].
32 Sethi N, Smith D, Kortequee S, et al. Benefits of frenulotomy in infants with ankyloglossia. Int J Pediatr Otorhinolaryngol. May. 2013;77(5):762-5. [pmid: 23453795].
33 Marchesan IQ, Martinelli RL, Gusmao RJ. Lingual frenulum: changes after frenectomy. J Soc Bras Fonoaudiol. 2012;24(4):409-12. [pmid: 23306695].
34 Choi YS, Lim JS, Han KT, et al. Ankyloglossia correction: Z-plasty combined with genioglossus myotomy. J Craniofac Surg. Nov. 2011;22(6):2238-40. [pmid: 22134257].
35 Miranda BH, Milroy CJ. A quick snip - A study of the impact of outpatient tongue tie release on neonatal growth and breastfeeding. J Plast Reconstr Aesthet Surg. Sep. 2010;63(9):e683-5. [pmid: 20493791].
36 Khoo AK, Dabbas N, Sudhakaran N, et al. Nipple pain at presentation predicts success of tongue-tie division for breastfeeding problems. Eur J Pediatr Surg. Dec. 2009;19(6):370-3. [pmid: 19750457].
37 Yeh ML. Outpatient division of tongue-tie without anesthesia in infants and children. World J Pediatr. May. 2008;4(2):106-8. [pmid: 18661764].
38 Geddes DT, Langton DB, Gollow I, et al. Frenulotomy for breastfeeding infants with ankyloglossia: effect on milk removal and sucking mechanism as imaged by ultrasound. Pediatrics. Jul. 2008;122(1):e188-94. [pmid: 18573859].
39 Wallace H, Clarke S. Tongue tie division in infants with breast feeding difficulties. Int J Pediatr Otorhinolaryngol. Jul. 2006;70(7):1257-61. [pmid: 16527363].
40 Amir LH, James JP, Beatty J. Review of tongue-tie release at a tertiary maternity hospital. J Paediatr Child Health. May-Jun. 2005;41(5-6):243-5. [pmid: 15953321].
41 Griffiths DM. Do tongue ties affect breastfeeding?. J Hum Lact. Nov. 2004;20(4):409-14. [pmid: 15479660].
42 Lalakea ML, Messner AH. Ankyloglossia: the adolescent and adult perspective. Otolaryngol Head Neck Surg. May. 2003;128(5):746-52. [pmid: 12748571].
43 Messner AH, Lalakea ML. The effect of ankyloglossia on speech in children. Otolaryngol Head Neck Surg. Dec. 2002;127(6):539-45. [pmid: 12501105].
44 Ballard JL, Auer CE, Khoury JC. Ankyloglossia: assessment, incidence, and effect of frenuloplasty on the breastfeeding dyad. Pediatrics. Nov. 2002;110(5):e63. [pmid: 12415069].
45 Masaitis NS, Kaempf JW. Developing a frenotomy policy at one medical center: a case study approach. J Hum Lact. Sep. 1996;12(3):229-32. [pmid: 9025430].
46 Godley FA. Frenuloplasty with a buccal mucosal graft. Laryngoscope. Mar. 1994;104(3 Pt 1):378-81. [pmid: 8127197].
47 Dave J, Sinha V, Barot D, et al. Speech disorders encountered in routine ENT practice and the role of speech therapy in its effective management. Indian Journal of Otology. October-December. 2013;19(4):169-72.
48 Klockars T, Pitkaranta A. Pediatric tongue-tie division: indications, techniques and patient satisfaction. Int J Pediatr Otorhinolaryngol. Oct. 2009;73(10):1399-401. [pmid: 19660817].
49 Mettias B, O'Brien R, Abo Khatwa MM, et al. Division of tongue tie as an outpatient procedure. Technique, efficacy and safety. Int J Pediatr Otorhinolaryngol. Apr. 2013;77(4):550-2. [pmid: 23411135].
50 Argiris K, Vasani S, Wong G, et al. Audit of tongue-tie division in neonates with breastfeeding difficulties: how we do it. Clin Otolaryngol. Jun. 2011;36(3):256-60. [pmid: 21752209].
51 Puthussery FJ, Shekar K, Gulati A, et al. Use of carbon dioxide laser in lingual frenectomy. Br J Oral Maxillofac Surg. Oct. 2011;49(7):580-1. [pmid: 20728254].
52 Dollberg S, Marom R, Botzer E. Lingual frenotomy for breastfeeding difficulties: a prospective follow-up study. Breastfeed Med. Jun. 2014;3:286-9. [pmid: 24892968].
53 Finigan V. Overcoming tongue-tie. Midwives. 2014;17(3):48-9. [pmid: 24960964].
54 Ito Y, Shimizu T, Nakamura T, et al. Effectiveness of tongue-tie division for speech disorder in children. Pediatr Int. 2014. Aug. 20. [pmid: 25142274].
55 Riskin A, Mansovsky M, Coler-Botzer T, et al. Tongue-tie and breastfeeding in newborns-mothers' perspective. Breastfeed Med. Nov. 2014;9:430-7. [pmid: 25290824].
56 Toner D, Giordano T, Handler SD. Office frenotomy for neonates: resolving dysphagia, parental satisfaction and cost-effectiveness. ORL Head Neck Nurs. Spring. 2014;32(2):6-7. [pmid: 24937906].
57 Rose K, Kasbekar AV, Flynn A, et al. Developing a Nurse-Delivered Frenulotomy Service. Otolaryngol Head Neck Surg. 2014. Oct. 22. [pmid: 25338668].
58 Sirinoglu H, Certel F, Akgun I. Subacute massive edema of the submandibular region after frenuloplasty. J Craniofac Surg. Jan. 2013;24(1):e74. [pmid: 23348346].
59 Santos Tde S, Filho PR, Piva MR, et al. Mucocele of the glands of Blandin-Nuhn after lingual frenectomy. J Craniofac Surg. Nov. 2012;23(6):e657-8. [pmid: 23172517].
60 Opara PI, Gabriel-Job N, Opara KO. Neonates presenting with severe complications of frenotomy: a case series. J Med Case Rep. 2012;6(1):77. [pmid: 22394653].
61 Tuli A, Singh A. Monopolar diathermy used for correction of ankyloglossia. J Indian Soc Pedod Prev Dent. Apr-Jun. 2010;28(2):130-3. [pmid: 20660983].
62 Lin HW, O'Neill A, Rahbar R, et al. Ludwig's angina following frenuloplasty in an adolescent. Int J Pediatr Otorhinolaryngol. Sep. 2009;73(9):1313-5. [pmid: 19560216].
63 Chu MW, Bloom DC. Posterior ankyloglossia: a case report. Int J Pediatr Otorhinolaryngol. Jun. 2009;73(6):881-3. [pmid: 19303646].
64 Cunha RF, Silva JZ, Faria MD. Clinical approach of ankyloglossia in babies: report of two cases. J Clin Pediatr Dent. Summer. 2008;32(4):277-81. [pmid: 18767457].
65 Nicholson WL. Tongue-tie (ankyloglossia) associated with breastfeeding problems. J Hum Lact. Jun. 1991;7(2):82-4. [pmid: 2036160].
66 Fleiss PM, Burger M, Ramkumar H, et al. Ankyloglossia: a cause of breastfeeding problems?. J Hum Lact. Sep. 1990;6(3):128-9. [pmid: 2400560].
67 Berg KL. Two cases of tongue-tie and breastfeeding. J Hum Lact. Sep. 1990;6(3):124-6. [pmid: 2400558].
68 Huggins K. Ankyloglossia--one lactation consultant's personal experience. J Hum Lact. Sep. 1990;6(3):123-4. [pmid: 2400557].
69 Mathewson R, Siegel MDM. Ankyloglossia: a review of the literature and a case report. J Dent Child. 1966;33:238-43.
70 Good ME. Breastfeeding and the short frenulum. J Human Lact. 1987;3:154-56.
71 Isaiah A, Pereira KD. Infected sublingual hematoma: a rare complication of frenulectomy. Ear Nose Throat J. Jul. 2013;92(7):296-7. [pmid: 23904303].
72 Reddy NR, Marudhappan Y, Devi R, et al. Clipping the (tongue) tie. J Indian Soc Periodontol. May. 2014;18(3):395-8. [pmid: 25024558].
73 Corylllos E, Genna CW, S A. Congenital tongue-tie and its impact on breastfeeding. American Academy of Pediatrics Section on Breastfeeding Newsletter 2004. Summer. 2004:1-6.
74 Articulation and Naming Test. The International Perspective on Speech Articulation. American Speech-Lanaguage-hearing Association Convention. November 2005. San Diego, CA.
75 Tylor DA. The Effect of Frenotomy in Ankyloglossia on Feeding and Speech in Children [Dissertation]. University of Liverpool. June. 2013.
76 Segal LM, Stephenson R, Dawes M, et al. Prevalence, diagnosis, and treatment of ankyloglossia: methodologic review. Can Fam Physician. Jun. 2007;53(6):1027-33. [pmid: 17872781].
77 Ito Y. Does Frenotomy Improve Breastfeeding Difficulties in Infants with Ankyloglossia?. Pediatr Int. 2014. Jun. 30. [pmid: 24978831].