# Introduction

## Background

### Ankyloglossia

Ankyloglossia is a congenital condition in which a neonate is born with an abnormally short, thickened, or tight lingual frenulum that restricts mobility of the tongue. Ankyloglossia may be associated with other craniofacial abnormalities, but is also often an isolated anomaly.1 It variably causes reduced anterior tongue mobility and has been associated with functional limitations in breastfeeding, swallowing, articulation, orthodontic problems including malocclusion, open bite, and separation of lower incisors, mechanical problems related to oral clearance, and psychological stress. Reported rates of ankyloglossia in one review including studies of infants, children, and adults ranged from 0.1 to 10.7 percent,2 but definitive incidence and prevalence statistics are difficult to obtain because there criterion standard or clinically practical diagnostic criteria.

Anterior ankyloglossia is defined as tongue-tie with a prominent lingual frenulum and/or restricted tongue protrusion with tongue tip tethering. The diagnosis of posterior ankyloglossia is considered when the lingual frenulum is not very prominent on inspection but is thought to be tight on manual palpation or is found to be abnormally prominent, short, thick, or fibrous cord-like with the use of the grooved director. Although treatment is similar in anterior and posterior cases, posterior ankyloglossia is more subtle in presentation. Usually, clinicians recognize the anterior frenulum as the cause of ankyloglossia; however, an infant can have ankyloglossia even without obvious abnormalities of the anterior frenulum. Anterior ankyloglossia has been found more commonly in males and posterior ankyloglossia in females.3 Posterior ankyloglossia is more likely to require revision surgery due to the relative difficulty of accurate diagnosis and treatment.

Estimates in the literature of the number of infants with ankyloglossia who have feeding difficulties are based on small case series without control groups. Mechanistically, infants with restrictive ankyloglossia cannot protrude their tongues over the gum line to contact their lips to form a proper latch and therefore use their jaws to keep the maternal nipple in the mouth for breastfeeding. Adequate tongue mobility is required, and infants with ankyloglossia often cannot overcome their deficiency with conservative measures such as positioning and latching techniques.2 Ineffective latch associated with ankyloglossia is hypothesized to underlie breastfeeding problems in these infants including failure to thrive, maternal nipple damage, maternal breast pain, poor milk supply, maternal breast engorgement, and refusing the breast.2

Consensus on ankyloglossia's role in breastfeeding difficulties is lacking. A minority of surveyed pediatricians (10%) and otolaryngologists (30%) believe it commonly affects feeding, while 69 percent of lactation consultants feel that it frequently causes breastfeeding problems.4 Therefore, depending on the audience, enthusiasm for its treatment varies. Currently, the U.K. National Health Service (NHS) and the Canadian Paediatric Society (CPS) recommend treatment only if it interferes with breastfeeding.5 Unfortunately, a standard definition of “interference” with breastfeeding is not provided, leaving room for interpretation and variation in treatment thresholds. The absence of data on the natural history of untreated ankyloglossia creates even more uncertainty. Some propose that a short frenulum elongates spontaneously due to progressive stretching and thinning of the frenulum with age and use.1 However, there are no prospective longitudinal data on the fate of the congenitally short lingual frenulum. Without this information it is difficult to inform parents fully about the long-term implications of ankyloglossia, which complicates the decision making process.

Although most ankyloglossia research is focused on the infant and breastfeeding issues, concerns beyond infancy include speech-related issues, such as difficulty with articulation, and social concerns related to limited tongue mobility. Individuals with untreated ankyloglossia may experience difficulty with licking foods such as ice cream, kissing, drooling, playing wind instruments, and licking the lips. Self- esteem or psychological issues may also be a concern for affected older patients.

### Treatment Strategies

#### Surgical Approaches

Surgical modalities include frenotomy, frenulectomy, and tongue tie release surgery. These interventions are often used interchangeably in the literature. In general, a lingual frenotomy involve clipping or cutting of the lingual frenulum using the proceduralist's fingers, a grooved tongue director, or other instrument to lift the tongue, which puts the tension on the frenulum and using straight scissors to divide the frenulum, generally without sedation. The ensuing wound does not typically require repair. Laser frenotomy or frenulotomy has also been described,6 and proponents argue that its use is more exact and provides better hemostasis than standard frenotomy or frenulotomy.

Frenuloplasty is more technically involved than frenotomy or frenulotomy. It generally refers to rearranging tissue or adding grafts after making incisions and closing the resultant wound in a specific pattern to lengthen the anterior tongue. Specific types of frenuloplasty include Z-frenuloplasty, which involves making a longitudinal incision along the length of the lingual frenulum combined with perpendicular incisions at tongue tip and floor of the mouth. These cuts create a Z-type incision. Submucosal flaps are then elevated, and transposed flaps are sutured closed, resulting in increased tongue length and mobility. A second type of frenuloplasty involves a horizontal division at the base of the frenulum where a harvested buccal mucosal graft is inserted and affixed to fill the defect created by the incision. Horizontal-to-vertical frenuloplasty is a third type in which a horizontal incision is created at mid-frenulum to release the tethering fibrotic band. The incision is then converted to a vertical orientation and closed with sutures to effectively elongate the anterior tongue. Frenuloplasty is most commonly performed under a general anesthetic and used in older infants and children or in more complex frenulum repairs.

#### Nonsurgical Approaches

Nonsurgical approaches include speech therapy and lactation interventions and observation to determine if intervention is warranted (Table 1).

Table 1 Nonsurgical treatment approaches

Intervention | Description
Complementary and alternative procedures | Diverse group of therapies not conventionally practiced by physicians or allied health professionals (e.g., craniosacral therapy).
Lactation intervention | Counseling and recommendations from a lactation consultant for better, easier or more efficient breast-feeding. Focus on latching technique and infant and maternal positioning on breast.
Physical therapy/occupational therapy | Approaches to reduce tension in and stretch neck, back, and strap muscles to improve range of motion. This includes myofascial release and other manual techniques.
Speech therapy/oromotor therapy | Exercises and techniques intended to develop awareness, strength, coordination and mobility of the oral muscles including the tongue, lip, and palate. Evaluation and treatment of swallowing and speech disorders using specific exercises and procedures.
Observation | Supportive therapy for mother without any treatment approach and observation for improvement through natural history of the condition process.

Several measures have been developed to assess or describe ankyloglossia. Structured assessments can also be used to assess the effectiveness of breastfeeding. Table 2 outlines measures used in the studies reported in this review.

Table 2 Structured assessments and screening tools used in ankyloglossia literature

Measure | Description
Degree of Ankyloglossia
Coryllos criteria | Scale for categorizing ankyloglossia based on proximity of frenulum attachment to tongue tip: Type 1=frenulum attached to tip of tongue. Type 2=frenulum attached 2-4 millimeters behind tongue tip on or behind alveolar ridge. Type 3=mid-tongue attachment. Type 4=attachment at base of tongue. Type 4 is associated with more difficulty with bolus swallowing and more significant symptoms.
Hazelbaker Assessment Tool for Lingual Frenulum Function (HATLFF) | Measure of ankyloglossia extent and severity that include items to assess the appearance and function of the tongue and frenulum. Lower scores indicate more severe ankyloglossia. HATLFF is scored: 0-14 with14=perfect; 11=acceptable if appearance item score is 10; <11=impaired function (frenotomy should be considered if management fails; frenotomy is necessary if appearance item score is <8). HATLFF score of 6-12=mild to moderate tongue-tie; <6=severe tongue-tie.7, 8
Breastfeeding Effectiveness
Breastfeeding Self-Efficacy Scale (BSES) | Measure of maternal breastfeeding confidence that uses a 5-point (1=not at all confident to 5=always confident) Likert scale to assess agreement with statements such as “I can always position my baby correctly at my breast.” BSES scores range from 33-165 on the 33-item instrument 9 and 14-70 on the 14-item BSES-Short Form.10 Higher overall scores indicate higher levels of breastfeeding self-efficacy.
Infant Breastfeeding Assessment Tool (IBFAT) | Measure of clinician or maternally rated perception of 4 items related to effectiveness of and satisfaction with a feeding (readiness to feed, rooting, latching on, sucking) rated on a 3-point scale (e.g., 3=rooted effectively at once, 0=did not root). Higher scores indicate greater perceived effectiveness. IBFAT scores range from 0-12; 12=vigorous and effective feeding.11
Latch, Audible swallowing, Type of nipple, Comfort, Hold (LATCH) | Measure of effectiveness of latch to the breast, feeding, comfort for mother, and maternal positioning rated on 3 levels with higher scores indicating greater effectiveness. LATCH score ≤8=breastfeeding difficulties.12

## Scope and Key Questions

### Scope of Review

This systematic review provides a comprehensive review of potential benefits of treatments (surgical and nonsurgical) as well as harms associated with those therapies in individuals with ankyloglossia and tight labial frenulum (lip-tie) concomitant with ankyloglossia. We assess outcomes related to breast and bottle-feeding and related to tongue tie in later life (e.g., orthodontic and dental issues, speech, self-esteem).

### Key Questions

We have synthesized evidence in the published literature to address the following Key Questions (KQs):

KQ1. What are the benefits of various treatments in breastfeeding newborns and infants with ankyloglossia intended to improve breastfeeding outcomes? Surgical treatments include frenotomy (anterior and/or posterior), frenuloplasty (transverse to vertical frenuloplasty), laser frenulectomy/frenulotomy, and Z-plasty repair. Nonsurgical treatments include complementary and alternative medicine therapies (e.g. craniosacral therapy), lactation intervention, physical/occupational therapy, oral motor therapy, and stretching exercises/therapy.

KQ2a. What are the benefits of various treatments in newborns, infants, and children with ankyloglossia intended to prevent, mitigate, or remedy attributable medium and long-term feeding sequelae including trouble bottle feeding, spilling and dribbling, difficulty moving food boluses in the mouth and deglutition?

KQ2b. What are the benefits of various treatments in infants and children with ankyloglossia intended to prevent, mitigate, or remedy attributable medium and long term other sequelae including articulation disorders, poor oral hygiene, oral and oropharyngeal dysphagia, sleep disordered breathing, orthodontic issues including malocclusion, open bite due to reverse swallowing, lingual tipping of the lower central incisors, separation of upper central incisors, crowding, narrow palatal arch, and dental caries?

KQ3. What are the benefits of various treatments for ankyloglossia in children through 18 years of age intended to prevent or address social concerns related to tongue mobility (i.e., speech, oral hygiene, excessive salivation, kissing, spitting while talking, and self-esteem)?

KQ4. What are the benefits of simultaneously treating ankyloglossia and concomitant tight labial frenulum (lip-tie) in infants and children through age 18 intended to improve or remedy breastfeeding, articulation, orthodontic and dental, and other feeding outcomes? What are the relative benefits of treating only ankyloglossia when tight labial frenulum (lip-tie) is also diagnosed?

KQ5. What are the harms of treatments for ankyloglossia or ankyloglossia with concomitant lip-tie in neonates, infants, and children through age 18?

Table 3 outlines the population, intervention, comparator, outcomes, timing, and setting characteristics for each KQ.

Table 3 PICOTS

PICOTS | Criteria
Population | - KQ1: Breastfeeding newborns with ankyloglossia; - KQ2 and KQ3: Infants and children with ankyloglossia; - KQ4: Infants and children (newborns through18 years of age) with ankyloglossia and concomitant tight labial frenulum (lip-tie); - KQ5: Children through age 18 treated for ankyloglossia or ankyloglossia and concomitant lip-tie.
Intervention(s) | - Surgical interventions, including frenotomy (anterior or posterior), frenuloplasty, laser frenulectomy and Z-plasty repair; - Nonsurgical treatments include complementary and alternative medicine (CAM) therapies (e.g., craniosacral therapy), lactation intervention, and speech therapy (for children ages 2 to 18 years), physical/occupational therapy, oral motor therapy, and stretching exercises/therapy
Comparator | - Other surgical approach; - Non-surgical interventions including lactation intervention, speech therapy, physical/occupational therapy oral motor therapy, and stretching exercises/therapy; - Observation; - Complementary and alternative medicine (CAM) therapies (e.g. craniosacral therapy); - Placebo (sham therapy)
Outcomes | - Breastfeeding, including latch, nipple pain, nipple excoriations, nipple infections (mastitis), weight gain, aerophagia, swallowing function, failure to thrive, milk transfer, low milk supply, breastfeeding cessation/duration of breastfeeding; - Other feeding issues, including difficulty bottle feeding, moving food boluses in the mouth, deglutition, spilling and dribbling, reflux, dysphagia; - Articulation; - Speech (e.g., speech fluency, effort with speech, speech intelligibility); - Sleep disordered breathing (sleep apnea); - Oral hygiene; - Excessive salivation; - Orthodontic problems, including malocclusion, open bite due to reverse swallowing, lingual tipping of lower central incisors, separation of upper central incisors, crowding, and narrow palatal arch, dental caries; - Psychological (e.g., self-esteem); - Harms, including excessive bleeding, airway obstruction, pain, transient poor feeding secondary to discomfort, dysphagia, complications related to dysphagia such as aspiration pneumonia, surgical site infection, nerve damage, salivary gland damage, ranulae, scarring, soft tissue damage, oral aversion, readherence, and need for further surgery/revision
Timing | - Short-term (breastfeeding); - Long-term (feeding) speech, psychological, oral hygiene
Setting | - Inpatient or outpatient pediatric care, operating room, newborn nursery or NICU, ENT clinic, primary care outpatient, dental office, breastfeeding medicine clinic

CAM = Complementary and alternative medicine; ENT = ear, nose and throat; KQ = Key Question; NICU = neonatal intensive care unit; PICOTS = population, intervention, comparator, outcomes, timing, setting

### Analytic Framework

Figure 1 depicts KQs 1, 4, and 5 within the context of the PICOTS (Population, Intervention, Comparator, Outcomes, Timing, Setting) described in the document. The figure examines surgical and nonsurgical treatments in newborns and infants to improve breastfeeding outcomes. Intermediate outcomes include maternal nipple pain, ability to latch and maintain latch, tongue mobility, and aerophagia. Final outcomes include duration of breastfeeding, failure to thrive, infant weight gain and oral and oropharyngeal dysphagia. Harms (KQ5) may occur at any point after the intervention is received.

Figure 1 Analytic framework for ankyloglossia in neonates and infants

This figure depicts Key Questions 1, 4 and 5 within the context of the PICOTS described in the document. The figure examines surgical and nonsurgical treatments in newborns and infants to improve breastfeeding outcomes. Intermediate outcomes include maternal nipple pain, ability to latch and maintain latch, tongue mobility, and aerophagia. Final outcomes include duration of breastfeeding, failure to thrive, infant weight gain and oral and oropharyngeal dysphagia. Harms (KQ5) may occur at any point after the intervention is received.

Figure 2 depicts KQs 2, 3, 4, and 5 within the context of the PICOTS described in the document. The figure examines surgical and nonsurgical treatments in infants and children with ankyloglossia (KQ2, KQ3) or ankyloglossia with concomitant tight labial frenulum (lip-tie) (KQ4). The intermediate outcome is tongue mobility and final health outcomes include articulation disorder, oral hygiene, oral and oropharyngeal dysphagia, orthodontic problems, psychological outcomes and social concerns including kissing. Harms (KQ5) may occur at any point after the intervention is received.

Figure 2 Analytic framework for ankyloglossia in infants and children through 18 years of age

This figure depicts Key Questions 2, 3, 4 and 5 within the context of the PICOTS described in the document. In general, the figure examines surgical and nonsurgical treatments in infants and children with ankyloglossia (KQ2, KQ3) or ankyloglossia with concomitant tight labial frenulum (lip-tie) (KQ4). The intermediate outcome is tongue mobility and final health outcomes include articulation disorder, oral hygiene, oral and oropharyngeal dysphagia, orthodontic problems, psychological outcomes and social concerns including kissing. Harms (KQ5) may occur at any point after the intervention is received.

## Organization of This Report

The Methods section describes our processes including our search strategy, inclusion and exclusion criteria, approach to review of abstracts and full publications, and methods for extraction of data into evidence tables, and compiling evidence. We also describe our approach to grading the quality of the literature and to describing the strength of the body of evidence.

The Results section presents the findings of the literature search and the review of the evidence by KQ, synthesizing the findings across strategies.

The Discussion section of the report discusses the results and expands on the methodologic considerations relevant to each KQ. We also outline the current state of the literature and challenges for future research in the field.

The report includes a number of appendices to provide further detail on our methods and the studies assessed. The appendixes are as follows:

- Appendix A. Search Strategies
- Appendix B. Abstract and Full-Text Screening Forms
- Appendix C. Excluded Studies
- Appendix D. Evidence Tables
- Appendix E. Quality Assessment Forms
- Appendix F. Quality Scoring Results
- Appendix G. Case Reports Harms
- Appendix H. Conference Abstracts
- Appendix I. Applicability Tables

We also include a list of abbreviations and acronyms at the end of the report.

## Uses of This Evidence Report

We anticipate this report will be of primary value to organizations that develop guidelines for clinical practitioners and to health care providers who take care of infants and children through 18 years of age with ankyloglossia. Interested organizations would include the American Academy of Pediatrics, the Pediatric Academic Societies (PAS), the Academy of Breastfeeding Medicine(ABM), the American Academy of Pediatric Dentistry (AAPD), the American Academy of Otolaryngology—Head and Neck Surgery (AAO-HNS), the American Speech-Language-Hearing Association (ASHA), the International Lactation Consultant Association (ILCA), Lactation Consultants of Australia and New Zealand (LCANZ), the College of Lactation Consultants of Western Australia (CLCWA), the American Orthodontic Society (AOS) and the American Association of Orthodontists (AAO), the NHS and other organizations and societies for pediatric care. Ankyloglossia is diagnosed and treated by an array of physicians and allied health professionals, but this most commonly includes pediatricians, otolaryngologists, dentists, and lactation consultants. This report supplies practitioners and researchers up-to-date information about the current state of evidence, and assesses the quality of studies that aim to determine the outcomes of treatments for ankyloglossia. It will be of interest to parents concerned about the health of their infants and facing treatment choices around care for their children with ankyloglossia.

Researchers can obtain a concise analysis of the current state of knowledge in this field. They will be poised to pursue further investigations that are needed to advance research methods, develop new treatment strategies, and optimize the effectiveness and safety of clinical care infants and children through 18 years of age with ankyloglossia.