# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Jeanne L. Ballard, M.D.
  Cincinnati College of Medicine
  Cincinnati, OH
- Lori Feldman-Winter, M.D., M.P.H.
  Cooper Medical School of Rowan University
  Camden, NJ
- Ann L. Kellams, M.D., IBCLC
  University of Virginia Health System
  Charlottesville, VA
- Diana Mayer, M.D., IBCLC, FAAP
  CentraState Medical Center
  Freehold, NJ
- Megan Overby, Ph.D., CCC-SLP
  Duquesne University
  Pittsburgh, PA
- Gautham K. Suresh, M.D.
  Dartmouth-Hitchcock Medical Center
  Lebanon, NH
- Dale Amanda Tylor, M.D., M.P.H.
  Washington Township Medical Foundation
  Fremont, CA
- Catherine Watson Genna, IBCLC, RLC
  Private Practice
  Woodhaven, NY
- Lynn S. Wolf, M.O.T., O.T.R., IBCLC
  Seattle Children's Hospital
  Seattle, WA