# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Jeanne L. Ballard, M.D.
  Cincinnati College of Medicine
  Cincinnati, OH
- Lori Feldman-Winter, M.D., M.P.H.
  Cooper Medical School of Rowan University
  Camden, NJ
- Donna Geddes, Ph.D.
  University of Western Australia
  Crawley, Western Australia, Australia
- Timothy Hickman, M.D., M.Ed, M.P.H.
  University of Missouri-Kansas City
  School of Medicine
  Kansas City, MO
- Gregory L. Lof, Ph.D., CCC-SLP, FASHA
  MGH Institute of Health Professions
  Boston, MA
- Diana Mayer, M.D., IBCLC, FAAP
  CentraState Medical Center
  Freehold, NJ
- Greg Notestine, D.D.S.
  Beavercreek, OH
- Richard Rosenfeld, M.D., M.P.H.
  SUNY Downstate Medical Center
  Brooklyn, NY
- Catherine Watson Genna, IBCLC, RLC
  Private Practice
  Woodhaven, NY