# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project. Annette Williams assisted with managing the report. Tanya Surawicz extracted data, created tables, and assisted with screening studies and quality assessment. Jessica Kimber and Sanura Latham provided invaluable assistance with retrieving studies, data entry, and table formatting.