# Conference Abstracts

We searched for abstracts/proceedings within PubMed, CINAHL, EMBASE, Web of Science, Science Direct and websites and journal publications of pediatric, dental, orthodontic and lactation societies and organizations from 1980 to the present. Organizations included the Academy of Breastfeeding Medicine (ABM), American Academy of Pediatric Dentistry (AAPD), American Academy of Otolaryngology – Head and Neck Surgery (AAO-HNS), American Association of Orthodontists (AAO), American Association of Pediatrics (AAP), American Orthodontic Society (AOS), American Speech-Language-Hearing Association (AHSA), College of Lactation Consultants of Western Australia (CLCWA), International Lactation Consultant Association (ILCA), Lactation Consultants of Australia and New Zealand (LCANZ), and Pediatric Academic Societies (PAS).

We identified over 20 abstracts, a number of which reported on incidence or prevalence rates or rates of surgical procedures or provided summaries of studies included in the full review. Abstracts that address outcomes related to breastfeeding, feeding, and speech or social concerns are outlined in H-1.

Table H-1 Relevant conference abstracts

Abstract | Key outcomes
4^th^ Congress of the European Academy of Paediatric Societies, Istanbul, Turkey, 2012.
Post E. et al. “Snipping of a tongue-tie in neonates” with ankyloglossia and breastfeeding problems: Outcomes and complications. | - 117/132 (89%) mothers whose infant (<3 months of age) underwent frenotomy reported breastfeeding improvements (latch and decreased nipple pain). Specific assessment tools are not reported.; - 12/132 (9%) mothers reported no improvement; - Minor brief bleeding post intervention and pain were reported in five patients .
Matthews E. et al. An audit of impacts of frenulectomy in breast feeding. | - Results of a questionnaire administered to mothers approximately three weeks after infant (mean age of 6.6 weeks) underwent frenulectomy. Mothers reported decreased latch difficulties (reduction from 16/26 (62%) to 2/26 (8%)) and nipple/breast pain (from 13/26 (50%) to 5/26(19%)). Breastfeeding exclusively increased to 61% (16/26) from pre-intervention 46% (12/26).
4^th^ British Academic Conference in Otolaryngology, Glasgow, UK, 2012
Dhillon B. Audit of division of tongue ties in a single consultant's clinic. | - 77% of mothers (90/118) reported improved breast feeding immediately following infant tongue tie division.
10^th^ World Conference of Perinatal Medicine. Punta del Este, Uruguay, 2011.
Alvarez V. et al. Breastfeeding and tongue tie. | - 69/75 infants referred for frenotomy due to breastfeeding difficulties underwent procedure.; - Mothers reported immediate improved breastfeeding. No associated complications occurred.
Annual Scientific Meeting of the British Association of Oral and Maxillofacial Surgeons (BAOMS) 2011 Nice France.
Cottom H. Division of ankyloglossia-Its effectiveness in improving associated breastfeeding difficulties. | - All 40 mothers whose infants were referred for frenulotomy reported improvement in breastfeeding evaluated on a scale of zero (impossible) to 10 (no feeding problems) and 40% reported total resolution.
2009 International Lactation Consultant Association (ILCA) Conference
Felc Z. Ankyloglossia: incidence and effect of neonatal frenotomy on breastfeeding. | - 60/3383 consecutively screened infants experienced breastfeeding problems due to ankyloglossia. Thirty-five of the sixty infants (58%) underwent frenotomy. In 24/35 (68.6%) of the infants, latch, milk transfer, nipple pain improved. No complications occurred.