# Case Reports Harms

Table G-1 Harms of frenectomy described in case reports

Study and Country | Age | Bleeding | Pain | Surgical Site Infection | Swelling /edema | Need for further surgery | Ranulae | Other/comments
Santos et al. 2012^1^ Brazil | 12 years | | | | | ✓ | ✓ | Mucocele post-surgery
Cunha et al. 2008^2^ Brazil | 3 months | ✓
Fleiss et al.1990^3^ U.S. | 13 years | | | | | | | Lisp post-surgery
Tuli et al. 2010^4^ India | 5 years | | | | | ✓
Reddy et al. 2014^5^ India | NR | | ✓ | | ✓

Table G-2 Harms of frenotomy described in case reports

Study and Country | Age | Bleeding | Pain | Surgical Site Infection | Swelling /edema | Need for further surgery | Ranulae | Other/comments
Opara et al. 2012^6^ Nigeria (case 1) | 1 day | ✓ | | | | | | Continued bleeding for one day post intervention; sepsis
Opara et al. 2012^6^ Nigeria (case 2) | 3 days | ✓ | | | | | | Continued bleeding for three days post-intervention
Mathewson et al. 1966^7^ U.S. | 16 years | | | | | | | Scar band formed post-surgery

Table G-3 Harms of frenulectomy described in case reports

Study and Country | Age | Bleeding | Pain | Surgical Site Infection | Swelling /edema | Need for further surgery | Ranulae | Other/comments
Isaiah et al. 2013^8^ U.S. | 2 years | | | ✓ | ✓ | | | Fever and drooling
Nicholson 1991^9^ Australia | 44 hours | | | | | | | Slight bruising under tongue for three to four days.

Table G-4 Harms of frenuloplasty described in case reports

Study and Country | Age | Bleeding | Pain | Surgical Site Infection | Swelling /edema | Need for further surgery | Ranulae
Sirinoglu et al. 2013^10^ Turkey | 3 years | | | | ✓
Chu et al. 2009^11^ U.S. | 4 weeks | ✓
Lin et al. 2009^12^ U.S. | 13 years | | ✓ | ✓ | ✓

Table G-5 Harms of frenulotomy described in case reports

Study and Country | Age | Bleeding | Pain | Surgical Site Infection | Swelling /edema | Need for further surgery | Ranulae
Berg. 1990^13^ U.S. | 12.5 weeks | ✓
Huggins. 1990^14^ U.S. | 2 weeks | ✓
Good. 1987^15^ U.S. | 7 months | ✓

## References

1 Santos Tde S, Filho PR, Piva MR, et al. Mucocele of the glands of Blandin-Nuhn after lingual frenectomy. J Craniofac Surg. Nov. 2012;23(6):e657-8. [pmid: 23172517].
2 Cunha RF, Silva JZ, Faria MD. Clinical approach of ankyloglossia in babies: report of two cases. J Clin Pediatr Dent. Summer. 2008;32(4):277-81. [pmid: 18767457].
3 Fleiss PM, Burger M, Ramkumar H, et al. Ankyloglossia: a cause of breastfeeding problems?. J Hum Lact. Sep. 1990;6(3):128-9. [pmid: 2400560].
4 Tuli A, Singh A. Monopolar diathermy used for correction of ankyloglossia. J Indian Soc Pedod Prev Dent. Apr-Jun. 2010;28(2):130-3. [pmid: 20660983].
5 Reddy NR, Marudhappan Y, Devi R, et al. Clipping the (tongue) tie. J Indian Soc Periodontol. May. 2014;18(3):395-8. [pmid: 25024558].
6 Opara PI, Gabriel-Job N, Opara KO. Neonates presenting with severe complications of frenotomy: a case series. J Med Case Rep. 2012;6(1):77. [pmid: 22394653].
7 Mathewson R, Siegel M, D M. M. Ankyloglossia: a review of the literature and a case report. J Dent Child. 1966;33:238-43.
8 Isaiah A, Pereira KD. Infected sublingual hematoma: a rare complication of frenulectomy. Ear Nose Throat J. Jul. 2013;92(7):296-7. [pmid: 23904303].
9 Nicholson WL. Tongue-tie (ankyloglossia) associated with breastfeeding problems. J Hum Lact. Jun. 1991;7(2):82-4. [pmid: 2036160].
10 Sirinoglu H, Certel F, Akgun I. Subacute massive edema of the submandibular region after frenuloplasty. J Craniofac Surg. Jan. 2013;24(1):e74. [pmid: 23348346].
11 Chu MW, Bloom DC. Posterior ankyloglossia: a case report. Int J Pediatr Otorhinolaryngol. Jun. 2009;73(6):881-3. [pmid: 19303646].
12 Lin HW, O'Neill A, Rahbar R, et al. Ludwig's angina following frenuloplasty in an adolescent. Int J Pediatr Otorhinolaryngol. Sep. 2009;73(9):1313-5. [pmid: 19560216].
13 Berg KL. Two cases of tongue-tie and breastfeeding. J Hum Lact. Sep. 1990;6(3):124-6. [pmid: 2400558].
14 Huggins K. Ankyloglossia--one lactation consultant's personal experience. J Hum Lact. Sep. 1990;6(3):123-4. [pmid: 2400557].
15 Good ME. Breastfeeding and the short frenulum. J Human Lact. 1987;3:154-56.