# Quality Scoring Results

Table F-1 RCT quality score results

Author, Year | Sequence Generation | Allocation Concealment | Selective Reporting | Other Bias | Blinding of Participants/Personnel | Blinding of Outcome Assessment | Incomplete Outcome Data | Risk of Bias Rating for Outcome
Studies assessing HATLFF^*^
Emond et al. 2013^1^ | Low | Low | Low | Low | Low | Low | Low | Good
Buryk et al. 2011^2^ | Low | Low | Low | Low | Low | Low | Low | Good
Studies assessing LATCH^†^
Emond et al. 2013^1^ | Low | Low | Low | Low | Low | Low | Low | Good
Berry et al. 2012^3^ | Low | Low | Low | Low | Low | Low | Low | Good
Dollberg et al. 2006^4^ | Low | Low | High | Unclear | High | Low | Low | Poor
Studies assessing IBFAT^††^
Emond et al. 2013^1^ | Low | Low | Low | Low | Low | Low | Low | Good
Berry et al. 2012^3^ | Low | Low | Low | Low | Low | Low | Low | Good
Buryk et al. 2011^2^ | Low | Low | Low | Low | Low | Low | Low | Good
Studies assessing BSES^§^
Emond et al. 2013^1^ | Low | Low | Low | Low | High | Low | Low | Fair
Studies assessing pain scores
Emond et al. 2013^1^ | Low | Low | Low | Low | Low | Low | Low | Good
Berry et al. 2012^3^ | Low | Low | Low | Low | Low | Low | Low | Good
Buryk et al. 2011^2^ | Low | Low | Low | Low | Low | Low | Low | Good
Dollberg et al. 2006^4^ | Low | Low | High | Unclear | High | Low | Low | Poor
Studies assessing infant weight gain
Emond et al. 2013^1^ | Low | Low | Low | Low | Unclear | Low | Low | Fair
Studies assessing frenulum length
Heller et al. 2005^5^ | Unclear | Unclear | Low | Unclear | Low | Unclear | Low | Poor
Studies assessing tongue protrusion
Heller et al. 2005^5^ | Unclear | Unclear | Low | Unclear | Low | Unclear | Low | Poor
Studies assessing speech
Heller et al. 2005^5^ | Unclear | Unclear | Low | Unclear | Unclear | Unclear | Low | Poor
Studies assessing feeding (breast and bottle) measured by observers
Hogan et al. 2005^6^ | Unclear | Low | Low | Low | High | Low | Low | Fair

* HATLFF=Hazelbaker Assessment Tool for Lingual Frenulum Function

± LATCH=Latch, Audible swallowing, Type of Nipple, Comfort, Hold

†† IBFAT=Infant Breastfeeding Assessment Tool

§ BSES= Breastfeeding Self-Efficacy Scale

Table F-2 Cohort quality score results

Author, Year | Inclusion/exclusion criteria across groups | Recruitment strategy across groups | Selection of the comparison group | Outcome assessor blinding | Valid & reliable measures across study participants | Length of followup different across groups | Assessment of impact of high loss to followup | Balancing allocation between groups/matching groups | Accounting for confounding factors | Adequacy of statistical methods to assess primary outcomes | Adequacy of statistical methods to assess harms or adverse events | Rating
Walls et al. 2014^7^ | - | + | + | - | - | + | NA | - | - | + | + | Poor
Steehler et al. 2012^8^ | + | + | + | - | - | - | - | - | - | + | + | Poor
Dollberg et al. 2011^9^ | - | + | + | - | - | + | NA | + | - | - | - | Poor

NA=not applicable

Table F-3 Case series quality score results

Author, Year | Confounding and modifying variables accounted | Concurrent intervention/unintended exposure ruled out | Study free from variations from protocol | Low rate (≤20%) attrition | Attrition did not result in difference in groups baseline & followup | Outcome assessors blinded | Clearly stated inclusion/exclusion criteria | Measures implemented consistently | Appropriate measures for assessing interventions/exposures | Interventions implemented consistently | Outcome: Latch | Appropriate measures for outcome assessment | Outcome: Nipple Pain | Appropriate measures for outcome assessment | Outcome: breastfeeding | Appropriate measures for outcome assessment | Outcome: feeding outcomes | Appropriate measures for outcome assessment | Outcome: infant growth | Appropriate measures for outcome assessment | Outcome: speech | Appropriate measures for outcome assessment | Outcome: Tongue mobility, protrusion | Appropriate measure for outcome assessment | Outcome: Oral hygiene | Appropriate measure for outcome assessment | Outcome: reoperation | Appropriate measure for outcome assessment | Outcome: Beneficial | Appropriate measure for outcome assessment | Consistent implementation of outcome assessment | Appropriate measures for confounding variables assessment | Consistent assessment of confounding variables | Secular trends and regression to the mean accounted for | Pre-specified potential outcomes | Pre-specified harms | Reporting of all pre-specified outcomes | Reporting of all pre-specified harms
Dollberg et al. 2014^10^ | - | NA | + | + | NA | - | + | + | + | + | | | | | + | + | | | | | | | | | | | | | | | + | NR | NR | - | + | + | + | +
Finigan et al. 2014^11^ | - | - | NR | - | NR | - | - | NR | + | NR | | | | | | | + | + | | | | | | | | | | | | | + | - | NA | NA | + | - | + | NA
Ito et al. 2014^12^ | - | + | NR | + | NA | - | + | + | + | - | | | | | | | | | | | + | + | | | | | | | | | + | - | NA | NA | + | - | + | NA
Riskin et al. 2014^13^ | - | - | NR | - | NR | NA | + | + | + | NA | + | + | + | + | + | + | | | + | + | | | | | | | | | | | + | - | - | - | + | | +
Rose et al. 2014^14^ | - | - | NR | - | NR | - | + | + | + | NR | | | | | | | + | + | | | | | | | | | | | + | + | + | - | NA | NA | + | - | + | NA
Toner et al. 2014^15^ | - | - | NR | - | NR | - | - | NR | + | NR | | | | | | | | | | | | | | | | | | | + | + | + | - | NA | NA | + | - | + | NA
Dave et al. 2013^16^ | - | - | NR | + | NA | NR | - | NR | NR | + | | | | | | | | | | | - | NR | | | | | | | | | NR | - | NA | NA | - | - | NA | NA
Edmunds et al. 2013^17,*^ | - | - | + | + | NA | - | - | + | - | NA | | | | | | | | | | | | | | | | | | | | | NR | - | - | NA | - | - | + | +
O'Callahan et al. 2013^18^ | - | - | + | - | - | - | + | + | + | + | | | | | + | + | | | | | | | | | | | | | | | + | - | - | NA | + | - | + | NR
Mettias et al. 2013^19^ | - | - | - | - | NR | - | - | + | + | + | | | | | + | + | | | | | | | | | | | | | | | + | - | - | - | + | + | + | +
Sethi et al. 2013^20^ | - | - | + | - | NR | - | - | + | + | + | | | | | - | + | | | | | | | | | | | | | | | - | NA | NA | - | + | - | + | NA
Marchesan et al. 2012^21^ | - | - | + | + | NA | - | + | + | + | + | | | | | | | | | | | | | - | - | | | | | | | NR | - | - | NA | - | - | NA | NA
Argiris et al. 2011^22^ | - | NR | + | NA | NA | - | + | + | + | + | + | + | + | + | + | + | | | | | | | | | | | | | | | + | NR | NA | NA | + | - | + | NA
Cho et al. 2011^23^ | - | - | - | + | NA | - | - | + | - | + | | | | | | | | | | | - | - | | | | | | | | | NR | - | - | - | - | - | NA | NA
Puthussery et al. 2011^24^ | - | - | + | + | NA | - | - | + | + | + | | | | | | | | | | | + | + | + | + | | | | | | | + | - | - | NA | + | + | + | +
Hong et al. 2010^25^ | - | - | + | + | NA | - | + | + | + | + | | | | | - | NR | | | | | | | | | | | + | + | | | + | NA | - | - | + | -+- | + | NA
Miranda et al. 2010^26^ | - | + | + | + | NR | - | + | + | + | + | - | NA | - | NA | - | NA | | | | | | | | | | | | | | | + | NA | NA | NA | + | - | + | NA
Khoo et al. 2009^27^ | - | - | NA | NA | NA | - | - | + | + | + | | | | | + | + | | | | | | | | | | | | | | | + | NR | NR | NA | + | - | + | NA
Klockars et al. 2009^28^ | - | - | + | - | NR | - | + | + | + | NR | | | | | | | | | | | | | | | | | + | + | - | - | + | - | - | - | + | - | + | NA
Ridgers et al. 2009^29^ | - | - | + | + | NA | - | - | + | + | + | | | | | | | + | + | | | | | | | | | | | | | - | - | NA | - | - | - | NA | NA
Geddes et al. 2008^30^ | NR | NR | + | + | NA | - | + | + | + | + | + | + | + | + | + | + | | | | | | | | | | | | | | | + | NA | NA | NA | + | - | + | NA
Yeh. 2008^31^ | - | - | NR | + | NA | - | - | + | NR | + | | | | | | | | | | | | | | | | | + | + | | | + | - | - | - | - | - | NA | NA
Srinivasan et al. 2006^32^ | - | + | + | + | NA | - | + | + | + | + | + | + | + | + | + | + | | | | | | | | | | | | | | | + | NA | NA | - | + | - | + | -
Blenkinsop. 2003^33^ | - | NR | + | + | NA | - | - | + | + | + | | | | | - | - | | | | | | | | | | | | | | | + | - | - | - | + | - | + | NA
Wallace et al. 2006^34^ | - | - | - | + | NA | - | - | + | + | + | | | | | + | + | | | | | | | | | | | | | | | + | - | NR | NA | + | - | + | NA
Amir et al. 2005^35^ | - | - | - | - | NR | - | + | + | + | + | | | | | + | + | | | | | | | | | | | | | | | + | - | - | - | + | - | + | NA
Heller et al. 2005^5^ | - | - | - | + | NA | - | - | NR | NR | + | | | | | | | | | | | - | - | | | | | | | | | + | NR | NA | - | - | - | NA | NA
Griffiths. 2004^36^ | - | + | + | + | + | - | + | + | + | + | | | | | + | + | | | | | | | + | + | | | | | | | + | + | + | - | + | - | + | NA
Lalakea et al. 2003^37^ | - | + | + | + | NA | - | + | + | + | | | | | | | | | | | | | | + | + | | | | | | | + | NR | NA | - | + | - | + | NA
Ballard et al. 2002^38^ | - | - | + | + | NA | - | - | - | + | + | + | + | + | + | + | + | | | | | + | + | | | | | | | | | + | NR | - | - | + | - | + | NA
Messner et al. 2002^39^ | - | - | + | + | NA | - | + | + | + | + | | | | | | | | | | | + | + | + | + | | | | | | | + | + | NA | NR | + | + | + | NA
Masaitis et al. 1996^40^ | - | NA | + | + | NR | NA | - | + | + | + | | | | | + | + | | | - | + | | | + | + | | | | | | | + | NA | NA | - | + | - | + | NA
Godley. 1994^41^ | - | + | NR | + | NA | - | - | NR | + | + | | | | | | | | | | | | | - | - | | | | | | | NR | - | NA | - | - | - | NA | Na

* No discrete outcomes measured;

NA=Not applicable; NR=Not reported

## References

1 Emond A, Ingram J, Johnson D, et al. Randomised controlled trial of early frenotomy in breastfed infants with mild-moderate tongue-tie. Arch Dis Child Fetal Neonatal Ed. Nov. 18. 2013;99(3):F189-95. [pmid: 24249695].
2 Buryk M, Bloom D, Shope T. Efficacy of neonatal release of ankyloglossia: a randomized trial. Pediatrics. Aug. 2011;128(2):280-8. [pmid: 21768318].
3 Berry J, Griffiths M, Westcott C. A double-blind, randomized, controlled trial of tongue-tie division and its immediate effect on breastfeeding. Breastfeed Med. Jun. 2012;7(3):189-93. [pmid: 21999476].
4 Dollberg S, Botzer E, Grunis E, et al. Immediate nipple pain relief after frenotomy in breast-fed infants with ankyloglossia: a randomized, prospective study. J Pediatr Surg. Sep. 2006;41(9):1598-600. [pmid: 16952598].
5 Heller J, Gabbay J, O'Hara C, et al. Improved ankyloglossia correction with four-flap Z-frenuloplasty. Ann Plast Surg. Jun. 2005;54(6):623-8. [pmid: 15900148].
6 Hogan M, Westcott C, Griffiths M. Randomized, controlled trial of division of tongue-tie in infants with feeding problems. J Paediatr Child Health. May-Jun. 2005;41(5-6):246-50. [pmid: 15953322].
7 Walls A, Pierce M, Wang H, et al. Parental perception of speech and tongue mobility in three-year olds after neonatal frenotomy. Int J Pediatr Otorhinolaryngol. Jan. 2014;78(1):128-31. [pmid: 24315215].
8 Steehler MW, Steehler MK, Harley EH. A retrospective review of frenotomy in neonates and infants with feeding difficulties. Int J Pediatr Otorhinolaryngol. Sep. 2012;76(9):1236-40. [pmid: 22704670].
9 Dollberg S, Manor Y, Makai E, et al. Evaluation of speech intelligibility in children with tongue-tie. Acta Paediatr. Sep. 2011;100(9):e125-7. [pmid: 21401716].
10 Dollberg S, Marom R, Botzer E. Lingual frenotomy for breastfeeding difficulties: a prospective follow-up study. Breastfeed Med. Jun. 2014;3:286-9. [pmid: 24892968].
11 Finigan V. Overcoming tongue-tie. Midwives. 2014;17(3):48-9. [pmid: 24960964].
12 Ito Y, Shimizu T, Nakamura T, et al. Effectiveness of tongue-tie division for speech disorder in children. Pediatr Int. 2014. Aug. 20. [pmid: 25142274].
13 Riskin A, Mansovsky M, Coler-Botzer T, Kugelman A, Shaoul R, Hemo M, Wolff L, Harpaz S, Olchov Z, Bader D. Breastfeed Med. Nov. 2014;9:430-7. [pmid: 25290824].
14 Rose K, Kasbekar AV, Flynn A, et al. Developing a Nurse-Delivered Frenulotomy Service. Otolaryngol Head Neck Surg. 2014. Oct. 22. [pmid: 25338668].
15 Toner D, Giordano T, Handler SD. Office frenotomy for neonates: resolving dysphagia, parental satisfaction and cost-effectiveness. ORL Head Neck Nurs. Spring. 2014;32(2):6-7. [pmid: 24937906].
16 Dave J, Sinha V, Barot D, et al. Speech disorders encountered in routine ENT practice and the role of speech therapy in its effective management. Indian Journal of Otology. October-December. 2013;19(4):169-72.
17 Edmunds JE, Fulbrook P, Miles S. Understanding the experiences of mothers who are breastfeeding an infant with tongue-tie: a phenomenological study. J Hum Lact. 2013;29(2):190-5. [pmid: 23515085].
18 O'Callahan C, Macary S, Clemente S. The effects of office-based frenotomy for anterior and posterior ankyloglossia on breastfeeding. Int J Pediatr Otorhinolaryngol. May. 2013;77(5):827-32. [pmid: 23523198].
19 Mettias B, O'Brien R, Abo Khatwa MM, et al. Division of tongue tie as an outpatient procedure. Technique, efficacy and safety. Int J Pediatr Otorhinolaryngol. Apr. 2013;77(4):550-2. [pmid: 23411135].
20 Sethi N, Smith D, Kortequee S, et al. Benefits of frenulotomy in infants with ankyloglossia. Int J Pediatr Otorhinolaryngol. May. 2013;77(5):762-5. [pmid: 23453795].
21 Marchesan IQ, Martinelli RL, Gusmao RJ. Lingual frenulum: changes after frenectomy. J Soc Bras Fonoaudiol. 2012;24(4):409-12. [pmid: 23306695].
22 Argiris K, Vasani S, Wong G, et al. Audit of tongue-tie division in neonates with breastfeeding difficulties: how we do it. Clin Otolaryngol. Jun. 2011;36(3):256-60. [pmid: 21752209].
23 Choi YS, Lim JS, Han KT, et al. Ankyloglossia correction: Z-plasty combined with genioglossus myotomy. J Craniofac Surg. Nov. 2011;22(6):2238-40. [pmid: 22134257].
24 Puthussery FJ, Shekar K, Gulati A, et al. Use of carbon dioxide laser in lingual frenectomy. Br J Oral Maxillofac Surg. Oct. 2011;49(7):580-1. [pmid: 20728254].
25 Hong P, Lago D, Seargeant J, et al. Defining ankyloglossia: a case series of anterior and posterior tongue ties. Int J Pediatr Otorhinolaryngol. Sep. 2010;74(9):1003-6. [pmid: 20557951].
26 Miranda BH, Milroy CJ. A quick snip - A study of the impact of outpatient tongue tie release on neonatal growth and breastfeeding. J Plast Reconstr Aesthet Surg. Sep. 2010;63(9):e683-5. [pmid: 20493791].
27 Khoo AK, Dabbas N, Sudhakaran N, et al. Nipple pain at presentation predicts success of tongue-tie division for breastfeeding problems. Eur J Pediatr Surg. Dec. 2009;19(6):370-3. [pmid: 19750457].
28 Klockars T, Pitkaranta A. Pediatric tongue-tie division: indications, techniques and patient satisfaction. Int J Pediatr Otorhinolaryngol. Oct. 2009;73(10):1399-401. [pmid: 19660817].
29 Ridgers I, McCombe K, McCombe A. A tongue-tie clinic and service. Br J Midwifery. 2009;17(4):230-3.
30 Geddes DT, Langton DB, Gollow I, et al. Frenulotomy for breastfeeding infants with ankyloglossia: effect on milk removal and sucking mechanism as imaged by ultrasound. Pediatrics. Jul. 2008;122(1):e188-94. [pmid: 18573859].
31 Yeh ML. Outpatient division of tongue-tie without anesthesia in infants and children. World J Pediatr. May. 2008;4(2):106-8. [pmid: 18661764].
32 Srinivasan A, Dobrich C, Mitnick H, et al. Ankyloglossia in breastfeeding infants: the effect of frenotomy on maternal nipple pain and latch. Breastfeed Med. Winter. 2006;1(4):216-24. [pmid: 17661602].
33 Blenkinsop A. A measure of success: audit of frenulotomy for infant feeding: problems associated with tongue-tie. MIDIRS Midwifery Digest. 2003;13(3):389-92.
34 Wallace H, Clarke S. Tongue tie division in infants with breast feeding difficulties. Int J Pediatr Otorhinolaryngol. Jul. 2006;70(7):1257-61. [pmid: 16527363].
35 Amir LH, James JP, Beatty J. Review of tongue-tie release at a tertiary maternity hospital. J Paediatr Child Health. May-Jun. 2005;41(5-6):243-5. [pmid: 15953321].
36 Griffiths DM. Do tongue ties affect breastfeeding?. J Hum Lact. Nov. 2004;20(4):409-14. [pmid: 15479660].
37 Lalakea ML, Messner AH. Ankyloglossia: the adolescent and adult perspective. Otolaryngol Head Neck Surg. May. 2003;128(5):746-52. [pmid: 12748571].
38 Ballard JL, Auer CE, Khoury JC. Ankyloglossia: assessment, incidence, and effect of frenuloplasty on the breastfeeding dyad. Pediatrics. Nov. 2002;110(5):e63. [pmid: 12415069].
39 Messner AH, Lalakea ML. The effect of ankyloglossia on speech in children. Otolaryngol Head Neck Surg. Dec. 2002;127(6):539-45. [pmid: 12501105].
40 Masaitis NS, Kaempf JW. Developing a frenotomy policy at one medical center: a case study approach. J Hum Lact. Sep. 1996;12(3):229-32. [pmid: 9025430].
41 Godley FA. Frenuloplasty with a buccal mucosal graft. Laryngoscope. Mar. 1994;104(3 Pt 1):378-81. [pmid: 8127197].