# Quality Assessment Forms

Table E-1 Cochrane Collaboration modified tool for assessing risk of bias, Part I

REF ID: | | | | Reviewer:
Domain | Description | High risk of bias | Low risk of bias | Unclear risk of bias | Reviewer Assessment
Selection bias Random sequence generation | Described the method used to generate the allocation sequence in sufficient detail to allow an assessment of whether it should produce comparable groups. Reviewer Comments: | Selection bias (biased allocation to interventions) due to inadequate generation of a randomized sequence. | Random sequence generation method should produce comparable groups | Not described in sufficient detail | Judgment: Random Sequence generation; □ High; □ Low; □ Unclear
Selection bias Allocation concealment | Described the method used to conceal the allocation sequence in sufficient detail to determine whether intervention allocations could have been foreseen in advance of, or during, enrollment. Reviewer Comments: | Selection bias (biased allocation to interventions) due to inadequate concealment of allocations prior to assignment. | Intervention allocations likely could not have been foreseen in advance of, or during, enrollment | Not described in sufficient detail | Judgment: Allocation concealment; □ High; □ Low; □ Unclear
Reporting Bias Selective reporting | State how the possibility of selective outcome reporting was examined by the authors and what was found. Reviewer Comments: | Reporting bias due to selective outcome reporting. | Selective outcome reporting bias not detected | Insufficient information to permit judgment of ‘Low risk’ or ‘High risk’. (It is likely that the majority of studies will fall into this category.) | Judgment: Selective reporting; □ High; □ Low; □ Unclear
Other bias Other sources of bias | Any important concerns about bias not addressed above. If particular questions/entries were pre-specified in the study's protocol, responses should be provided for each question/entry. Reviewer Comments: | Bias due to problems not covered elsewhere in the table. | No other bias detected | There may be a risk of bias, but there is either: Insufficient information to assess whether an important risk of bias exists; or Insufficient rationale or evidence that an identified problem will introduce bias. | Judgment: Other sources of bias; □ High; □ Low; □ Unclear

Table E-2 Cochrane Collaboration modified tool for assessing risk of bias for RCTs, Part II

REF ID:
Outcome(s):
Domain | Description | High risk of bias | Low risk of bias | Unclear risk of bias | Reviewer Assessment
Performance bias Blinding (participants and personnel) | Described all measures used, if any, to blind study participants and personnel from knowledge of which intervention a participant received. Provided any information relating to whether the intended blinding was effective. Reviewer Comments: | Performance bias due to knowledge of the allocated interventions by participants and personnel during the study. | Blinding was likely effective. | Not described in sufficient detail | Judgment: Blinding (participants and personnel); □ High; □ Low; □ Unclear
Detection bias Blinding (outcome assessment) | Described all measures used, if any, to blind outcome assessors from knowledge of which intervention a participant received. Provided any information relating to whether the intended blinding was effective. Reviewer Comments: | Detection bias due to knowledge of the allocated interventions by outcome assessors. | Blinding was likely effective. | Not described in sufficient detail | Judgment: Blinding (outcome assessment); □ High; □ Low; □ Unclear
Attrition bias Incomplete outcome data | Described the completeness of outcome data for each main outcome, including attrition and exclusions from the analysis. Stated whether attrition and exclusions were reported, the numbers in each intervention group (compared with total randomized participants), reasons for attrition/exclusions where reported. Reviewer Comments: | Attrition bias due to amount, nature or handling of incomplete outcome data. | Handling of incomplete outcome data was complete and unlikely to have produced bias | Insufficient reporting of attrition/exclusions to permit judgment of ‘Low risk’ or ‘High risk’ (e.g. number randomized not stated, no reasons for missing data provided) | Judgment: Incomplete outcome data; □ High; □ Low; □ Unclear

Table E-3 Cohort study assessment

Questions to Assess the Risk of Bias
1. Do the inclusion/exclusion criteria vary across the comparison groups of the study? | No | Yes | Comments
2 Does the strategy for recruiting participants into the study differ across groups? | No | Yes | Comments
3 Is the selection of the comparison group inappropriate, after taking into account feasibility and ethical considerations? | No | Yes | Comments
4 Was the outcome assessor not blinded to the intervention or exposure status of participants? | No | Yes | Comments
5 Were valid and reliable measures, implemented consistently across all study participants used to assess inclusion/exclusion criteria, intervention/exposure outcomes, participant health benefits and harms, and confounding? | No | Yes | Comments
6 Was the length of followup different across study groups? | No | Yes | Comments
7 In cases of high loss to followup (or differential loss to followup), was the impact assessed (e.g., through sensitivity analysis or other adjustment method)? | No | Yes | Comments
Questions to Assess Confounding
8 Any attempt to balance the allocation between the groups or match groups (e.g., through stratification, matching, propensity scores)? | No | Yes | Comments
9 Were the important confounding variables taken into account in the design and/or analysis (e.g., through matching, stratification, interaction terms, multivariate analysis, or other statistical adjustment such as instrumental variables)? | No | Yes | Comments
Questions to Assess Precision
10 Are the statistical methods used to assess the primary benefit outcomes inadequate? | No | Yes | Comments
11 Are the statistical methods used to assess the main harm or adverse event outcomes inadequate? | No | Yes | Comments

Based on cohort questions from: Viswanathan M, Berkman ND, Dryden DM, et al. Assessing Risk of Bias and Confounding in Observational Studies of Interventions or Exposures: Further Development of the RTI Item Bank [Internet]. Rockville (MD). Agency for Healthcare Research and Quality (US). 2013. Aug. Available from: http://www.ncbi.nlm.nih.gov/books/NBK154461/.

Table E-4 Minimum criteria to assess risk of bias in case series

Selection bias and confounding
1. Were the important confounding and modifying variables taken into account in the design and analysis? | Yes | No | NA | NR | Comments
Performance bias
2 Was any impact from a concurrent intervention or an unintended exposure that might bias results ruled out by the researchers? | Yes | No | NA | NR | Comments
3 Was the study free from variations from the study protocol that could compromise the conclusions of the study? | Yes | No | NA | NR | Comments
Attrition bias
4 Was there a low rate of differential or overall attrition? (note: low≤20%) | Yes | No | NA | NR | Comments
5 Attrition did not result in a difference in group characteristics between baseline and follow-up | Yes | No | NA | NR | Comments
Detection bias
6 Were the outcome assessors blinded to the intervention or exposure status of participants? | Yes | No | NA | NR | Comments
7a Are the inclusion/exclusion criteria clearly stated? (note: consider whether level of detail would allow for replication) | Yes | No | NA | NR | Comments
7b Were the measures implemented consistently across all study participants? | Yes | No | NA | NR | Comments
8a Are interventions/exposures assessed using appropriate measures? | Yes | No | NA | NR | Comments
8b Were the interventions implemented consistently across all study participants? | Yes | No | NA | NR | Comments
9a Are primary outcome measurement approaches clearly described? List outcome.; Outcome 1: | Yes | No | NA | NR | Comments
Outcome 2:
Outcome 3:
Outcome 4:
Outcome 5:
Outcome 6:
9b Are primary outcomes assessed using appropriate measures? List outcome.; Outcome 1: | Yes | No | NA | NR | Comments
Outcome 2: | Yes | No | NA | NR | Comments
Outcome 3: | Yes | No | NA | NR | Comments
Outcome 4: | Yes | No | NA | NR | Comments
Outcome 5: | Yes | No | NA | NR | Comments
Outcome 6: | Yes | No | NA | NR | Comments
9b Was outcome assessment implemented consistently across all study participants? | Yes | No | NA | NR | Comments
10a Are confounding variables assessed using appropriate measures? | Yes | No | NA | NR | Comments
10b Was assessment of confounding variables implemented consistently across all study participants? | Yes | No | NA | NR | Comments
11 Did the study account for secular trends and regression to the mean? | Yes | No | NA | NR | Comments
Reporting bias
12a Are the potential outcomes pre-specified by the researchers? | Yes | No | NA | NR | Comments
12b Are harms pre-specified by the researchers? | Yes | No | NA | NR | Comments
13 Are all pre-specified outcomes reported? | Yes | No | NA | NR | Comments
13a Are all pre-specified harms reported? | Yes | No | NA | NR | Comments

Table E-5 Harms risk-of-bias assessment

RefID: __________________ Reviewer:____________________

Question | Yes | No | Comments
Were the harms predefined using standardized or precise definitions? | Yes | No | Comments
Are all pre-specified harms reported? | Yes | No | Comments
Did the author(s) use STANDARD scale(s) or checklist(s) for harms collection? | Yes | No | Comments
Are the statistical methods used to assess the main harm or adverse event outcomes adequate? | Yes | No | Comments

Based on questions from: Viswanathan M, Berkman ND, Dryden DM, et al. Assessing Risk of Bias and Confounding in Observational Studies of Interventions or Exposures: Further Development of the RTI Item Bank [Internet]. Rockville (MD). Agency for Healthcare Research and Quality (US). 2013. Aug. Available from: http://www.ncbi.nlm.nih.gov/books/NBK154461/. and Santaguida P, Raina P. McMaster Quality Scale of Harms (McHarm) for primary studies: Manual for use of the McHarm. Hamilton, ON. McMaster University. n.d. .