# Evidence Table

Table D-1 Evidence table

Table D-2 Abbreviations in evidence table

μm | Micrometers
BSES-SF | Breastfeeding Self-Efficacy Scale – Short Form
CI | Confidence Interval
CM | Centimeters
CPT | Current Procedural Terminology
ENT | Otolaryngologist
g/d | Weight Velocity
HATLFF | Hazelbaker Assessment Tool for Lingual Frenulum Function
IBAT | Infant Breastfeeding Assessment Tool
ICD | International Classification of Diseases
IQR | Interquartile Range
J/cm^2^ | Joules per Area
LATCH | Latch, Audible swallowing, Type of Nipple, Comfort, Hold;
mL/min | Milliliters per Minute
MM | Millimeters
MPQ | McGill Pain Questionnaire
NA | Not Applicable
NOMESCO | Nordic Medico-Statistical Committee
NR | Not Reported
NS | Not Statistically Significant
ORL | Otorhinolaryngology
PRI | Pain Rating Index
PPI | Present Pain Intensity
RCT | Randomized, Controlled Trials
SD | Standard Deviation
SE | Standard error
SF-MQP | Short Form McGill Pain Scale
VAS | Visual Analog Scale for Pain
W/cm^2^ | Power per Area
WHO | World Health Organization

## Evidence Table References

1 Amir LH, James JP, Beatty J. Review of tongue-tie release at a tertiary maternity hospital. J Paediatr Child Health. May-Jun. 2005;41(5-6):243-5. [pmid: 15953321].
2 Argiris K, Vasani S, Wong G, et al. Audit of tongue-tie division in neonates with breastfeeding difficulties: how we do it. Clin Otolaryngol. Jun. 2011;36(3):256-60. [pmid: 21752209].
3 Ballard JL, Auer CE, Khoury JC. Ankyloglossia: assessment, incidence, and effect of frenuloplasty on the breastfeeding dyad. Pediatrics. Nov. 2002;110(5):e63. [pmid: 12415069].
4 Berry J, Griffiths M, Westcott C. A double-blind, randomized, controlled trial of tongue-tie division and its immediate effect on breastfeeding. Breastfeed Med. Jun. 2012;7(3):189-93. [pmid: 21999476].
5 Blenkinsop A. A measure of success: audit of frenulotomy for infant feeding: problems associated with tongue-tie. MIDIRS Midwifery Digest. 2003;13(3):389-92.
6 Buryk M, Bloom D, Shope T. Efficacy of neonatal release of ankyloglossia: a randomized trial. Pediatrics. Aug. 2011;128(2):280-8. [pmid: 21768318].
7 Choi YS, Lim JS, Han KT, et al. Ankyloglossia correction: Z-plasty combined with genioglossus myotomy. J Craniofac Surg. Nov. 2011;22(6):2238-40. [pmid: 22134257].
8 Dave J, Sinha V, Barot D, et al. Speech disorders encountered in routine ENT practice and the role of speech therapy in its effective management. Indian Journal of Otology. October-December. 2013;19(4):169-72.
9 Dollberg S, Marom R, Botzer E. Lingual frenotomy for breastfeeding difficulties: a prospective follow-up study. Breastfeed Med. Jun. 2014;3:286-9. [pmid: 24892968].
10 Dollberg S, Manor Y, Makai E, et al. Evaluation of speech intelligibility in children with tongue-tie. Acta Paediatr. Sep. 2011;100(9):e125-7. [pmid: 21401716].
11 Dollberg S, Botzer E, Grunis E, et al. Immediate nipple pain relief after frenotomy in breast-fed infants with ankyloglossia: a randomized, prospective study. J Pediatr Surg. Sep. 2006;41(9):1598-600. [pmid: 16952598].
12 Edmunds JE, Fulbrook P, Miles S. Understanding the experiences of mothers who are breastfeeding an infant with tongue-tie: a phenomenological study. J Hum Lact. 2013;29(2):190-5. [pmid: 23515085].
13 Emond A, Ingram J, Johnson D, et al. Randomised controlled trial of early frenotomy in breastfed infants with mild-moderate tongue-tie. Arch Dis Child Fetal Neonatal Ed. Nov. 18. 2013;99(3):F189-95. [pmid: 24249695].
14 Finigan V. Overcoming tongue-tie. Midwives. 2014;17(3):48-9. [pmid: 24960964].
15 Fiorotti RC, Bertolini MM, Nicola JH, et al. Early lingual frenectomy assisted by CO2 laser helps prevention and treatment of functional alterations caused by ankyloglossia. Int J Orofacial Myology. Nov. 2004;30:64-71. [pmid: 15832863].
16 Geddes DT, Langton DB, Gollow I, et al. Frenulotomy for breastfeeding infants with ankyloglossia: effect on milk removal and sucking mechanism as imaged by ultrasound. Pediatrics. Jul. 2008;122(1):e188-94. [pmid: 18573859].
17 Godley FA. Frenuloplasty with a buccal mucosal graft. Laryngoscope. Mar. 1994;104(3 Pt 1):378-81. [pmid: 8127197].
18 Griffiths DM. Do tongue ties affect breastfeeding?. J Hum Lact. Nov. 2004;20(4):409-14. [pmid: 15479660].
19 Heller J, Gabbay J, O'Hara C, et al. Improved ankyloglossia correction with four-flap Z-frenuloplasty. Ann Plast Surg. Jun. 2005;54(6):623-8. [pmid: 15900148].
20 Hogan M, Westcott C, Griffiths M. Randomized, controlled trial of division of tongue-tie in infants with feeding problems. J Paediatr Child Health. May-Jun. 2005;41(5-6):246-50. [pmid: 15953322].
21 Hong P, Lago D, Seargeant J, et al. Defining ankyloglossia: a case series of anterior and posterior tongue ties. Int J Pediatr Otorhinolaryngol. Sep. 2010;74(9):1003-6. [pmid: 20557951].
22 Khoo AK, Dabbas N, Sudhakaran N, et al. Nipple pain at presentation predicts success of tongue-tie division for breastfeeding problems. Eur J Pediatr Surg. Dec. 2009;19(6):370-3. [pmid: 19750457].
23 Klockars T, Pitkaranta A. Pediatric tongue-tie division: indications, techniques and patient satisfaction. Int J Pediatr Otorhinolaryngol. Oct. 2009;73(10):1399-401. [pmid: 19660817].
24 Lalakea ML, Messner AH. Ankyloglossia: the adolescent and adult perspective. Otolaryngol Head Neck Surg. May. 2003;128(5):746-52. [pmid: 12748571].
25 Marchesan IQ, Martinelli RL, Gusmao RJ. Lingual frenulum: changes after frenectomy. J Soc Bras Fonoaudiol. 2012;24(4):409-12. [pmid: 23306695].
26 Masaitis NS, Kaempf JW. Developing a frenotomy policy at one medical center: a case study approach. J Hum Lact. Sep. 1996;12(3):229-32. [pmid: 9025430].
27 Messner AH, Lalakea ML. The effect of ankyloglossia on speech in children. Otolaryngol Head Neck Surg. Dec. 2002;127(6):539-45. [pmid: 12501105].
28 Mettias B, O'Brien R, Abo Khatwa MM, et al. Division of tongue tie as an outpatient procedure. Technique, efficacy and safety. Int J Pediatr Otorhinolaryngol. Apr. 2013;77(4):550-2. [pmid: 23411135].
29 Miranda BH, Milroy CJ. A quick snip - A study of the impact of outpatient tongue tie release on neonatal growth and breastfeeding. J Plast Reconstr Aesthet Surg. Sep. 2010;63(9):e683-5. [pmid: 20493791].
30 O'Callahan C, Macary S, Clemente S. The effects of office-based frenotomy for anterior and posterior ankyloglossia on breastfeeding. Int J Pediatr Otorhinolaryngol. May. 2013;77(5):827-32. [pmid: 23523198].
31 Puthussery FJ, Shekar K, Gulati A, et al. Use of carbon dioxide laser in lingual frenectomy. Br J Oral Maxillofac Surg. Oct. 2011;49(7):580-1. [pmid: 20728254].
32 Ridgers I, McCombe K, McCombe A. A tongue-tie clinic and service. Br J Midwifery. 2009;17(4):230-3.
33 Riskin A, Mansovsky M, Coler-Botzer T, et al. Tongue-tie and breastfeeding in newborns-mothers' perspective. Breastfeed Med. Nov. 2014;9:430-7. [pmid: 25290824].
34 Rose K, Kasbekar AV, Flynn A, et al. Developing a Nurse-Delivered Frenulotomy Service. Otolaryngol Head Neck Surg. 2014. Oct. 22. [pmid: 25338668].
35 Sethi N, Smith D, Kortequee S, et al. Benefits of frenulotomy in infants with ankyloglossia. Int J Pediatr Otorhinolaryngol. May. 2013;77(5):762-5. [pmid: 23453795].
36 Srinivasan A, Dobrich C, Mitnick H, et al. Ankyloglossia in breastfeeding infants: the effect of frenotomy on maternal nipple pain and latch. Breastfeed Med. Winter. 2006;1(4):216-24. [pmid: 17661602].
37 Steehler MW, Steehler MK, Harley EH. A retrospective review of frenotomy in neonates and infants with feeding difficulties. Int J Pediatr Otorhinolaryngol. Sep. 2012;76(9):1236-40. [pmid: 22704670].
38 Toner D, Giordano T, Handler SD. Office frenotomy for neonates: resolving dysphagia, parental satisfaction and cost-effectiveness. ORL Head Neck Nurs. Spring. 2014;32(2):6-7. [pmid: 24937906].
39 Wallace H, Clarke S. Tongue tie division in infants with breast feeding difficulties. Int J Pediatr Otorhinolaryngol. Jul. 2006;70(7):1257-61. [pmid: 16527363].
40 Walls A, Pierce M, Wang H, et al. Parental perception of speech and tongue mobility in three-year olds after neonatal frenotomy. Int J Pediatr Otorhinolaryngol. Jan. 2014;78(1):128-31. [pmid: 24315215].
41 Yeh ML. Outpatient division of tongue-tie without anesthesia in infants and children. World J Pediatr. May. 2008;4(2):106-8. [pmid: 18661764].