# Excluded Studies

## Abstract Review Exclusion Reasons

X-1 | Does not address treatment of ankyloglossia and/or concomitant lip-tie or harms of treatment/no treatment
X-2 | Not original research
X-3 | Participants not in target age range

1 Oberndorf CP. Slips of the tongue and pen. J Abnorm Psychol. 1914;8(6):378-84. PMID:. X-1.
2 Special mental conditions. Psychol Bull. 1925;22(5):291-4. PMID:. X-1.
3 Jidigian Y, Bickers W. Transplantation of the ureters into the rectosigmoid. Surg Gynecol Obstet. Jul. 1947;85(1):30-4. X-1. [pmid: 20249243].
4 Phillips JC. Rehabilitation in a case of manic depressive reaction with a speech defect. Case Reports in Clinical Psychology. 1951;2(4):50-2. PMID:. X-3.
5 Masters F, Georgiade N, Horton C, et al. The use of interlocking Z's in the repair of incomplete clefts of the lip and secondary lip deformities. Plast Reconstr Surg (1946). Oct. 1954;14(4):287-92. X-1. [pmid: 13215109].
6 Beers MD, Pruzansky S. The growth of the head of an infant with mandibular micrognathia, glossoptosis and cleft palate following the Beverly Douglas operation. Plast Reconstr Surg (1946). Sep. 1955;16(3):189-93. X-1. [pmid: 13266547].
7 Knight PF. Anesthesia in recurring post-tonsiliectomy haemorrhage due to macroglossia; a case report. Br J Anaesth. Feb. 1958;30(2):83-4. X-1. [pmid: 13523030].
8 Watt OM. Lingual thyroid; complicating general anaesthesia. Anaesthesia. Apr. 1959;14(2):162-7. X-1. [pmid: 13637370].
9 Perzik SL. Early management in extensive cervical cystic hygroma and macroglossia. Arch Surg. Mar. 1960;80:460-3. X-1. [pmid: 14432102].
10 Kokic A, Gazabatt C. Dissection of labial frenum: a new technic. J Oral Surg Anesth Hosp Dent Serv. Jul. 1961;19:326-8. X-1. [pmid: 13757671].
11 Moyson F. A plea against tracheostomy in the Pierre-Robin syndrome. Br J Plast Surg. Oct. 1961;14:187-9. X-1. [pmid: 14476768].
12 Goldberg MH, Eckblom RH. The treatment of the Pierre Robin syndrome. Pediatrics. Sep. 1962;30:450-8. X-1. [pmid: 13899709].
13 Gorlin RJ, Psaume J. Orodigitofacial dysostosis--a new syndrome. A study of 22 cases. J Pediatr. Oct. 1962;61:520-30. X-1. [pmid: 13900550].
14 Costich ER. The role of oral surgery in preventive dentistry. Dent Clin North Am. Jul. 1965;25:475-83. X-1. [pmid: 14290101].
15 Costich ER. The role of oral surgery in preventive dentistry. Dent Clin North Am. Jul. 1965;25:475-83. X-1. [pmid: 14290101].
16 Marge M. Speech difficulties associated with dental anomalies in children. ASDC J Dent Child. 1965;32:82-9. X-1. [pmid: 14285595].
17 Olin WH, Huffman WC, Schweiger JW. Congenital pits of the lower lip associated with cleft lip and palate. A case report. J Iowa Med Soc. Dec. 1965;55(12):698-701. X-1. [pmid: 5840072].
18 Risch F, Boden ES, Mindlin H, et al. The relationship of dental hypoplasia to epilepsy in adults. Oral Surg Oral Med Oral Pathol. Feb. 1965;19:269-75. X-1. [pmid: 14232608].
19 Combs JT, Grunt JA, Brandt IK. New syndrome of neonatal hypoglycemia. Association with visceromegaly, macroglossia, microcephaly and abnormal umbilicus. N Engl J Med. Aug. 4. 1966;275(5):236-43. X-1. [pmid: 5943267].
20 Degering CI. Prenatal therapeutic radiation. Preliminary report of two cases. Oral Surg Oral Med Oral Pathol. Apr. 1966;21(4):473-7. X-1. [pmid: 5218152].
21 DesEnfants JA. The abnormal labial frenum. J Mo Dent Assoc. Oct. 1966;46(8):9-12. X-1. [pmid: 5223623].
22 Dewel BF. The labial frenum, midline diastema, and palatine papilla: a clinical analysis. Dent Clin North Am. Mar. 1966:175-84. X-1. [pmid: 5216396].
23 Garfinkle VI. Surgery for prosthetics. J Oral Surg. May. 1966;24(3):209-17. X-1. [pmid: 5325394].
24 Gibson II. Macroglossia. Gerontol Clin (Basel). 1966;8(4):202-6. X-1. [pmid: 5964997].
25 Hale ML. Pediatric exodontia. Dent Clin North Am. Jul. 1966:405-19. X-1. [pmid: 4222774].
26 Hawkinson RT. Diagnosis and preoperative planning for the surgical correction of mandibular prognathism. J Prosthet Dent. Mar-Apr. 1966;16(2):351-70. X-1. [pmid: 5217118].
27 Kramer GM, Kohn JD. A classification of periodontal surgery: An approach based on tissue coverage. Periodontics. Mar-Apr. 1966;4(2):80-9. X-1. [pmid: 5217828].
28 Monroe CW. Midline cleft of the lower lip, mandible and tongue with flexion contracture of the neck: case report and review of the literature. Plast Reconstr Surg. Oct. 1966;38(4):312-9. X-1. [pmid: 5926987].
29 Nabers JM. Extension of the vestibular fornix utilizing a gingival graft--case history. Periodontics. Mar-Apr. 1966;4(2):77-9. X-1. [pmid: 5217827].
30 Tucker CC, Finley SC, Tucker ES, et al. Oral-facial-digital syndrome, with polycystic kidneys and liver: pathological and cytogenetic studies. J Med Genet. Jun. 1966;3(2):145-7. X-1. [pmid: 5963210].
31 Bodner BN. Dentoalveolar surgery. Dent Dig. Jan. 1967;73(1):12-5. X-1. [pmid: 5225133].
32 Edlan A. The prevention of inflammatory damage to the periodontium in children. Int Dent J. Jun. 1967;17(2):329-38. X-1. [pmid: 5233871].
33 Egyedi P. Some aspects of pre-operative planning in the correction of deformities of the jaws. Trans Int Conf Oral Surg. 1967:62-8. X-1. [pmid: 5237111].
34 Gardiner JH. Midline spaces. Dent Pract Dent Rec. Apr. 1967;17(8):287-97. X-1. [pmid: 5228693].
35 Gonzalez-Ulloa M, Stevens E. The tent-pole mechanics in the correction of the retractive syndrome of the middle third of the face. Klin Med Osterr Z Wiss Prakt Med. 1967;22(11):483-4. X-1. [pmid: 5631401].
36 Hanson ML. Some suggestions for more effectiive therapy for tongue thrust. J Speech Hear Disord. 1967;32(1):75-9. PMID:. X-1, X-2, X-3. [pmid: 6017929].
37 Howe GL. Soft tissue plastic operations in the maxilla. Trans Int Conf Oral Surg. 1967:192-6. X-1. [pmid: 5237058].
38 Irving IM. Exomphalos with macroglossia: a study of eleven cases. J Pediatr Surg. Dec. 1967;2(6):499-507. X-1. [pmid: 4865835].
39 James GA. Clinical implications of a follow-up study after fraenectomy. Dent Pract Dent Rec. Apr. 1967;17(8):299-305. X-1. [pmid: 5228694].
40 Janebova M. Cortical spreading depression as a means of analysing the role of the thalamic gustatory area in taste discrimination in rats. Physiol Bohemoslov. 1967;16(1):18-22. PMID:. X-1. [pmid: 4226640].
41 Merson RM. Speech rehabilitation in congenital aglossia. J Rehabil. Sep-Oct. 1967;33(5):33-4. X-1. [pmid: 6073256].
42 Pitanguy I, Franco T. Nonoperated facial fissures in adults. Plast Reconstr Surg. Jun. 1967;39(6):569-77. X-1. [pmid: 4960961].
43 Rose GJ. Receding mandibular labial gingiva on children. Angle Orthod. Apr. 1967;37(2):147-50. X-1. [pmid: 5229085].
44 Swan H, Jenkins D, Schemmel J. Thyroid autograft. A 12-year follow-up. Arch Surg. Jun. 1967;94(6):817-20. X-1. [pmid: 4226078].
45 Tulley WJ. Prevention in orthodontics within the scope of the school programme. Int Dent J. Jun. 1967;17(2):368-83. X-1. [pmid: 5248124].
46 Weiner MF, Land M. Psychiatry, psychosomatics and dentistry. Psychosomatics. Nov-Dec. 1967;8(6):338-41. X-1. [pmid: 6078040].
47 Abramovich A, Devoto FC. Anomalous maxillofacial patterns produced by maternal lathyrism in rat foetuses. Arch Oral Biol. Jul. 1968;13(7):823-6. X-1. [pmid: 5244303].
48 Allen DL, Shell JH. Clinical and radiographic evaluation of a periosteal separation procedure. J Periodontol. Sep. 1968;39(5):290-5. X-1. [pmid: 5244723].
49 Arima M, Komiya K, Ono K, et al. Congenital minor anomalies in mentally retarded children. Proc Aust Assoc Neurol. 1968;5(1):177-82. X-1. [pmid: 5709957].
50 Bachicha RL, Higgins LT. The abnormal frenum and its surgical correction. Chronicle. Dec. 1968;32(4):112-3. X-1. [pmid: 5247407].
51 Bjuggren G, Jensen R, Strombeck JO. Macroglossia and its surgical treatment. Indications and postoperative experiences from the orthodontic, phoniatric, and surgical points of view. Scand J Plast Reconstr Surg. 1968;2(2):116-24. X-1. [pmid: 5733935].
52 Block JR. The role of the speech clinician in determining indications for frenulotomy in cases of ankyloglossia. N Y State Dent J. Oct. 1968;34(8):479-81. X-1, X-2. [pmid: 5244728].
53 Bressman E, Chasens AI. Free gingival graft with periosteal fenestration. J Periodontol. Sep. 1968;39(5):298-300. X-1. [pmid: 5244725].
54 Buisson G. Preprosthetic surgery. Int Dent J. Mar. 1968;18(1):32-47. X-1. [pmid: 4868941].
55 Doege TC, Campbell MM, Bryant JS, et al. Mental retardation and dermatoglyphics in a family with the oral-facial-digital syndrome. Am J Dis Child. Dec. 1968;116(6):615-22. X-1. [pmid: 4301481].
56 Ewen SJ. Frena: Their roles especially in periodontics. N Y State Dent J. Dec. 1968;34(10):626-30. X-1. [pmid: 5246656].
57 Gayler GG. Additional cases of a cardiofacial syndrome. J Pediatr. Dec. 1968;73(6):953-4. X-1. [pmid: 5723510].
58 Gellis SS, Feingold M. Picture of the month: syndrome of neonatal hypoglycemia, macroglossia, visceromegaly, and omphalocele. Am J Dis Child. Mar. 1968;115(3):349-50. X-1. [pmid: 5640529].
59 Gibbs SL. The superior labial frenum and its orthodontic considerations. N Y State Dent J. Nov. 1968;34(9):550-3. X-1. [pmid: 5245974].
60 Hanley FJ, Floyd CE, Parker D. Congenital partial hemihypertrophy of the face. Report of three cases. J Oral Surg. Feb. 1968;26(2):136-41. X-1. [pmid: 5241846].
61 Hiatt WH. Free gingival graft or frenectomy?. J Colo Dent Assoc. Mar. 1968;46(2):7-9. X-1. [pmid: 5242516].
62 Jolly M. Soft tissue surgery in general dental practice. Aust Dent J. Feb. 1968;13(1):1-16. X-1. [pmid: 4869053].
63 Knaysi GA Jr., Cosman B, Crikelair GF. Hidradenitis suppurativa. Jama. Jan. 1. 1968;203(1):19-22. X-1. [pmid: 4864515].
64 Laskin DM. Surgical aids in orthodontics. Dent Clin North Am. Jul. 1968:509-24. X-1. [pmid: 5240775].
65 Lazarus L, Young JD, Friend JC. E.M.G. syndrome and carbohydrate metabolism. Lancet. Dec. 21. 1968;2(7582):1347-8. X-1. [pmid: 4177412].
66 Nadeau J. Special prostheses. J Prosthet Dent. Jul. 1968;20(1):62-76. X-1. [pmid: 4873089].
67 Popescu V. Congenital transverse facial cleft. Rom Med Rev. 1968;12(4):75-85. X-1. [pmid: 5703538].
68 Poschel BP. Do biological reinforcers act via the self-stimulation areas of the brain?. Physiol Behav. 1968;3(1):53-60. PMID:. X-1.
69 Powell WJ, Jenkins HP. Transverse facial clefts. Report of three cases. Plast Reconstr Surg. Nov. 1968;42(5):454-9. X-1. [pmid: 5699562].
70 Shafer AD. Primary macroglossia. Clin Pediatr (Phila). Jun. 1968;7(6):357-63. X-1. [pmid: 5648339].
71 Sinnette C, Odeku EL. Rubinstein-Taybi syndrome. The first case in an African child and the first case recognized at birth. Clin Pediatr (Phila). Aug. 1968;7(8):488-92. X-1. [pmid: 4970066].
72 Spivack J, Bennett JE. Glossopalatine ankylosis. Plast Reconstr Surg. Aug. 1968;42(2):129-36. X-1. [pmid: 5665378].
73 Stahl A. Clinical, orthodontic and radiological findings in the jaws and face of children with dysmelia associated with thalidomide-embryopathy. Int Dent J. Sep. 1968;18(3):631-8. X-1. [pmid: 5246854].
74 Stanback JS 3rd, Peagler FD. Primary amyloidosis. Review of the literature and report of a case. Oral Surg Oral Med Oral Pathol. Dec. 1968;26(6):774-81. X-1. [pmid: 5246776].
75 Tarsitano JJ, Cohen SM. Revelation and initial diagnosis of mild hemophilia from dental findings: report of case. J Am Dent Assoc. Apr. 1968;76(4):823-5. X-1. [pmid: 5300257].
76 Tawil HM, Najjar SS. Congenital absence of the breasts. J Pediatr. Nov. 1968;73(5):751-3. X-1. [pmid: 5681165].
77 West EE. Diastema--a cause for concern. Dent Clin North Am. Jul. 1968:425-34. X-1. [pmid: 5248121].
78 Buchanan J, Frew ID, Gibson II, et al. Macroglossia in myelomatosis. Br J Plast Surg. Apr. 1969;22(2):157-60. X-1. [pmid: 5785533].
79 Cosman B, Crikelair GF. Midline branchiogenic syndromes. Plast Reconstr Surg. Jul. 1969;44(1):41-8. X-1. [pmid: 5791338].
80 Delilkan AE. Anaesthetic problems in a case of pseudo-hypertrophic muscular dystrophy presenting with macroglossia. Med J Malaya. Jun. 1969;23(4):253-5. X-1. [pmid: 4242170].
81 DeMyer W, Baird I. Mortality and skeletal malformations from amniocentesis and oligohydramnios in rats: cleft palate, clubfoot, microstomia, and adactyly. Teratology. Feb. 1969;2(1):33-7. X-1. [pmid: 4892408].
82 Gordon H, Davies D, Friedberg S. Congenital pits of the lower lip with cleft lip and palate. S Afr Med J. Oct. 18. 1969;43(42):1275-9. X-1. [pmid: 5361756].
83 Harris F, Zachary RB. xomphalos and marcroglossia (Beckwith's syndrome). Proc R Soc Med. Sep. 1969;62(9):905-6. X-1. [pmid: 5823807].
84 Hoggins GS. Aglossia congenita with bony fusion of the jaws. Br J Oral Surg. Jul. 1969;7(1):63-5. X-1. [pmid: 4309862].
85 Jain SN. Lingual thyroid. Int Surg. Oct. 1969;52(4):320-5. X-1. [pmid: 5347292].
86 Knowles CC, Littlewood AH, Bush PG. Incomplete median cleft of the lower lip and chin with complete cleft of the mandible. A preliminary report. Br Dent J. Oct. 7. 1969;127(7):337-9. X-1. [pmid: 5259661].
87 Pitanguy I. A chiro-cheilo-podalic syndrome. Br J Plast Surg. Jan. 1969;22(1):79-85. X-1. [pmid: 5775429].
88 Swanson LT, Murray JE. Partial glossectomy to stabilize occlusion following surgical correction of prognathism. Report of a case. Oral Surg Oral Med Oral Pathol. Jun. 1969;27(6):707-15. X-1. [pmid: 5254558].
89 Vande Voorde HE. Gingival grafting and gingival repositioning. J Am Dent Assoc. Dec. 1969;79(6):1415-20. X-1. [pmid: 5259861].
90 White JH. Oculo-nasal dysplasia. J Genet Hum. May. 1969;17(1):107-14. X-1. [pmid: 5808535].
91 Woolf CM, Woolf RM, Broadbent TR. Cleft lip and palate in parent and child. Plast Reconstr Surg. Nov. 1969;44(5):436-40. X-1. [pmid: 5345481].
92 Arons MS, Solitare GB, Grunt JA. The macroglossia of Beckwith's syndrome. Plast Reconstr Surg. Apr. 1970;45(4):341-5. X-1. [pmid: 5435867].
93 Barakat NJ, Howe GL. Pre-prosthetic surgery. 2. Rev Dent Liban. Mar-Jun. 1970;20(1):39-46. X-1. [pmid: 4934337].
94 Barakat NJ, Howe GL. Pre-prosthetic surgery. 1. Rev Dent Liban. Mar-Jun. 1970;20(1):27-38. X-1. [pmid: 4934336].
95 Bodner JW, Goss AN, Avery JK. Partial fusion between upper and lower lips in the rat: a report of a case. Cleft Palate J. Jan. 1970;7:330-5. X-1. [pmid: 5266344].
96 Boo-Chai K. The oblique facial cleft. A report of 2 cases and a review of 41 cases. Br J Plast Surg. Oct. 1970;23(4):352-9. X-1. [pmid: 4990922].
97 Bowers DG Jr. Congenital lower lip sinuses with cleft palate. Plast Reconstr Surg. Feb. 1970;45(2):151-4. X-1. [pmid: 5411896].
98 Curran JP, al-Salihi FL, Allderdice PW. Partial deletion of the long arm of chromosome E-18. Pediatrics. Nov. 1970;46(5):721-9. X-1. [pmid: 5481073].
99 Dorman HL, Bishop JG. Production of experimental edema in dog tongue with dilute hydrogen peroxide. Oral Surg Oral Med Oral Pathol. Jan. 1970;29(1):38-43. X-1. [pmid: 5261906].
100 Ewer RW, Kotheimer TG Jr. Spontaneous burned-out acromegaly with preservation of normal human growth hormone responses: diagnostic, historical, theoretical, and treatment aspects. Johns Hopkins Med J. Oct. 1970;127(4):199-212. X-1. [pmid: 4320105].
101 Hamula W. Surgical alteration of muscle attachments to enhance esthetics and denture stability. Am J Orthod. Apr. 1970;57(4):327-69. X-1. [pmid: 5265006].
102 Hitchin AD, Smith GA. The sequelae in a case of sublingual dermoid cyst with ankyloglossia. Br J Oral Surg. Nov. 1970;8(2):175-8. X-2, X-2. [pmid: 5276749].
103 Holbrook LA. Congenital midline sinus of the upper lip. Br J Plast Surg. Apr. 1970;23(2):155-60. X-1. [pmid: 5448527].
104 Kelly E. Tissue preparation for the complete denture patient--a simplified approach. Dent Clin North Am. Jul. 1970;14(3):441-52. X-1. [pmid: 5268161].
105 Khanna NN. Congenital lip sinuses. Aust N Z J Surg. Nov. 1970;40(2):184-6. X-1. [pmid: 5274942].
106 Mackenzie KI. Mid-line sinus of the upper lip. J Laryngol Otol. Feb. 1970;84(2):235-8. X-1. [pmid: 5416439].
107 Malakouti B. Combined procedures in corrective surgery of prognathism and associated deformities. J Oral Surg. Jul. 1970;28(7):506-15. X-1. [pmid: 5269213].
108 McConnel FM, Zellweger H, Lawrence RA. Labial pits--cleft lip and-or palate syndrome. A report of five new families. Arch Otolaryngol. May. 1970;91(5):407-11. X-1. [pmid: 5442732].
109 Moncrieff MW, Mann JR, Goldsmith AR, et al. Macroglossia, abnormal umbilicus and hypoglycaemia (Beckwith's syndrome). Postgrad Med J. Mar. 1970;46(533):162-6. X-1. [pmid: 5440739].
110 Mouly R. Correction of hypertrophy of the upper lip. Plast Reconstr Surg. Sep. 1970;46(3):262-4. X-1. [pmid: 4915226].
111 Muhlbauer WD. Elongation of mouth in post-burn microstomia by a double Z-plasty. Plast Reconstr Surg. Apr. 1970;45(4):400-2. X-1. [pmid: 5435871].
112 Nanda R, van der Linden FP, Jansen HW. Production of cleft palate with dexamethasone and hypervitaminosis A in rat embryos. Experientia. Oct. 15. 1970;26(10):1111-2. X-1. [pmid: 4320730].
113 Pereira LG. Partial glossectomy and osteotomy in the correction of mandibular prognathism. Trans Int Conf Oral Surg. 1970:185-9. X-1. [pmid: 5282460].
114 Reed WB, Lopez DA, Landing B. Clinical spectrum of anhidrotic ectodermal dysplasia. Arch Dermatol. Aug. 1970;102(2):134-43. X-1. [pmid: 5430308].
115 Rehim IA. Surgical management of double lip case report. Egypt Dent J. Apr. 1970;16(2):173-8. X-1. [pmid: 5270718].
116 Smith JD, Cagas CR, Seely JR, et al. Defective iodide organification in “cryptothyroidism”. J Okla State Med Assoc. May. 1970;63(5):195-9. X-1. [pmid: 5511591].
117 Solomon LM, Fretzin D, Pruzansky S. Pilosebaceous dysplasia in the oral-facial-digital syndrome. Arch Dermatol. Dec. 1970;102(6):598-602. X-1. [pmid: 5501900].
118 Sotelo-Avila C, Singer DB. Syndrome of hyperplastic fetal visceromegaly and neonatal hypoglycemia (Beckwith's syndrome). A report of seven cases. Pediatrics. Aug. 1970;46(2):240-51. X-1. [pmid: 5432155].
119 Tipton JB. Closure of large septal perforations with a labial-buccal flap. Plast Reconstr Surg. Nov. 1970;46(5):514-5. X-1. [pmid: 4919288].
120 Weinberg B, Paras N. Speech intelligibility of a seven-year-old girl with severe congenital hypoplasia of the tongue. Cleft Palate J. Apr. 1970;7:436-42. X-1. [pmid: 5270490].
121 Wolfe SM, Henkin RI. Absence of taste in type II familial dysautonomia: unresponsiveness to methacholine despite the presence of taste buds. J Pediatr. Jul. 1970;77(1):103-8. X-1. [pmid: 5450270].
122 Allison ML, Miller CW, Troiano MF, et al. Partial glossectomy for macroglossia. J Am Dent Assoc. Apr. 1971;82(4):852-7. X-1. [pmid: 5278785].
123 Aro L, Takki S, Aromaa U. Technique for difficult intubation. Br J Anaesth. Nov. 1971;43(11):1081-3. X-1. [pmid: 5131462].
124 Bell RC. A child with two tongues (oral-facial-digital syndrome). Br J Plast Surg. Apr. 1971;24(2):193-6. X-1. [pmid: 5581758].
125 Birch JR, Lindsay WK. An evaluation of adults with repaired bilateral cleft lips and palates. Plast Reconstr Surg. Nov. 1971;48(5):457-65. X-1. [pmid: 4941137].
126 Char F, Hansen FC. Frontonasal dysplasia with cutis aplasia congenita. Birth Defects Orig Artic Ser. Jun. 1971;7(8):265-6. X-1. [pmid: 5173279].
127 Cohen MM Jr., Pantke H, Siris E. Nosologic and genetic considerations in the aglossy-adactyly syndrome. Birth Defects Orig Artic Ser. Jun. 1971;7(7):237-40. X-1. [pmid: 5173210].
128 Dougrty HL. Intraoral soft tissue problems in orthodontic practice. J Am Dent Assoc. Apr. 1971;82(4):841-51. X-1. [pmid: 5278784].
129 Fleming JP. Improvement of the face in Crouzon's disease by conservative operations. Plast Reconstr Surg. Jun. 1971;47(6):560-4. X-1. [pmid: 4932580].
130 Guernsey LH. Preprosthetic surgery. Dent Clin North Am. Apr. 1971;15(2):455-86. X-1. [pmid: 4926803].
131 Guerrero-Santos J, Ramirez M, Castaneda A, et al. Crossed-denuded flap as a complement to the Millard technique in the correction of cleft lip. Plast Reconstr Surg. Nov. 1971;48(5):506-8. X-1. [pmid: 5120485].
132 Gupta OP. Congenital macroglossia. Arch Otolaryngol. Apr. 1971;93(4):378-83. X-1. [pmid: 5548986].
133 Herremans EL. Anterior diastema: frenectomy. Dent Surv. Feb. 1971;47(2):33-7. X-1. [pmid: 5279756].
134 Heycock MH. Beckwith's syndrome. Br J Plast Surg. Oct. 1971;24(4):414-6. X-1. [pmid: 5115046].
135 Hoffman S. Congenital lip sinuses: hereditary aspects and their relationship to cleft lip and palate. Br J Plast Surg. Jul. 1971;24(3):241-6. X-1. [pmid: 5568625].
136 Lentrodt J, Luhr HG. Reconstruction of the lower lip after tumor resection combined with radical neck dissection. Plast Reconstr Surg. Dec. 1971;48(6):579-83. X-1. [pmid: 5141276].
137 Michaels DL, Go S, Humbert JR, et al. Intestinal nodular lymphoid hyperplasia, hypogammaglobulinemia, and hematologic abnormalities in a child with a ring 18 chromosome. J Pediatr. Jul. 1971;79(1):80-8. X-1. [pmid: 5091271].
138 Miller EL. Preprosthetic surgery from the viewpoint of the prosthodontist. J Oral Surg. Nov. 1971;29(11):760-7. X-1. [pmid: 4939870].
139 Palubis JE, Scott CI Jr. Lip pits with cleft lip and palate. Birth Defects Orig Artic Ser. Jun. 1971;7(7):254-7. X-1. [pmid: 5173212].
140 Potdar GG, Desai PB. Carcinoma of the lingual thyroid. Laryngoscope. Mar. 1971;81(3):427-9. X-1. [pmid: 4251886].
141 Rosenfeld PA, Gupta OP. Macroglossia. Arch Otolaryngol. Oct. 1971;94(4):381-2. X-1. [pmid: 4255570].
142 Sharpe C. Congenital lip sinuses. Case reports. Plast Reconstr Surg. Jan. 1971;47(1):85-6. X-1. [pmid: 5538570].
143 Spielman WR, Marano PD, Kolodny SC, et al. True hemifacial hypertrophy: report of case. J Oral Surg. Aug. 1971;29(8):592-5. X-1. [pmid: 5284048].
144 Summitt RL, Hiatt RL, Duenas D, et al. Mesoectodermal dysplasia of the iris and cornea, mental retardation and myopathy: a sporadic case. Birth Defects Orig Artic Ser. Mar. 1971;7(3):129-35. X-1. [pmid: 5006137].
145 Tan KL, Wong TT, Ong ES, et al. Congenital lip pits with cleft lip or palate. J Singapore Paediatr Soc. Oct. 1971;13(2):75-8. X-1. [pmid: 5149808].
146 Tessier P. The definitive plastic surgical treatment of the severe facial deformities of craniofacial dysostosis. Crouzon's and Apert's diseases. Plast Reconstr Surg. Nov. 1971;48(5):419-42. X-1. [pmid: 4942075].
147 Verne D. Surgical treatment of common abnormalities in relation to oral prosthesis. J Oral Surg. Nov. 1971;29(11):768-76. X-1. [pmid: 4939871].
148 Wei SH, Pal GS. Oral d dental abnormalities in mongolism (Down's Syndrome). J Iowa Med Soc. Jan. 1971;61(1):31-6. X-1. [pmid: 4249961].
149 Welch JP, Penchaszadeh VB, Goldberg MF. Congenital indifference to pain. Birth Defects Orig Artic Ser. Feb. 1971;7(1):205-10. X-1. [pmid: 4141908].
150 Zallen RD. Congenital lip sinuses of the lower lip: report of case. J Oral Surg. Oct. 1971;29(10):732-3. X-1. [pmid: 5285833].
151 Abramovich A. Cleft palate in the fetuses of lathyric rats and its relation to other structures: nasal septum, tongue and mandible. Cleft Palate J. Jan. 1972;9(1):73-83. X-1. [pmid: 4500298].
152 Bowers DG. Surgical repair of congenital lower lip sinuses. Plast Reconstr Surg. Jun. 1972;49(6):632-6. X-1. [pmid: 5027418].
153 Caronni EP. A new method to correct the nasolabial angle in rhinoplasty. Plast Reconstr Surg. Oct. 1972;50(4):338-40. X-1. [pmid: 5074933].
154 Cosman B, Crikelair GF. Mandibular hypoplasia and the late development of glossopharyngeal airway obstruction. Plast Reconstr Surg. Dec. 1972;50(6):573-9. X-1. [pmid: 4636491].
155 Downs MP, Silver HK. The “A.B.C.D's” to H.E.A.R. Early identification in nursery, office and clinic of the infant who is deaf. Clin Pediatr (Phila). Oct. 1972;11(10):563-6. X-1. [pmid: 5078530].
156 Fernandes CT, Wapnick S. Exomphalos and Beckwith syndrome. Cent Afr J Med. Dec. 1972;18(12):247-8. X-1. [pmid: 4655843].
157 Ginsberg SP, Polack FM, Ravin MB, et al. Autonomic dysfunction syndrome. Am J Ophthalmol. Dec. 1972;74(6):1121-5. X-1. [pmid: 4646716].
158 Grunt JA, Enriquez AR. Further studies of the hypoglycemia in children with the exomphalos--macroglossia--gigantism syndrome. Yale J Biol Med. Feb. 1972;45(1):15-21. X-1. [pmid: 5015569].
159 Hartbauer RE. Speech defects associated with orofacial abnormalities. Dent Assist. Aug. 1972;41(8):15-6. X-1. [pmid: 4505287].
160 Hsieh CC. Dental diseases among the children in Chung-Shin Village and Tsaotung. Taiwan Yi Xue Hui Za Zhi. Aug. 28. 1972;71(8):537-49. X-1. [pmid: 4511944].
161 Khosla VM. Labial and lingual frenectomy. Dent Assist. Jul. 1972;41(7):22-5. X-1. [pmid: 4504995].
162 Krishnamurthy GT, Blahd WH. Lingual thyroid associated with Zenker's and vallecular diverticula. Report of a case and review of the literature. Arch Otolaryngol. Aug. 1972;96(2):171-5. X-1. [pmid: 4628257].
163 Lawson RS. Lingual thyroid: behaviour after transplantation. Aust N Z J Surg. Feb. 1972;41(3):247-9. X-1. [pmid: 4501634].
164 Massey WR. Closure of maxillary midline diastema with frenectomy and corticotomy. J Ga Dent Assoc. Autumn. 1972;46(2):26-7. X-1. [pmid: 4511077].
165 Meinhof W, Gunther D. Treatment of chronic mucocutaneous candidiasis of children (Candida Granuloma) with Clotrimazole. Arch Dermatol Forsch. 1972;242(3):293-308. X-1. [pmid: 4337938].
166 Miller H. Lip incompetency and its treatment. N Y State Dent J. Apr. 1972;38(4):210-6. X-1. [pmid: 4501451].
167 Nash HS Jr. Benign lesions of the oral cavity. Otolaryngol Clin North Am. Jun. 1972;5(2):207-29. X-1. [pmid: 4339096].
168 Peterson A. Electrosurgical correction of maxillary double lip. Dent Dig. Apr. 1972;78(4):182-8. X-1. [pmid: 4501431].
169 Reddy JK, Schimke RN, Chang CH, et al. Beckwith-Wiedemann syndrome. Wilms' tumor, cardiac hamartoma, persistent visceromegaly, and glomeruloneogenesis in a 2-year-old boy. Arch Pathol. Dec. 1972;94(6):523-32. X-1. [pmid: 4343707].
170 Silbermann M, Moynihan FM, Maloney PL, et al. Skeletal open bite associated with bimaxillary dento-alveolar protrusion, evaluation and treatment. Br J Oral Surg. Nov. 1972;10(2):223-32. X-1. [pmid: 4509986].
171 Ursell W. Hydramnios associated with congenital microstomia agnathia and synotia. J Obstet Gynaecol Br Commonw. Feb. 1972;79(2):185-6. X-1. [pmid: 4556726].
172 NIDR at 25. J Am Dent Assoc. Jul. 1973;87(1):49-56. X-1. [pmid: 4513385].
173 Ackerman JL, Ackerman AL, Ackerman AB. A new dental, ocular and cutaneous syndrome. Int J Dermatol. Sep-Oct. 1973;12(5):285-9. X-1. [pmid: 4355828].
174 Ardran GM, Hamilton A, Kemp FH. Enlargement of the tongue and changes in the jaws with muscular dystrophy. Clin Radiol. Jul. 1973;24(3):359-64. X-1. [pmid: 4730230].
175 Bartels RJ, Howard RC. Congenital midline sinus of the upper lip. Case report. Plast Reconstr Surg. Dec. 1973;52(6):665-8. X-1. [pmid: 4759224].
176 Chaube S. Protective effects of thymidine, 5-aminoimidazolecarboxamide, and riboflavin against fetal abnormalities produced in rats by 5-(3,3-dimethyl-1-triazeno)imidazole-4-carboxamide. Cancer Res. Oct. 1973;33(10):2231-40. X-1. [pmid: 4795389].
177 Fish J. Congenital intermaxillary fibrous bands. J Dent. Feb. 1973;1(3):117-9. X-1. [pmid: 4516014].
178 Foretich EA, Cardo VA Jr., Zambito RF. Bilateral congenital absence of the submandibular duct orifices. J Oral Surg. Jul. 1973;31(7):556-7. X-1. [pmid: 4513467].
179 Gotlin RW. Diazoxide therapy in the syndrome of Beckwith-Weidemann-Coombs. J Pediatr. Aug. 1973;83(2):342-3. X-1. [pmid: 4717592].
180 Gottlieb SK, Fisher BK, Violin GA. Focal dermal hypoplasia. A nine-year follow-up study. Arch Dermatol. Oct. 1973;108(4):551-3. X-1. [pmid: 4745291].
181 Greene RJ, Gilbert EF, Huang SW, et al. Immunodeficiency associated with exomphalos-macroglossia-gigantism syndrome. J Pediatr. May. 1973;82(5):814-20. X-1. [pmid: 4540610].
182 Hayashi S, Tomioka T, Aoki H, et al. Hemifacial hypertrophy. Report of two cases. Oral Surg Oral Med Oral Pathol. Jun. 1973;35(6):750-61. X-1. [pmid: 4513644].
183 Hicks KA, Dickie WR. Amyloidosis: report of a case presenting with macroglossia. Br J Plast Surg. Jul. 1973;26(3):274-6. X-1. [pmid: 4726108].
184 Karfik V. Further development of congenital malformations influenced by surgical treatment. Acta Univ Carol Med Monogr. 1973;56:37-42. X-1. [pmid: 4791775].
185 Kaufman SL, Frederickson R. Thyroid-binding globulin deficiency in a patient with Beckwith's syndrome. Calif Med. Apr. 1973;118(4):63-6. X-1. [pmid: 4692182].
186 Kochhar DM. Limb development in mouse embryos. I. Analysis of teratogenic effects of retinoic acid. Teratology. Jun. 1973;7(3):289-95. X-1. [pmid: 4713875].
187 Olow-Nordenram M, Nordenram A. Partial tongue excision in the treatment of apertognathia. I. Oral Surg Oral Med Oral Pathol. Feb. 1973;35(2):152-9. X-1. [pmid: 4513060].
188 Papanayotou PH, Hatziotis JC. Ascher's syndrome. Report of a case. Oral Surg Oral Med Oral Pathol. Apr. 1973;35(4):467-71. X-1. [pmid: 4511796].
189 Poradowska W, Jaworska M, Dudkiewicz Z, et al. Paranasal (oro-ocular) cleft of the face. Report of a case. Acta Chir Plast. 1973;15(1):1-6. X-1. [pmid: 4126045].
190 Pruzansky S. 4th Symposium on oral sensation and perception. Concluding comment. II Symp Oral Sens Percept. 1973;(4):390-408. X-1. [pmid: 4531113].
191 Rintala A, Lahti A. On so-called median lowerlip sinuses. Case report. Scand J Plast Reconstr Surg. 1973;7(1):78-80. X-1. [pmid: 4752574].
192 Roe TF, Kershnar AK, Weitzman JJ, et al. Beckwith's syndrome with extreme organ hyperplasia. Pediatrics. Sep. 1973;52(3):372-81. X-1. [pmid: 4730394].
193 Sanger RG, Kirby JW. The oral and facial manifestations of dermatomyositis with calcinosis. Report of a case. Oral Surg Oral Med Oral Pathol. Apr. 1973;35(4):476-88. X-1. [pmid: 4511797].
194 Schiff D, Colle E, Wells D, et al. Metabolic aspects of the Beckwith-Wiedemann syndrome. J Pediatr. Feb. 1973;82(2):258-62. X-1. [pmid: 4684368].
195 Schwartz AW. Median rhomboid glossitis. Case report. Plast Reconstr Surg. Jul. 1973;52(1):91-2. X-1. [pmid: 4713826].
196 Skurnik H. Pre-prosthetic considerations--aberrant frena and muscle attachments. J Can Dent Assoc (Tor). Aug. 1973;39(8):534-6. X-1. [pmid: 4580239].
197 Watson AC. An innervated muco-muscular flap for the correction of defects of the vermilion border of the lip. Br J Plast Surg. Oct. 1973;26(4):355-8. X-1. [pmid: 4586381].
198 Wiedemann HR. E.M.G. syndrome. Lancet. Sep. 15. 1973;2(7829):626-7. X-1. [pmid: 4125428].
199 Akinosi JO. Multiple sublingual dermoid cysts. Br J Oral Surg. Nov. 1974;12(2):235-9. X-1. [pmid: 4531363].
200 Converse JM, Wood-Smith D, McCarthy JG, et al. Bilateral facial microsomia. Diagnosis, classification, treatment. Plast Reconstr Surg. Oct. 1974;54(4):413-23. X-1. [pmid: 4412188].
201 Fucci DJ, Curtis AP, Harnack MM. Oral vibrotactile stimulation: A method for monitoring change in lingual sensitivity as a function of time. Bull Psychon Soc. 1974;4(6):573-4. PMID:. X-1.
202 Hawkins DB, Simpson JV. Micrognathia and glossoptosis in the newborn. Surgical tacking of the tongue in small jaw syndromes. Clin Pediatr (Phila). Dec. 1974;13(12):1066-73. X-1. [pmid: 4215607].
203 Hornblass A, Dolan R. Oculofacial anomalies and corneal ulceration. Ann Ophthalmol. Jun. 1974;6(6):575-9. X-1. [pmid: 4209237].
204 Hussey HH. Editorial: Tongue-tie. Jama. May. 6. 1974;228(6):735. X-2. [pmid: 4406265].
205 Jorgenson RJ. M--craniocarpotarsal dystrophy (whistling face syndrome) in two families. Birth Defects Orig Artic Ser. 1974;10(5):237-42. X-1. [pmid: 4220006].
206 Kasner J, Gilbert EF, Viseskul C. Studies of malformation syndromes VID: the G syndrome. Further observations. Z Kinderheilkd. 1974;118(2):81-5. X-1. [pmid: 4440087].
207 Knudsen GE, Bang G, Kristoffersen T. Implanting of allogenic demineralized dentin in human gingival tissue. J Clin Periodontol. 1974;1(3):153-9. X-1. [pmid: 4532671].
208 McAllister RG. Macroglossia--a positional complication. Anesthesiology. Feb. 1974;40(2):199-200. X-1. [pmid: 4812721].
209 Mirko P, Miroslav S, Lubor M. Significance of the labial frenum attachment in periodontal disease in man. Part II. An attempt to determine the resistance of periodontium. J Periodontol. Dec. 1974;45(12):895-7. X-1. [pmid: 4533499].
210 Paez P, Warren WS, Srouji MN. Stridor as the presenting symptom of lingual thyroglossal duct cyst in an infant. Clin Pediatr (Phila). Dec. 1974;13(12):1077-8. X-1. [pmid: 4434667].
211 Pearlman BA. An oral contraceptive drug and gingival enlargement; the relationship between local and systemic factors. J Clin Periodontol. 1974;1(1):47-51. X-1. [pmid: 4532116].
212 Pries C, Mittelman D, Miller M, et al. The EEC syndrome. Am J Dis Child. Jun. 1974;127(6):840-4. X-1. [pmid: 4209740].
213 Schwenzer N. Rare clefts of the face. J Maxillofac Surg. Dec. 1974;2(4):224-9. X-1. [pmid: 4531472].
214 Stadelmann W. Lingua fixata. Surgery for a shortened lingual frenum. Quintessence Int Dent Dig. Oct. 1974;5(10):49-53. X-1. [pmid: 4530343].
215 Valdes-Dapena MA, Huff DS, DiGeorge AM. The association of congenital malformations and malignant tumors in infants and children. Ann Clin Lab Sci. Sep-Oct. 1974;4(5):363-71. X-1. [pmid: 4369266].
216 van Huffelen AC, Gabreels FJ, Luypen-vd Horst JS, et al. Chondrodystrophic myotonia. A report of two unrelated Dutch patients. Neuropadiatrie. Feb. 1974;5(1):71-90. X-1. [pmid: 4406232].
217 Wade AB. Periodontal recession - surgical treatment. Rev Belge Med Dent. 1974;29(3):287-98. X-1. [pmid: 4530361].
218 Ward VJ. A clinical assessment of the use of the free gingival graft for correcting localized recession associated with frenal pull. J Periodontol. Feb. 1974;45(2):78-83. X-1. [pmid: 4520963].
219 Weaver DD, Graham CB, Thomas IT, et al. A new overgrowth syndrome with accelerated skeletal maturation, unusual facies, and camptodactyly. J Pediatr. Apr. 1974;84(4):547-52. X-1. [pmid: 4366187].
220 Wertz ML. Management of undescended lingual and subhyoid thyroid glands. Laryngoscope. Apr. 1974;84(4):507-21. X-1. [pmid: 4274490].
221 Wu NF, Kushnick T. The Beckwith-Wiedemann syndrome. The exomphalos-macroglossia-gigantism syndrome. Clin Pediatr (Phila). May. 1974;13(5):452-7. X-1. [pmid: 4827141].
222 Bernick SM, Cohen DW, Baker L, et al. Dental disease in children with diabetes mellitus. J Periodontol. Apr. 1975;46(4):241-5. X-1. [pmid: 1055217].
223 Burghardt GM, Pruitt CH. Role of the tongue and senses in feeding of naive and experienced garter snakes. Physiol Behav. Feb. 1975;14(2):185-94. X-1. [pmid: 1161823].
224 Burzynski NJ, Podruch PE, Snawder K. Oral-facial-digital syndrome. A family case report. Oral Surg Oral Med Oral Pathol. May. 1975;39(5):735-41. X-1. [pmid: 1056578].
225 Cohen MM Sr. Chromosomal disorders. Dent Clin North Am. Jan. 1975;19(1):87-111. X-1. [pmid: 122818].
226 Hanson JW, Smith DW. The fetal hydantoin syndrome. J Pediatr. Aug. 1975;87(2):285-90. X-1. [pmid: 50428].
227 Hofer PA, Bergenholtz A. Oral manifestations in Urbach--Wiethe disease (lipoglycoproteinosis; lipoid proteinosis; hyalinosis cutis et mucosae). Odontol Revy. 1975;26(1):39-57. X-1. [pmid: 1054442].
228 Kaplan EN. The occult submucous cleft palate. Cleft Palate J. Oct. 1975;12:356-68. X-1. [pmid: 1058746].
229 Kirchner SG, Lee YT. Beckwith-Wiedemann syndrome. Discussion. J Tenn Med Assoc. May. 1975;68(5):389-90. X-1. [pmid: 1127937].
230 Krupp PJ, Lee FY, Bohm JW, et al. Prognostic parameters and clinical staging criteria in the epidermoid carcinoma of the vulva. Obstet Gynecol. Jul. 1975;46(1):84-8. X-1. [pmid: 1153141].
231 Leckie GB. Aplasia of the first and second branchial arches. J Laryngol Otol. Dec. 1975;89(12):1263-9. X-1. [pmid: 1214103].
232 Levin MP, Cutright DE, Bhaskar SN. Cyanoacrylate as a periodontal dressing. J Oral Med. Apr-Jun. 1975;30(2):40-3. X-1. [pmid: 1054752].
233 Mahler DM, Karev A. Lateral congenital sinus of the upper lip. Br J Plast Surg. Jul. 1975;28(3):203-4. X-1. [pmid: 1191863].
234 Monroe JB, Fahey D. Lingual thyroid. Case report and review of the literature. Arch Otolaryngol. Sep. 1975;101(9):574-6. X-1. [pmid: 1164243].
235 Samant HC, Gupta OP, Bhatia PL, et al. Congenital midline fistula of the tongue. Oral Surg Oral Med Oral Pathol. Jan. 1975;39(1):34-8. X-1. [pmid: 1053678].
236 Sensenbrenner JA, Dorst JP, Owens RP. New syndrome of skeletal, dental and hair anomalies. Birth Defects Orig Artic Ser. 1975;11(2):372-9. X-1. [pmid: 1227553].
237 Shaheen OH. Arterial epistaxis. J Laryngol Otol. Jan. 1975;89(1):17-34. X-1. [pmid: 1113029].
238 Sternlicht HC. A contiguous mucosal graft. J Periodontol. Apr. 1975;46(4):221-5. X-1. [pmid: 1055215].
239 Swift TR, Ignacio OJ, Dyken PR. Neonatal dystrophia myotonica. Electrophysiologic studies. Am J Dis Child. Jun. 1975;129(6):734-7. X-1. [pmid: 808120].
240 Tannenbaum KA. The oral aspects of mongolism. J Public Health Dent. Spring. 1975;35(2):95-108. X-1. [pmid: 123960].
241 Trice WB. Enhancing the quality of life via electrosurgery. Oral Health. Nov. 1975;65(11):13-5. X-1. [pmid: 1074123].
242 Verma IC, Goswami HL. Letter: Anterior abdominal wall defects and E.M.G. syndrome. Indian Pediatr. Apr. 1975;12(4):366. X-1. [pmid: 1158507].
243 Wald C. Myotonic dystrophy--sedative and anesthetic management. Oral Surg Oral Med Oral Pathol. Jun. 1975;39(6):886-92. X-1. [pmid: 1055975].
244 Alvarez GE. The aglossia-adactylia syndrome. Br J Plast Surg. Apr. 1976;29(2):175-8. X-1. [pmid: 1276526].
245 Hilless AD, Black JE. Lingual ectopia of the thyroid gland and autotransplantation. Br J Surg. Dec. 1976;63(12):924-6. X-1. [pmid: 1009339].
246 Hoekstra P, Wensvoort P. Cheilognathoschisis in Texel sheep. Tijdschr Diergeneeskd. Jan. 15. 1976;101(2):71-6. X-1. [pmid: 1251422].
247 Kosseff AL, Herrmann J, Gilbert EF, et al. Studies of malformation syndromes of man XXIX: the Wiedemann-Beckwith syndrome. Clinical, genetic and pathogenetic studies of 12 cases. Eur J Pediatr. Oct. 1. 1976;123(3):139-66. X-1. [pmid: 976281].
248 Lapidot A, Rezvani F, Terrefe D, et al. A new functional approach to the surgical management of Pierre Robin syndrome: experimental and clinical report. Laryngoscope. Jul. 1976;86(7):979-83. X-1. [pmid: 933693].
249 Lo Curto F, Maraschio P, Milanesi P, et al. The syndrome of partial trisomy 14q. Eur J Pediatr. Nov. 3. 1976;123(4):237-41. X-1. [pmid: 991871].
250 Olney LA. The umbilicus. Am Fam Physician. Nov. 1976;14(5):96-101. X-1. [pmid: 136182].
251 Rapin I, Ruben RJ. Patterns of anomalies in children with malformed ears. Laryngoscope. Oct. 1976;86(10):1469-502. X-1. [pmid: 966914].
252 Siegel JM, Reed WB. Cowden's syndrome report of a case with malignant melanoma. Pahlavi Med J. Apr. 1976;7(2):262-9. X-1. [pmid: 1272600].
253 Skolnik EM, Yee KF, Golden TA. Transposition of the lingual thyroid. Laryngoscope. Jun. 1976;86(6):785-91. X-1. [pmid: 933671].
254 Weintraub DM, White GE, Dines MM, et al. Intraoral findings of oculodentodigital dysplasia. ASDC J Dent Child. Nov-Dec. 1976;43(6):427-9. X-1. [pmid: 824333].
255 Williams HJ, Sane SM. Cerebro-costo-mandibular syndrome: long term follow-up of a patient and review of the literature. AJR Am J Roentgenol. Jun. 1976;126(6):1223-8. X-1. [pmid: 179385].
256 Ben-Galim E, Gross-Kieselstein E, Abrahamov A. Beckwith-Wiedemann syndrome in a mother and her son. Am J Dis Child. Jul. 1977;131(7):801-3. X-1. [pmid: 879119].
257 Brandtzaeg P, Tolo K. Mucosal penetrability enhanced by serum-derived antibodies. Nature. Mar. 17. 1977;266(5599):262-3. X-1. [pmid: 846571].
258 Canetta R. Decline in oral perception from 20 to 70 years. Percept Mot Skills. Dec. 1977;45(3 Pt 2):1028-30. X-1. [pmid: 604874].
259 Coleton SH. Mucogingival surgical procedures employed in re-establishing the integrity of the gingival unit (III). The frenectomy and the free mucosal graft. Quintessence Int Dent Dig. Jul. 1977;8(7):53-61. X-1. [pmid: 270103].
260 Cooper HK. Rehabilitation of the individual with oral-facial anomalies and communicative disorders. Oral Surg Oral Med Oral Pathol. Jun. 1977;43(6):820-6. X-1. [pmid: 266675].
261 Edwards JG. A clinical study: the diastema, the frenum, the frenectomy. Oral Health. Sep. 1977;67(9):51-62. X-1. [pmid: 351509].
262 Edwards JG. The diastema, the frenum, the frenectomy: a clinical study. Am J Orthod. May. 1977;71(5):489-508. X-1. [pmid: 266363].
263 Epker BN, Wolford LM. Reduction cheiloplasty: its role in the correction of dentofacial deformities. J Maxillofac Surg. Jun. 1977;5(2):134-41. X-1. [pmid: 267704].
264 Farman AG, van Wyk CW, Staz J, et al. Central papillary atrophy of the tongue. Oral Surg Oral Med Oral Pathol. Jan. 1977;43(1):48-58. X-1. [pmid: 264349].
265 Harris DJ, Fellows RA. The course of the cerebrocostomandibular syndrome. Birth Defects Orig Artic Ser. 1977;13(3c):117-30. X-1. [pmid: 890107].
266 Kauffman J, Hallahan DP, Ianna S. Suppression of a retardate's tongue protrusion by contingent imitation: A case study. Behav Res Ther. 1977;15(2):196-7. PMID:. X-1. [pmid: 869870].
267 Ogle RE. Preprosthetic surgery. Dent Clin North Am. Apr. 1977;21(2):219-36. X-1. [pmid: 321273].
268 Pinsky TM, Goldberg HJ. Potential for clinical cooperation between dentistry and speech pathology. Int Dent J. Dec. 1977;27(4):363-9. X-1. [pmid: 271138].
269 Popovich F, Thompson GW, Main PA. The maxillary interincisal diastema and its relationship to the superior labial frenum and intermaxillary suture. Angle Orthod. Oct. 1977;47(4):265-71. X-1. [pmid: 335923].
270 Popovich F, Thompson GW, Main PA. Persisting maxillary diastema: differential diagnosis and treatment. Dent J. Jul. 1977;43(7):330-3. X-1. [pmid: 268288].
271 Shah RM. Palatomandibular and maxillo-mandibular fusion, partial aglossia and cleft palate in a human embryo. Report of a case. Teratology. Jun. 1977;15(3):261-72. X-1. [pmid: 882915].
272 Taylor PH, Bicknell PG. Stripping of branchial fitulae. A new technique. J Laryngol Otol. Feb. 1977;91(2):141-9. X-1. [pmid: 839135].
273 Ziegler TF. A modified technique for ligating impacted canines. Am J Orthod. Dec. 1977;72(6):665-70. X-1. [pmid: 271467].
274 Balch CR. Modification of cross-lip flap. Plast Reconstr Surg. Mar. 1978;61(3):457-8. X-1. [pmid: 625504].
275 Becker A. The median diastema. Dent Clin North Am. Oct. 1978;22(4):685-710. X-1. [pmid: 359378].
276 Bruce RA. Total maxillary osteotomy for the correction of dentofacial deformities. J Mich Dent Assoc. Apr. 1978;60(4):250-8. X-1. [pmid: 277696].
277 Butler MG, Eisen JD, Henry J. Cryptophthalmos with an orbital cyst and profound mental and motor retardation. J Pediatr Ophthalmol Strabismus. Jul-Aug. 1978;15(4):233-5. X-1. [pmid: 739357].
278 Elsahy NI. Moebius syndrome associated with bilateral hypopigmentation of the areola case report. Acta Chir Plast. 1978;20(2):97-100. X-1. [pmid: 83768].
279 Gaberthuel TW, Mormann W. The angiographic tension test in mucogingival surgery. J Periodontol. Aug. 1978;49(8):395-9. X-1. [pmid: 288905].
280 Hall RK, Hyland AL. Combined surgical and orthodontic management of the oral abnormalities in children with cleidocranial dysplasia. Int J Oral Surg. Aug. 1978;7(4):267-73. X-1. [pmid: 100437].
281 Iregbulem LM. Median cleft of the lower lip: case report. Plast Reconstr Surg. May. 1978;61(5):787-9. X-2, X-2. [pmid: 643967].
282 Kelly JR, Sorenson HW, Turner EG. Prosthodontic treatment for Pierre Robin syndrome. J Prosthet Dent. May. 1978;39(5):554-60. X-1. [pmid: 274550].
283 Lavy U, Bauer CH. Pathophysiology of failure to thrive in gastrointestinal disorders. Pediatr Ann. Nov. 1978;7(11):743-9. X-1. [pmid: 740423].
284 Quayle AA. Preprosthetic surgery. Dent Update. Jun. 1978;5(4):215-23. 26. X-1. [pmid: 290535].
285 Rampp DL, Pannbacker M. Indications and contraindications for tongue thrust therapy. Lang Speech Hear Serv Sch. 1978;9(4):259-64. PMID:. X-1.
286 Rintala A, Uuspaa V. Anophthalmia and agenesis of columnella, prolabium and premaxilla without hypotelorism-a new syndrome? Case reports. Scand J Plast Reconstr Surg. 1978;12(1):69-74. X-1. [pmid: 663568].
287 Roitman A, Assa S, Laron Z. Hyperprolactinaemia in a boy with hypothyroidism due to an ectopic thyroid. Acta Paediatr Belg. Jul-Sep. 1978;31(3):155-7. X-1. [pmid: 707094].
288 Smith RG. A method of fraenectomy. J Dent. Mar. 1978;6(1):59-62. X-1. [pmid: 275293].
289 Tunnessen WW Jr., McMillan JA, Levin MB. The Coffin-Siris syndrome. Am J Dis Child. Apr. 1978;132(4):393-5. X-1. [pmid: 645658].
290 Weinstock JV, Kawanishi H. Gastrointestinal polyposis with orocutaneous hamartomas (Cowden's disease). Gastroenterology. May. 1978;74(5 Pt 1):890-5. X-1. [pmid: 640342].
291 Yang TS, Chi CC, Tsai CJ, et al. Diphenylhydantoin teratogenicity in man. Obstet Gynecol. Dec. 1978;52(6):682-4. X-1. [pmid: 733136].
292 Cohen MM Jr. Syndromology's message for craniofacial biology. J Maxillofac Surg. May. 1979;7(2):89-109. X-1. [pmid: 287758].
293 Dammacco F, Albrizio M, Pollice L. Argyrophil cells hyperplasia (apudosis) in Beckwith syndrome. Pathologica. Nov-Dec. 1979;71(1016):863-8. X-1. [pmid: 45385].
294 de Grouchy J. Which chromosomal syndromes can be managed medically. Prog Clin Biol Res. 1979;34:81-96. X-1. [pmid: 161024].
295 Elzay RP, Van Sickels JE. Oromandibular-limb hypogenesis syndrome: type II C, hypoglossia-hypodactylomelia. Oral Surg Oral Med Oral Pathol. Aug. 1979;48(2):146-9. X-1. [pmid: 289081].
296 Hand CR, Burns MO, Ireland E. Treatment of hypertonicity in muscles of lip retraction. Biofeedback Self Regul. Jun. 1979;4(2):171-81. X-1. [pmid: 476192].
297 Hoag PM. Isolated areas of gingival recession: etiology and treatment. CDS Rev. May. 1979;72(5):27-34. X-1. [pmid: 293227].
298 Kahane JC. Pathophysiological effects of Mobius syndrome on speech and hearing. Arch Otolaryngol. Jan. 1979;105(1):29-34. X-1. [pmid: 760704].
299 Kobayashi T. Congenital unilateral lower lip palsy. Acta Otolaryngol. 1979;88(3-4):303-9. X-1. [pmid: 495080].
300 Lehman J 3rd, Meister F Jr., Gerstein H. Use of a pedicle flap to correct an endodontic problem: a case report. J Endod. Oct. 1979;5(10):317-20. X-1, X-2. [pmid: 297754].
301 Mallory SB, Paradise JL. Glossoptosis revisited: on the development and resolution of airway obstruction in the Pierre Robin syndrome. Pediatrics. Dec. 1979;64(6):946-8. X-1. [pmid: 514722].
302 Meister F Jr., Campos CA, Davies EE, et al. Surgical and orthodontic correction of a problem associated with an oral habit. Quintessence Int Dent Dig. Oct. 1979;10(10):81-7. X-1. [pmid: 298778].
303 Meister F Jr., Davies EE. A frenectomy associated with a laterally positioned flap. Quintessence Int Dent Dig. Feb. 1979;10(2):65-70. X-1. [pmid: 297906].
304 Monteith GG. The partially edentulous patient with special problems. Dent Clin North Am. Jan. 1979;23(1):107-15. X-1. [pmid: 365627].
305 Nanson EM. Salivary gland drainage into the thyroglossal duct. Surg Gynecol Obstet. Aug. 1979;149(2):203-5. X-1. [pmid: 462351].
306 Nigl AJ. Electromyograph training to increase oral cavity functioning in a postoperative cancer patient. Behavior Therapy. 1979;10(3):423-7. PMID:. X-1.
307 Schwarz KB, Keating JP, Holtmann B, et al. Congenital lip pits and Hirschsprung's disease. J Pediatr Surg. Apr. 1979;14(2):162-4. X-1. [pmid: 379290].
308 Schwimmer A, Dym H, Barr C. Surgical repair of a double lip. J Am Dent Assoc. Dec. 1979;99(6):993-4. X-1. [pmid: 291660].
309 Stephens AP. Midline fracture of complete dentures. Miss Dent Assoc J. Fall. 1979;35(3):28-9. X-1. [pmid: 398440].
310 Stickel FR, Chisholm TC, Benson DD. Advances in oral-facial deformity reconstruction. Minn Med. Jun. 1979;62(6):405-9. X-1. [pmid: 386070].
311 Thompson GA, Iwata BA, Poynter H. Operant control of pathological tongue thrust in spastic cerebral palsy. J Appl Behav Anal. 1979;12(3):325-33. PMID:. X-1. [pmid: 511801].
312 Vaitiekaitis AS, Hornstein L, Neale HW. A new surgical procedure for correction of lip deformity in cranio-carpo-tarsal dysplasia (whistling face syndrome). J Oral Surg. Sep. 1979;37(9):669-72. X-1. [pmid: 288890].
313 Vecchione TR. Reconstruction of the oral mucocutaneous junction. Plast Reconstr Surg. Mar. 1979;63(3):430-2. X-1. [pmid: 368844].
314 Velcek FT, Klotz DH, Hill CH, et al. Tongue lesions in children. J Pediatr Surg. Jun. 1979;14(3):238-46. X-1. [pmid: 480086].
315 Aketa J, Nodai T, Kuga Y, et al. A method for the repair of transverse facial clefts. Cleft Palate J. Jul. 1980;17(3):245-8. X-1. [pmid: 6930998].
316 AM GE. Mucogingival problems and the movement of mandibular incisors: a clinical review. Am J Orthod. Nov. 1980;78(5):511-27. X-1. [pmid: 6933858].
317 Block CH, Siegel A, Edinger H. Effects of Amygdaloid Stimulation Upon Trigeminal Sensory Fields of the Lip That Are Established during Hypothalamically-Elicited Quiet Biting Attack in the Cat. Brain Res. 1980;197(1):39-55. PMID:. X-1. [pmid: 6249460].
318 Flores F, Cabeza A, Alvarez R, et al. Lingual thyroid: a report of two cases. Its diagnosis and treatment. Rev Invest Clin. Apr-Jun. 1980;32(2):213-8. X-1. [pmid: 7423079].
319 Gallagher DM, Hyler RL, Epker BN. Hemifacial microsomia: an anesthetic airway problem. Oral Surg Oral Med Oral Pathol. 1980;49(1):2-4. X-1. [pmid: 6927938].
320 Ilic D. Dysostosis cleido-cranialis. Protet Stomatol. Jul-Oct. 1980;30(4-5):293-8. X-1. [pmid: 6942447].
321 Janku P, Robinow M, Kelly T, et al. The van der Woude syndrome in a large kindred: variability, penetrance, genetic risks. Am J Med Genet. 1980;5(2):117-23. X-1. [pmid: 7395906].
322 Miller CJ, Smith JM. Midline sinus of the upper lip and a theory concerning etiology. Plast Reconstr Surg. May. 1980;65(5):674-5. X-1. [pmid: 7367511].
323 Namba K, Abe M, Narasaki Y, et al. Problems and reconstruction of “dish face” deformity due to cleft lip and palate. Ann Plast Surg. Jul. 1980;5(1):7-16. X-1. [pmid: 7425498].
324 Nevin NC, Kernohan DC, Ross AM. Ankyloglossum superius syndrome. Oral Surg Oral Med Oral Pathol. Sep. 1980;50(3):254-6. X-1. [pmid: 6932000].
325 Pauli RM, Hall JG. Lip pits, cleft lip and/or palate, and congenital heart disease. Am J Dis Child. Mar. 1980;134(3):293-5. X-1. [pmid: 7361737].
326 Shaw WC, Simpson JP. Oral adhesions associated with cleft lip and palate and lip fistulae. Cleft Palate J. Apr. 1980;17(2):127-31. X-1. [pmid: 6929230].
327 Sherman JE, Goulian D. The successful one-stage surgical management of a midline cleft of the lower lip, mandible, and tongue. Plast Reconstr Surg. Nov. 1980;66(5):756-9. X-1. [pmid: 7433558].
328 Tank ES, Kay R. Neoplasms associated with hemihypertophy, Beckwith-Wiedemann syndrome and aniridia. J Urol. Aug. 1980;124(2):266-8. X-1. [pmid: 6249939].
329 Chapparo CJ, Yerxa EJ, Nelson JG. Incidence of sensory integrative dysfunction among children with orofacial cleft. Am J Occup Ther. 1981;35:96-100. PMID:. X-1. [pmid: 7223831].
330 Fischer TJ, Psaltis GL. The diastema and the abnormal frenum. ASDC J Dent Child. Jul-Aug. 1981;48(4):264-8. X-1. [pmid: 6944323].
331 Hemminki K, Mutanen P, Saloniemi I, et al. Congenital malformations and maternal occupation in Finland: multivariate analysis. J Epidemiol Community Health. Mar. 1981;35(1):5-10. X-1. [pmid: 7264533].
332 Kuroda T, Ohyama K. Hypoglossia: case report and discussion. Am J Orthod. Jan. 1981;79(1):86-94. X-1. [pmid: 6935975].
333 May M, Fria TJ, Blumenthal F, et al. Facial paralysis in children: differential diagnosis. Otolaryngol Head Neck Surg. Sep-Oct. 1981;89(5):841-8. X-1. [pmid: 6799919].
334 Meister F Jr., Van Swol RL, Rank DF. The maxillary anterior frenectomy. J Wis Dent Assoc. Mar. 1981;57(3):205-10. X-1. [pmid: 6939905].
335 Nara T. Reconstruction of an upper lip and the coloboma in the nasal ala accompanying with Freeman-Sheldon syndrome. Nihon Geka Hokan. Jul. 1. 1981;50(4):626-32. X-1. [pmid: 7316645].
336 Parnes EI, Neto CG, Silva Y. Midline cleft of the lower lip and mandible: report of a case. J Oral Surg. Dec. 1981;39(12):958-60. X-1. [pmid: 6948098].
337 Rintala AE, Ranta R. Lower lip sinuses: I. Epidemiology, microforms and transverse sulci. Br J Plast Surg. Jan. 1981;34(1):26-30. X-1. [pmid: 7459520].
338 Sher MR. Surgical correction of the diastema. N Y State Dent J. Aug-Sep. 1981;47(7):382-3. X-1. [pmid: 6943466].
339 Steiner M, Clark TJ. Crainiofacial anomalies - the dentist's role. J Ky Dent Assoc. Mar. 1981;33(2):14-8. X-1. [pmid: 6939766].
340 Timms DJ, Vero D. The relationship of rapid maxillary expansion to surgery with special reference to midpalatal synostosis. Br J Oral Surg. Sep. 1981;19(3):180-96. X-1. [pmid: 7025886].
341 Carey JC, Fineman RM, Ziter FA. The Robin sequence as a consequence of malformation, dysplasia, and neuromuscular syndromes. J Pediatr. Nov. 1982;101(5):858-64. X-1. [pmid: 7131178].
342 Freedman AL, Stein MD, Schneider DB. A modified maxillary labial frenectomy. Quintessence Int Dent Dig. Jun. 1982;13(6):675-8. X-1. [pmid: 6957907].
343 Kent K, Schaaf NG. The effects of dental abnormalities on speech production. Quintessence Int Dent Dig. Dec. 1982;13(12):1353-62. X-1. [pmid: 6961475].
344 Mahler D, Baruchin A. Double lower lip. Ann Plast Surg. Mar. 1982;8(3):248-9. X-1. [pmid: 7103378].
345 Milles M, Gold B, Berger J. Cheiloplasty using Michel clips. Oral Surg Oral Med Oral Pathol. Aug. 1982;54(2):154-6. X-1. [pmid: 6956834].
346 Noordhoff MS, Cheng WS. Median facial dysgenesis in cleft lip and palate. Ann Plast Surg. Jan. 1982;8(1):83-92. X-1. [pmid: 7073197].
347 Oringer MJ. Broader horizons and indications for use of electrosurgery in oral surgery. Dent Clin North Am. Oct. 1982;26(4):729-44. X-2, X-2. [pmid: 6958596].
348 Parsons RW, Smith DJ. Rule of thumb criteria for tongue-lip adhesion in Pierre Robin anomalad. Plast Reconstr Surg. Aug. 1982;70(2):210-12. X-1. [pmid: 7100310].
349 Peterson A. The use of electrosurgery in reconstructive and cosmetic maxillofacial surgery. Dent Clin North Am. Oct. 1982;26(4):799-823. X-1. [pmid: 6958599].
350 Powell RN, McEniery TM. A longitudinal study of isolated gingival recession in the mandibular central incisor region of children aged 6-8 years. J Clin Periodontol. Sep. 1982;9(5):357-64. X-1. [pmid: 6958683].
351 Ranta R, Rintala A. Tooth anomalies associated with congenital sinuses of the lower lip and cleft lip/palate. Angle Orthod. Jul. 1982;52(3):212-21. X-1. [pmid: 6959547].
352 Scott EA. Surgery of the oral cavity. Vet Clin North Am Large Anim Pract. May. 1982;4(1):3-31. X-1. [pmid: 7101691].
353 Sonis AL, Musselman RJ. Oral bleeding in classic hemophilia. Oral Surg Oral Med Oral Pathol. Apr. 1982;53(4):363-6. X-1. [pmid: 6979022].
354 Wynne JM, Fraser AG, Herman R. Massive oral membrane in the popliteal web syndrome. J Pediatr Surg. Feb. 1982;17(1):59-60. X-1. [pmid: 7077478].
355 Azmy AF, Raine PA, Young DG. Orofacial clefts and oesophageal atresia. Arch Dis Child. Aug. 1983;58(8):639-41. X-1. [pmid: 6614982].
356 Benveniste D. The archetypal image of the mouth and its relation to autism. The Arts in Psychotherapy. 1983;10(2):99-112. PMID:. X-1.
357 Dummett CO Jr. The dentist and the dentition. Birth Defects Orig Artic Ser. 1983;19(1):3-12. X-1. [pmid: 6661524].
358 Hersh JH, Graham JM Jr., Destrempes MM, et al. Teschler-Nicola/Killian syndrome: a case report. J Clin Dysmorphol. Fall. 1983;1(3):20-4. X-1. [pmid: 6584558].
359 Hosokawa K, Susuki T, Kikui TA, et al. A congenital lateral sinus in the upper lip. Ann Plast Surg. Jul. 1983;11(1):69-70. X-1. [pmid: 6614756].
360 Kinirons MJ. Oral aspects of Rubenstein--Taybi syndrome. Br Dent J. Jan. 22. 1983;154(2):46-7. X-1. [pmid: 6572061].
361 Kurppa K, Holmberg PC, Hernberg S, et al. Screening for occupational exposures and congenital malformations. Scand J Work Environ Health. Apr. 1983;9(2 Spec No):89-93. X-1. [pmid: 6648425].
362 Mickleson KN. Developmental delay, cupid's bow of the upper lip, short great toes, and skull abnormalities. J Clin Dysmorphol. Winter. 1983;1(4):21-3. X-1. [pmid: 6590785].
363 Morishita M, Shiba R, Chiyo H, et al. The oral manifestations of 4p- syndrome. J Oral Maxillofac Surg. Sep. 1983;41(9):601-5. X-1. [pmid: 6577152].
364 Pagon RA. Teschler-Nicola/Killian syndrome. J Clin Dysmorphol. Fall. 1983;1(3):18-9. X-1. [pmid: 6584556].
365 Peterka M, Jelinek R. Origin of hydrocortisone induced orofacial clefts in the chick embryo. Cleft Palate J. Jan. 1983;20(1):35-46. X-1. [pmid: 6572574].
366 Ranta R, Rintala AE. The Pierre Robin anomalad--comparisons of some disturbances in the formation of the teeth and the lower lip. Proc Finn Dent Soc. 1983;79(4):155-61. X-1. [pmid: 6664980].
367 Theogaraj SD, Hoehn JG, Hagan KF. Practical management of congenital choanal atresia. Plast Reconstr Surg. Nov. 1983;72(5):634-42. X-1. [pmid: 6622570].
368 Young LD, Vogel V. The use of cueing and positive practice in the treatment of tongue thrust swallowing. J Behav Ther Exp Psychiatry. 1983;14(1):73-7. PMID:. X-1. [pmid: 6863556].
369 Anderman II. Pediatric dental electrosurgery. N Y State Dent. Jun-Jul. 1984;50(6):348-50. X-1. [pmid: 6589554].
370 Beukelman F, Rogers JJ. Noncontingent use of alum in the reduction of rumination. Psychol Sch. 1984;21(4):500-3. PMID:. X-1.
371 Christian JM, Goldberg MH, Sturman G, et al. Orthodontic-surgical treatment of micrognathia associated with hypoglossia-hypodactylomelia syndrome. J Conn State Dent Assoc. Jul-Aug. 1984;58(3):156-9. X-1. [pmid: 6432867].
372 Hartzband PI, Diehl DL, Lewin KJ, et al. Histological characterization of a lingual mass using thyroglobulin immunoperoxidase staining. J Endocrinol Invest. Jun. 1984;7(3):221-3. X-1. [pmid: 6381584].
373 Kaku T. Functional differentiation of hypoglossal motoneurons during the amygdaloid or cortically induced rhythmical jaw and tongue movements in the rat. Brain Res Bull. Jul. 1984;13(1):147-54. X-1. [pmid: 6478262].
374 Kamogashira K, Itoh T, Nakagawa M, et al. Orthodontic findings in a case of Beckwith-Wiedemann syndrome. Nihon Kyosei Shika Gakkai Zasshi. Dec. 1984;43(4):564-72. X-1. [pmid: 6597842].
375 Leck GD, Aird JC. An incomplete form of the popliteal pterygium syndrome?. Br Dent J. Nov. 10. 1984;157(9):318-9. X-1. [pmid: 6595011].
376 Pruszewicz A, Kruk-Zagajewska A. Phoniatric disturbances in patients after partial tongue resection for malignant neoplasms. Folia Phoniatr. 1984;36(2):84-92. PMID:. X-1.
377 Sadeghi EM, Van Swol RL, Eslami A. Histologic analysis of the hyperplastic maxillary anterior frenum. J Oral Maxillofac Surg. Dec. 1984;42(12):765-70. X-1. [pmid: 6594470].
378 Schneider PE, Sheridan J, Gardiner JF. Orthodontic headgear to control hemorrhage. ASDC J Dent Child. Jul-Aug. 1984;51(4):295-7. X-1. [pmid: 6381564].
379 Swenson HM. ABC's periodontics. “F” is for the frenum. J Indiana Dent Assoc. May-Jun. 1984;63(3):27-8. X-1. [pmid: 6590645].
380 Sydney SB. Periodontics and von Willebrand's disease, the team approach: a case report. J Md State Dent Assoc. Apr. 1984;27(1):13-5. X-1. [pmid: 6610017].
381 Urade M, Tofani I, Igarashi T, et al. Congenital midline sinus of the upper lip: report of a case. J Osaka Univ Dent Sch. Dec. 1984;24:59-65. X-1. [pmid: 6597304].
382 Wittkampf AR, van Limborgh J. Duplication of structures around the stomatodeum. J Maxillofac Surg. Feb. 1984;12(1):17-20. X-1. [pmid: 6583291].
383 Young LD, Wiedel TC, Vogel V. Cueing and positive practice as a self-control procedure: Applications to tongue thrust swallowing. Scandinavian Journal of Behaviour Therapy. 1984;13(4):191-202. PMID:. X-1.
384 Ashrafi MH, Meister F Jr., Meister RC. Mucogingival problems in children: three surgical techniques. Gen Dent. Sep-Oct. 1985;33(5):425-8. X-1. [pmid: 3865861].
385 Banks P. The orthodontic-oral surgery interface: 1. Dentoalveolar procedures. Dent Update. Sep. 1985;12(8):469-72. 74. 76 passim. X-1. [pmid: 3864699].
386 Bishara SE, Wilson LF, Perez PT, et al. Dentofacial findings in a child with unrepaired median cleft of the lip at 4 years of age. Am J Orthod. Aug. 1985;88(2):157-62. X-1. [pmid: 3861101].
387 Bixler D, Ward R, Gale DD. Agnathia-holoprosencephaly: a developmental field complex involving face and brain. Report of 3 cases. J Craniofac Genet Dev Biol Suppl. 1985;1:241-9. X-1. [pmid: 3932506].
388 Bolsin SN, Gillbe C. Opitz-Frias syndrome. A case with potentially hazardous anaesthetic implications. Anaesthesia. Dec. 1985;40(12):1189-93. X-1. [pmid: 4083447].
389 Bone RC, Fox RI, Howell FV, et al. Sjogren's syndrome: a persistent clinical problem. Laryngoscope. Mar. 1985;95(3):295-9. X-1. [pmid: 3974380].
390 Boraz RA, Hiebert JM, Thomas M. Congenital micrognathia and microglossia: an experimental approach to treatment. ASDC J Dent Child. Jan-Feb. 1985;52(1):62-4. X-1. [pmid: 3856593].
391 Broder H, Trier WC. Effectiveness of genetic counseling for families with craniofacial anomalies. Cleft Palate J. Jul. 1985;22(3):157-62. X-1. [pmid: 3860309].
392 Burdick AB, Bixler D, Puckett CL. Genetic analysis in families with van der Woude syndrome. J Craniofac Genet Dev Biol. 1985;5(2):181-208. X-1. [pmid: 4019732].
393 Chicarilli ZN, Polayes IM. Oromandibular limb hypogenesis syndromes. Plast Reconstr Surg. Jul. 1985;76(1):13-24. X-1. [pmid: 4011767].
394 de Escobar DM. Case report: Correction of ankyloglossia (“tongue-tie”) using hypnosis as sole method of anesthesia. Medical Hypnoanalysis. 1985;6(1-2):33-4. PMID:. X-1.
395 Duvie SO. Thyroglossal cysts and sinuses in Ilesa, Nigeria--a 20 year experience. Trop Geogr Med. Mar. 1985;37(1):47-50. X-1. [pmid: 4012850].
396 Georgiev E, Tzantcheva M. Craniocarpotarsal dystrophy--two case reports. Acta Chir Plast. 1985;27(3):152-9. X-1. [pmid: 3933233].
397 Miller PD Jr. The frenectomy combined with a laterally positioned pedicle graft. Functional and esthetic considerations. J Periodontol. Feb. 1985;56(2):102-6. X-1. [pmid: 3856653].
398 Nakamura J, Tomonari H, Goto S. True median cleft of the upper lip associated with three pedunculated club-shaped skin masses. Plast Reconstr Surg. May. 1985;75(5):727-31. X-1. [pmid: 3983280].
399 Ord RA, Sowray JH. Congenital lip pits and facial clefts. Br J Oral Maxillofac Surg. Dec. 1985;23(6):391-7. X-1. [pmid: 2933058].
400 Pollock RA, Newman MH, Burdi AR, et al. Congenital hemifacial hyperplasia: an embryologic hypothesis and case report. Cleft Palate J. Jul. 1985;22(3):173-84. X-1. [pmid: 3860311].
401 Precious DS, Jensen GM, McFadden LR. Correction of dentofacial deformities in children and adolescent patients. Int J Oral Surg. Oct. 1985;14(5):399-407. X-1. [pmid: 3932233].
402 Simpson JR, Maves MD. Congenital syngnathia or fusion of the gums and jaws. Otolaryngol Head Neck Surg. Feb. 1985;93(1):96-9. X-1. [pmid: 3920632].
403 Spedicato FS, Di Comite A, Tohidast-Akrad M. An unusual variant chromosome 9 with an extra C-negative, G-dark segment in the short arm. Clin Genet. Aug. 1985;28(2):162-5. X-1. [pmid: 4042399].
404 Superneau DW, Wertelecki W. Similarity of effects--experimental hyperthermia as a teratogen and maternal febrile illness associated with oromandibular and limb defects. Am J Med Genet. Jul. 1985;21(3):575-80. X-1. [pmid: 4025389].
405 Webster RC, Smith RC, Kazda G. Columella-labial changes in solution of rhinoplastic problems. Laryngoscope. Jun. 1985;95(6):629-43. X-1. [pmid: 3999896].
406 Burdick AB. Genetic epidemiology and control of genetic expression in van der Woude syndrome. J Craniofac Genet Dev Biol Suppl. 1986;2:99-105. X-1. [pmid: 3491128].
407 Cheney ML, Cheney WR, LeJeune FE Jr. Familial incidence of labial pits. Am J Otolaryngol. Jul-Aug. 1986;7(4):311-3. X-1. [pmid: 3752391].
408 Ellis MP. Oral habits--a behavioural approach. Br J Psychiatry. Jun. 1986;148:751-2. X-1. [pmid: 3779263].
409 Harris GM. Hypnotherapy for chronic tongue sucking: a case study. Am J Clin Hypn. Apr. 1986;28(4):233-7. X-1. [pmid: 3521253].
410 Herold HZ, Shmueli G, Baruchin AM. Popliteal pterygium syndrome. Clin Orthop Relat Res. Aug. 1986;(209):194-7. X-1. [pmid: 3731594].
411 Huang IY, Shieh TY. Unilaterally congenital dimple of the upper lip--a case study. Gaoxiong Yi Xue Ke Xue Za Zhi. Apr. 1986;2(4):277-81. X-1. [pmid: 3482894].
412 Zalzal GH, Bratcher GO, Cotton RT. Subglossopalatal membrane. Arch Otolaryngol Head Neck Surg. Oct. 1986;112(10):1101-3. X-1. [pmid: 3755983].
413 Addy M, Dummer PM, Hunter ML, et al. A study of the association of fraenal attachment, lip coverage, and vestibular depth with plaque and gingivitis. J Periodontol. Nov. 1987;58(11):752-7. X-1. [pmid: 3480348].
414 Darwish S, Sastry KA, Ruprecht A. Natal teeth, bifid tongue and deaf mutism. J Oral Med. Jan-Mar. 1987;42(1):49-56. X-1. [pmid: 3469352].
415 Dippenaar AP. The maxillary labial frenum and frenoplasty: a review and case report. J Dent Assoc S Afr. Nov. 1987;42(11):675-8. X-1. [pmid: 3267962].
416 Holmstrom H. The Abbe island flap for the correction of whistle deformity. Br J Plast Surg. Mar. 1987;40(2):176-80. X-1. [pmid: 3567451].
417 Horton SV. Reduction of maladaptive mouthing behavior by facial screening. J Behav Ther Exp Psychiatry. Jun. 1987;18(2):185-90. X-1. [pmid: 3611388].
418 Ophir D, Lifschitz B, Mogilner BM. Congenital granular cell tumor of the tongue. Head Neck Surg. Mar-Apr. 1987;9(4):250-2. X-1. [pmid: 3667301].
419 Parsons CL, Iacono TA, Rozner L. Effect of tongue reduction on articulation in children with Down syndrome. Am J Ment Defic. Jan. 1987;91(4):328-32. X-1. [pmid: 2949616].
420 Purdy AH, Deitz JC, Harris SR. Efficacy of two treatment approaches to reduce tongue protrusion of children with Down syndrome. Dev Med Child Neurol. Aug. 1987;29(4):469-76. X-1. [pmid: 2960579].
421 Rakocz M, Frand M, Brand N. Familial dysautonomia with Riga-Fede's disease: report of case. ASDC J Dent Child. Jan-Feb. 1987;54(1):57-9. X-1. [pmid: 3468143].
422 Calderon S, Garlick JA. Surgical excision of a congenital lateral fistula of the upper lip. An intra-oral approach. J Craniomaxillofac Surg. Jan. 1988;16(1):46-8. X-1. [pmid: 3422240].
423 Caligiuri MP, Harris MJ, Jeste DV. Quantitative analyses of voluntary orofacial motor control in schizophrenia and tardive dyskinesia. Biol Psychiatry. Nov. 1988;24(7):787-800. X-1. [pmid: 2906545].
424 Chewning LC, Sullivan CJ, Bavitz JB. Congenital commissural and lower lip pits in the same patient: report of a case. J Oral Maxillofac Surg. Jun. 1988;46(6):499-501. X-1. [pmid: 3164056].
425 Clarke L, Hepworth WB, Carey JC, et al. Chondrodystrophic mice with coincidental agnathia: evidence for the tongue obstruction hypothesis in cleft palate. Teratology. Dec. 1988;38(6):565-70. X-1. [pmid: 3266374].
426 Cohen DM, Green JG, Diekmann SL. Concurrent anomalies: cheilitis glandularis and double lip. Report of a case. Oral Surg Oral Med Oral Pathol. Sep. 1988;66(3):397-9. X-1. [pmid: 3174076].
427 Fletcher SG. Speech production following partial glossectomy. J Speech Hear Disord. Aug. 1988;53(3):232-8. X-1. [pmid: 3398476].
428 Ghafari J, Clark RE, Shofer FS, et al. Dental and occlusal characteristics of children with neuromuscular disease. Am J Orthod Dentofacial Orthop. Feb. 1988;93(2):126-32. X-1. [pmid: 3422527].
429 Kazak AE, Westervelt VD, Bracikowski A, et al. A systems-oriented treatment of an adolescent with factitious lip crusting. J Adolesc Health Care. Jul. 1988;9(4):337-9. X-1. [pmid: 3417511].
430 Kuster W, Lambrecht JT. Cleft lip and palate, lower lip pits, and limb deficiency defects. J Med Genet. Aug. 1988;25(8):565-7. X-1. [pmid: 2845088].
431 Lee KY, Lore JM Jr., Perry CJ. Use of the Kirschner wire for mandibular reconstruction. Arch Otolaryngol Head Neck Surg. Jan. 1988;114(1):68-72. X-1. [pmid: 3334822].
432 Morrish EC. Compensatory articulation in a subject with total glossectomy. Br J Disord Commun. Apr. 1988;23(1):13-22. X-1. [pmid: 3245929].
433 Myers BA. Psychological misinterpretations in the diagnosis of acute dystonia. Psychosomatics. Spring. 1988;29(2):224-6. X-1. [pmid: 3368567].
434 Nambu M, Oshima Y, Kakiuchi T, et al. Cohen's syndrome with diabetes mellitus. Acta Paediatr Jpn. Feb. 1988;30(1):84-8. X-1. [pmid: 3148266].
435 Nowak AJ. Oropharyngeal lesions and their management in epidermolysis bullosa. Arch Dermatol. May. 1988;124(5):742-5. X-1. [pmid: 3364996].
436 Case-Smith J. Intervention Strategies for Promoting Feeding Skills in Infants with sensory Deficits. Occup Ther Health Care. 1989;6(2-3):129-41. X-2, X-2. [pmid: 23941484].
437 Espie CA, Freedlander E, Campsie LM, et al. Psychological distress at follow-up after major surgery for intra-oral cancer. J Psychosom Res. 1989;33(4):441-8. PMID:. X-1. [pmid: 2795516].
438 Hodgkinson DJ. Medial thighplasty, prevention of scar migration, and labial flattening. Aesthetic Plast Surg. Spring. 1989;13(2):111-4. X-1. [pmid: 2741750].
439 Horton SV. Monitoring effects of timeout: a comparative analysis of response trends across five- and two-hundred-minute time samples. Journal of the Multihandicapped Person. 1989;2(2):167-77. PMID:. X-1.
440 Kukletová M, Kuklová J, Kukleta M. Oxazepam to stomatologic patients who do not cooperate. Act Nerv Super. 1989;31(1):57-8. PMID:. X-1.
441 Lew D, Shroyer JV Jr., Unhold GP, et al. The use of tissue expanders in the reconstruction of orofacial defects secondary to congenital rubella: case report. J Oral Maxillofac Surg. Nov. 1989;47(11):1202-7. X-1. [pmid: 2809835].
442 Marco LA, Reed TF, Joshi RS, et al. Metoclopramide fails to suppress linguopharyngeal events in a rat dyskinesia model. J Neuropsychiatry Clin Neurosci. Winter. 1989;1(1):53-6. X-1. [pmid: 2535430].
443 Reddy KA, Roa AK. Congenital double lip: a review of seven cases. Plast Reconstr Surg. Sep. 1989;84(3):420-3. X-1. [pmid: 2762400].
444 Saffran E. Aphasia Therapy: Whence and Whither?. PsycCRITIQUES. 1989;34(2):190. PMID:. X-1.
445 Weiss-Lambrou R, Tétreault S, Dudley J. The relationship between oral sensation and drooling in persons with cerebral palsy. Am J Occup Ther. 1989;43(3):155-61. PMID:. X-1. [pmid: 2735376].
446 Zunt SL, Tomich CE. Oral condyloma acuminatum. J Dermatol Surg Oncol. Jun. 1989;15(6):591-4. X-1. [pmid: 2723223].
447 Akpuaka FC, Nwozo JC. Reduplication of the mouth and mandible. Plast Reconstr Surg. Nov. 1990;86(5):971-2. X-1. [pmid: 2236325].
448 Andrews VH, Hall HR. The effects of relaxation/imagery training on recurrent aphthous stomatitis: a preliminary study. Psychosom Med. Sep-Oct. 1990;52(5):526-35. X-1. [pmid: 2247558].
449 Bagatin M, Boric V. Congenital intraoral epithelial bands: report of two cases. J Oral Maxillofac Surg. Mar. 1990;48(3):309-10. X-1. [pmid: 2303941].
450 Catania JA, Cohen BD, Deeney MR. The use of labial root torque and the tie-forward technique in the treatment of maxillary skeletal retrusion and severe arch length discrepancy. Am J Orthod Dentofacial Orthop. Jul. 1990;98(1):12-8. X-1. [pmid: 2363399].
451 Cranin AN, Gallo L. Hemifacial microsomia with an edentulous mandible: forme fruste or a new syndrome?. Oral Surg Oral Med Oral Pathol. Jul. 1990;70(1):29-33. X-1. [pmid: 2371048].
452 Dolan TA, Monopoli MP, Kaurich MJ, et al. Geriatric Grand Rounds: Oral diseases in older adults. J Am Geriatr Soc. 1990;38(11):1239-50. PMID:. X-1. [pmid: 2246461].
453 Farmand M, Stohler T. The median cleft of the lower lip and mandible and its surgical correction in a donkey. Equine Vet J. Jul. 1990;22(4):298-301. X-1. [pmid: 2209530].
454 Friend GW, Harris EF, Mincer HH, et al. Oral anomalies in the neonate, by race and gender, in an urban setting. Pediatr Dent. May-Jun. 1990;12(3):157-61. X-1. [pmid: 2077490].
455 Graser GN, Rogoff GS. Overdentures for acquired and congenital anomalies: 2. Partial overdentures. Int J Prosthodont. Jul-Aug. 1990;3(4):361-7. X-1. [pmid: 2088372].
456 Hennekam RC, Van Doorne JM. Oral aspects of Rubinstein-Taybi syndrome. Am J Med Genet Suppl. 1990;6:42-7. X-1. [pmid: 2118777].
457 Hunter A. The popliteal pterygium syndrome: report of a new family and review of the literature. Am J Med Genet. Jun. 1990;36(2):196-208. X-1. [pmid: 2164325].
458 Iammatteo PA, Trombly C, Luecke L. The effect of mouth closure on drooling and speech. Am J Occup Ther. Aug. 1990;44(8):686-91. X-1. [pmid: 1698021].
459 Jackson IT, Hussain K. Craniofacial and oral manifestations of fetal alcohol syndrome. Plast Reconstr Surg. Apr. 1990;85(4):505-12. X-1. [pmid: 2315390].
460 Kenny KF, Hreha JP, Dent CD. Bilateral redundant mucosal tissue of the upper lip. J Am Dent Assoc. Feb. 1990;120(2):193-4. X-1. [pmid: 2299060].
461 Limbrock GJ, Hoyer H, Scheying H. Regulation therapy by Castillo-Morales in children with Down syndrome: primary and secondary orofacial pathology. ASDC J Dent Child. Nov-Dec. 1990;57(6):437-41. X-1. [pmid: 2147925].
462 McClean MD, Dostrovsky JO, Lee L, et al. Somatosensory neurons in human thalamus respond to speech-induced orofacial movements. Brain Res. Apr. 16. 1990;513(2):343-7. X-1. [pmid: 2350707].
463 McClean MD, Kroll RM, Loftus NS. Kinematic analysis of lip closure in stutterers' fluent speech. J Speech Hear Res. Dec. 1990;33(4):755-60. X-1. [pmid: 2273888].
464 Ogata T, Matsuo N, Nishimura G, et al. Oto-palato-digital syndrome, type II: evidence for defective intramembranous ossification. Am J Med Genet. Jun. 1990;36(2):226-31. X-1. [pmid: 2114799].
465 Pillai KG, Kamath VV, Kumar GS, et al. Persistent buccopharyngeal membrane with cleft palate. A case report. Oral Surg Oral Med Oral Pathol. Feb. 1990;69(2):164-6. X-1. [pmid: 2304741].
466 Poole AE. The school of dental medicine as a community resource. III. Craniofacial disorders team. J Conn State Dent Assoc. Spring. 1990;66(1):26-8. X-1. [pmid: 2152384].
467 Serrano S, Aneiros J, O'Valle F, et al. Squamous cell carcinoma arising on a congenital fissure of the lower lip. Dermatologica. 1990;180(3):171-3. X-1. [pmid: 2340928].
468 Silbert RR. Ease of use of disposable mouthguards during ECT. Convuls Ther. 1990;6(4):314-6. PMID:. X-1. [pmid: 11941085].
469 Waters RS, Samulack DD, Dykes RW, et al. Topographic organization of baboon primary motor cortex: face, hand, forelimb, and shoulder representation. Somatosens Mot Res. 1990;7(4):485-514. X-1. [pmid: 2291379].
470 Weckx LL, Justino DA, Guedes ZC, et al. Hypoglossia congenita. Ear Nose Throat J. Feb. 11. 1990;69(2):108-3. X-1. [pmid: 2311539].
471 Widgerow AD. Klippel-Feil anomaly, cleft palate, and bifid tongue. Ann Plast Surg. Sep. 1990;25(3):216-22. X-1. [pmid: 2241042].
472 Wood AJ, Farrington FH. Objective evaluation of an airway management appliance in infants with craniofacial anomalies. Spec Care Dentist. Jan-Feb. 1990;10(1):30-1. X-1. [pmid: 2305341].
473 Bartholdson L, Hellstrom SO, Soderberg O. A case of a double tongue. Case report. Scand J Plast Reconstr Surg Hand Surg. 1991;25(1):93-5. X-1. [pmid: 2052917].
474 Bosman LJ, Fabert JM, Pruyn JF, et al. Judging speech communication effectiveness in oral cancer patients. J Commun Disord. Feb. 1991;24(1):40-50. X-1. [pmid: 2050840].
475 Broder H, Strauss R. Psychosocial problems and referrals among oral-facial team patients. J Rehabil. Jan-Mar. 1991;57(1):31-6. PMID:. X-1.
476 Chapko MK, Syrjala KL, Bush N, et al. Development of a behavioral measure of mouth pain, nausea, and wellness for patients receiving radiation and chemotherapy. J Pain Symptom Manage. Jan. 1991;6(1):15-23. X-1. [pmid: 1988533].
477 Chowdhury SR, Roy A. Duplication of the upper lip and maxilla. Br J Plast Surg. Aug-Sep. 1991;44(6):468-9. X-1. [pmid: 1933122].
478 Ema M, Itami T, Kawasaki H. Teratogenicity of di-n-butyltin dichloride in rats. Toxicol Lett. Nov. 1991;58(3):347-56. X-1. [pmid: 1957330].
479 Epstein SR. The frenectomy: a comparison of classic versus laser technique. Pract Periodontics Aesthet Dent. Aug. 1991;3(5):27-30. X-1, X-2, X-3. [pmid: 1813039].
480 Goel S, Nayak MN, Chelvakumaran TS. Oropalatal band (maxillo-mandibular band). off. Indian J Dent Res. Jan-Jun. 1991;2(1-2):7-9. X-1. [pmid: 1820173].
481 Golan HP. Treatment of tongue thrust with hypnosis: two case histories. Am J Clin Hypn. Apr. 1991;33(4):235-40. X-1. [pmid: 2024615].
482 Gorback MS. Management of the challenging airway with the Bullard laryngoscope. J Clin Anesth. Nov-Dec. 1991;3(6):473-7. X-1. [pmid: 1760171].
483 Goto S, Tanaka S, Iizuka T. A case report of congenital aglossia. Aichi Gakuin Dent Sci. 1991;4:7-14. X-1. [pmid: 1819338].
484 Lachiewicz AM, Hoegerman SF, Holmgren G, et al. Association of the Robin sequence with the fragile X syndrome. Am J Med Genet. Dec. 1. 1991;41(3):275-8. X-1. [pmid: 1789278].
485 Limbrock GJ, Fischer-Brandies H, Avalle C. Castillo-Morales' orofacial therapy: treatment of 67 children with Down syndrome. Dev Med Child Neurol. 1991;33(4):296-303. PMID:. X-1. [pmid: 1828445].
486 McCarthy R, Palmer RM. Ridge recontouring and crown lengthening prior to bridge placement. Restorative Dent. May. 1991;7(2):40-2. X-1. [pmid: 1816602].
487 Mindikoglu AN, Erginel A, Cenani A. An unknown syndrome of nose deformity, oxycephaly, aplasia of the nasolacrimal ducts, and symmetrical cyst formation on the upper lip in siblings: craniorhiny. Plast Reconstr Surg. Oct. 1991;88(4):699-702. X-1. [pmid: 1896543].
488 O'Callaghan E, Larkin C, Kinsella A, et al. Familial, obstetric, and other clinical correlates of minor physical anomalies in schizophrenia. Am J Psychiatry. Apr. 1991;148(4):479-83. X-1. [pmid: 2006694].
489 Ohishi M, Kai S, Ozeki S, et al. Alveolar synechia, ankyloblepharon, and ectodermal disorders: an autosomal recessive disorder?. Am J Med Genet. Jan. 1991;38(1):13-5. X-1. [pmid: 2012123].
490 Ohishi M, Yamamoto K, Higuchi Y. Congenital dermoid fistula of the lower lip. Oral Surg Oral Med Oral Pathol. Feb. 1991;71(2):203-5. X-1. [pmid: 2003015].
491 Omura Y. Accurate localization of organ representation areas of the tongue, using the Bi-Digital O-Ring Test: its clinical application, and re-evaluation of classical Oriental tongue diagnosis--Part I. Acupunct Electrother Res. 1991;16(1-2):27-43. X-1. [pmid: 1674832].
492 Peacock ME, Brennan WA, Strong SL, et al. Angioedema as a complication in periodontal surgery: report of a case. J Periodontol. Oct. 1991;62(10):643-5. X-1. [pmid: 1770424].
493 Phillips WR. Video-game therapy. N Engl J Med. Oct. 24. 1991;325(17):1256-7. X-1. [pmid: 1922219].
494 Roshkind DM. Use of the Nd:YAG laser for improved periodontal cosmetics. Pract Periodontics Aesthet Dent. Apr-May. 1991;3(3):29-33. X-1. [pmid: 1868233].
495 Schwarting RK, Elstermeier F, Francke W, et al. Trigeminal-basal ganglia interaction: control of sensory-motor gating and positive reinforcement. Brain Res Bull. Feb. 1991;26(2):293-300. X-1. [pmid: 2012990].
496 Surendran N, Varghese B. Midline cleft of lower lip with cleft of the mandible and midline dermoid in the neck. J Pediatr Surg. Dec. 1991;26(12):1387-8. X-1. [pmid: 1765914].
497 Talbot TR. Review of the Swinglock removable partial denture. Int J Prosthodont. Jan-Feb. 1991;4(1):80-8. X-1. [pmid: 2012675].
498 Wright JT, Fine JD, Johnson LB. Oral soft tissues in hereditary epidermolysis bullosa. Oral Surg Oral Med Oral Pathol. Apr. 1991;71(4):440-6. X-1. [pmid: 2052329].
499 April MM, Rebeiz EE, Friedman EM, et al. Laser therapy for lymphatic malformations of the upper aerodigestive tract. An evolving experience. Arch Otolaryngol Head Neck Surg. Feb. 1992;118(2):205-8. X-1. [pmid: 1540355].
500 Asher-McDade C, Brattstrom V, Dahl E, et al. A six-center international study of treatment outcome in patients with clefts of the lip and palate: Part 4. Assessment of nasolabial appearance. Cleft Palate Craniofac J. Sep. 1992;29(5):409-12. X-1. [pmid: 1472518].
501 Chaturvedi VN, Marathe NG. Electrogustometry in oral submucous fibrosis. A study in 50 cases. Indian J Dent Res. Jul-Sep. 1992;3(3):90-3. X-1. [pmid: 1343962].
502 Elias DL, Kawamoto HK Jr., Wilson LF. Holoprosencephaly and midline facial anomalies: redefining classification and management. Plast Reconstr Surg. Dec. 1992;90(6):951-8. X-1. [pmid: 1448530].
503 Eppley BL, Sadove AM, Goldenberg J. Philtral fistula in median cleft lip: cause and effect or coincidence?. Ann Plast Surg. Sep. 1992;29(3):263-5. X-1. [pmid: 1524378].
504 Hale ST, Kellum GD, Richardson JF, et al. Oral motor control, posturing, and myofunctional variables in 8-year-olds. J Speech Hear Res. Dec. 1992;35(6):1203-8. X-1. [pmid: 1494265].
505 Honig JF. Incomplete bilateral transverse facial cleft--a previously unreported associated defect of the Kallmann's syndrome. Eur J Pediatr Surg. Dec. 1992;2(6):357-60. X-1. [pmid: 1477065].
506 Hughes-Benzie RM, Hunter AG, Allanson JE, et al. Simpson-Golabi-Behmel syndrome associated with renal dysplasia and embryonal tumor: localization of the gene to Xqcen-q21. Am J Med Genet. Apr 15-May 1. 1992;43(1-2):428-35. X-1. [pmid: 1605222].
507 Imai S, Michi K. Articulatory function after resection of the tongue and floor of the mouth: palatometric and perceptual evaluation. J Speech Hear Res. Feb. 1992;35(1):68-78. X-1. [pmid: 1735978].
508 Ishida Y, Watanabe N, Ishihara Y, et al. The 11q- syndrome with mosaic partial deletion of 11q. Acta Paediatr Jpn. Dec. 1992;34(6):592-6. X-1. [pmid: 1285504].
509 Kallestal C, Uhlin S. Buccal attachment loss in Swedish adolescents. J Clin Periodontol. Aug. 1992;19(7):485-91. X-1. [pmid: 1430284].
510 Koch H, Grzonka M, Koch J. Popliteal pterygium syndrome with special consideration of the cleft malformation: case report. Cleft Palate Craniofac J. Jan. 1992;29(1):80-4. X-1. [pmid: 1312355].
511 Lahdenne P. Late sequelae of gonadal, mediastinal and oral teratomas in childhood. Acta Paediatr. Mar. 1992;81(3):235-8. X-1. [pmid: 1511197].
512 Larralde de Luna M, Raspa ML, Ibargoyen J. Oral-facial-digital type 1 syndrome of Papillon-Leage and Psaume. Pediatr Dermatol. Mar. 1992;9(1):52-6. X-1. [pmid: 1574477].
513 Luomanen M. Experience with a carbon dioxide laser for removal of benign oral soft-tissue lesions. Proc Finn Dent Soc. 1992;88(1-2):49-55. X-1. [pmid: 1470632].
514 Mori M. Pre-prosthetic surgery. J Philipp Dent Assoc. Sep-Nov. 1992;44(2):9-17. X-1. [pmid: 1339822].
515 Noda T, Yamano T, Shimizu M, et al. Comparative teratogenicity of di-n-butyltin diacetate with n-butyltin trichloride in rats. Arch Environ Contam Toxicol. Aug. 1992;23(2):216-22. X-1. [pmid: 1514842].
516 Pick RM. Lasers and their use in dentistry. Mo Dent J. May-Jun. 1992;72(3):34-41. 3. X-1. [pmid: 1630322].
517 Rodini ES, Nardi A, Guion-Almeida ML, et al. Ectodermal dysplasia, ectrodactyly, clefting, anophthalmia/microphthalmia, and genitourinary anomalies: nosology of Goltz-Gorlin syndrome versus EEC syndrome. Am J Med Genet. Feb. 1. 1992;42(3):276-80. X-1. [pmid: 1536161].
518 Rodini ES, Richieri-Costa A. Autosomal recessive blepharoptosis, cleft lip/palate, dental anomalies, and ectrodactyly. Am J Med Genet. Feb. 1. 1992;42(3):340-2. X-1. [pmid: 1536175].
519 Sams DR, Waldo BF, Thomas JP, et al. Dental involvement of an infant with Potter syndrome: case report. J Clin Pediatr Dent. Spring. 1992;16(3):219-21. X-1. [pmid: 1525079].
520 Scheerer CR. Perspectives on an oral motor activity: The use of rubber tubing as a “chewy”. Am J Occup Ther. 1992;46(4):344-52. PMID:. X-1. [pmid: 1566800].
521 Svensson P, Bjerring P, Arendt-Nielsen L, et al. Quantitative determinations of sensory and pain thresholds on human oral mucosa by argon laser stimulation. Pain. May. 1992;49(2):233-9. X-1. [pmid: 1608647].
522 Wiersma R, Hadley GP, Bosenberg AT, et al. Intralingual cysts of foregut origin. J Pediatr Surg. Nov. 1992;27(11):1404-6. X-1. [pmid: 1479498].
523 Zanini SA, Seara S, Willhelm R, et al. Hypoglossia-hypodactyly syndrome in a Brazilian child: clinical and surgical aspects. J Craniofac Surg. Jul. 1992;3(1):33-4. X-1. [pmid: 1391247].
524 Bacino C. ROR2-Related Robinow Syndrome. Pagon RA, Adam MP, Bird TD, Dolan CR, Fong CT, Stephens K, editors. GeneReviews. Seattle (WA). University of Washington, Seattle University of Washington, Seattle. All rights reserved. 1993.
525 Burton BK, Schulz CJ, Burd LI. Spectrum of limb disruption defects associated with chorionic villus sampling. Pediatrics. May. 1993;91(5):989-93. X-1. [pmid: 8474823].
526 Chan FL, Low LC, Yeung HW, et al. Case report: lingual thyroid, a cause of neonatal stridor. Br J Radiol. May. 1993;66(785):462-4. X-1. [pmid: 8319070].
527 Freeman R. A psychotherapeutic case illustrating a psychogenic factor in Burning Mouth Syndrome (BMS). Br J Psychother. 1993;10(2):220-5. PMID:. X-1.
528 Inaba R, Maeda M, Fujita S, et al. Prevalence of Raynaud's phenomenon and specific clinical signs related to progressive systemic sclerosis in the general population of Japan. Int J Dermatol. Sep. 1993;32(9):652-5. X-1. [pmid: 8407092].
529 Krantz PJ, MacDuff MT, McClannahan LE. Programming participation in family activities for children with autism: Parents' use of photographic activity schedules. J Appl Behav Anal. 1993;26(1):137-8. X-1. [pmid: 8473254].
530 Matsuo K, Fujiwara T, Hayashi R, et al. Bilateral lateral vermilion border transposition flaps to correct the “whistling lip” deformity. Plast Reconstr Surg. Apr. 1993;91(5):930-5. X-1. [pmid: 8460197].
531 Mavili ME, Gucer T, Erk Y. Unilateral absence of the soft palate: case report of reconstruction with a mucoperiosteal island flap. Cleft Palate Craniofac J. Sep. 1993;30(5):497-9. X-1. [pmid: 8218314].
532 Mukai S, Mukai C, Asaoka K. Congenital ankyloglossia with deviation of the epiglottis and larynx: symptoms and respiratory function in adults. Ann Otol Rhinol Laryngol. Aug. 1993;102(8 Pt 1):620-4. X-3. [pmid: 8352487].
533 Mutaf M, Sensoz O, Ustuner ET. The split-lip advancement technique (SLAT) for the treatment of congenital sinuses of the lower lip. Plast Reconstr Surg. Sep. 1993;92(4):615-20. X-1. [pmid: 8356123].
534 Noda T, Morita S, Baba A. Teratogenic effects of various di-n-butyltins with different anions and butyl(3-hydroxybutyl)tin dilaurate in rats. Toxicology. Dec. 31. 1993;85(2-3):149-60. X-1. [pmid: 8303710].
535 Noordhoff MS, Huang CS, Lo LJ. Median facial dysplasia in unilateral and bilateral cleft lip and palate: a subgroup of median cerebrofacial malformations. Plast Reconstr Surg. May. 1993;91(6):996-1005. discussion 6-7. X-1. [pmid: 8480000].
536 Pauloski BR, Logemann JA, Rademaker AW, et al. Speech and swallowing function after anterior tongue and floor of mouth resection with distal flap reconstruction. J Speech Hear Res. Apr. 1993;36(2):267-76. X-1. [pmid: 8487519].
537 Perrott DH, Berger R, Vargervik K, et al. Use of a skeletal distraction device to widen the mandible: a case report. J Oral Maxillofac Surg. Apr. 1993;51(4):435-9. X-1. [pmid: 8450367].
538 Raetzke PB. The need for mucogingival surgery re-evaluated. J Pierre Fauchard Acad. Jun. 1993;7(2):55-8. X-1. [pmid: 9791271].
539 Reid DH, Parsons MB, Phillips JF, et al. Reduction of self-injurious hand mouthing using response blocking. J Appl Behav Anal. 1993;26(1):139-40. PMID:. X-1. [pmid: 8473255].
540 Saeed NR, Mackay FA. The oral surgery/orthodontic interface: 2. Local causes of malocclusion. Dent Update. Apr. 1993;20(3):101. 2. 4. X-1. [pmid: 8224341].
541 Weingarten RT, Walner DL, Holinger LD. Tongue hypoplasia in a newborn. Int J Pediatr Otorhinolaryngol. Jan. 1993;25(1-3):235-41. X-1. [pmid: 8436470].
542 Wright JT, Fine JD, Johnson LB, et al. Oral involvement of recessive dystrophic epidermolysis bullosa inversa. Am J Med Genet. Dec. 1. 1993;47(8):1184-8. X-1. [pmid: 8291553].
543 Young K, Barth CK, Moore C, et al. Otopalatodigital syndrome type II associated with omphalocele: report of three cases. Am J Med Genet. Feb. 15. 1993;45(4):481-7. X-1. [pmid: 8465856].
544 Aki FE, Besteiro JM, Ferreira MC. Reconstruction of oropharyngeal defects utilizing a free radial forearm flap. Microsurgery. 1994;15(1):14-7. X-1. [pmid: 8133763].
545 Arshad AR, Goh CS. Hypoglossia congenita with anterior maxillo-mandibular fusion. Br J Plast Surg. Mar. 1994;47(2):139-41. X-1. [pmid: 8149059].
546 Bronheim H. Psychotherapy of the otolaryngology patient. Gen Hosp Psychiatry. Mar. 1994;16(2):112-8. X-1. [pmid: 7518787].
547 Cabrera PO. The connective tissue graft with labial vestibular extension. Pract Periodontics Aesthet Dent. Jun-Jul. 1994;6(5):57-63. quiz 4. X-1. [pmid: 7994017].
548 Chindia ML, Kimaro S. Congenital lower lip pits and bilateral clefting of the upper lip. East Afr Med J. May. 1994;71(5):332-3. X-1. [pmid: 7925069].
549 Dao TT, Lavigne GJ, Charbonneau A, et al. The efficacy of oral splints in the treatment of myofascial pain of the jaw muscles: a controlled clinical trial. Pain. Jan. 1994;56(1):85-94. X-1. [pmid: 8159444].
550 Drachnik C. The tongue as a graphic symbol of sexual abuse. Art Therapy. 1994;11(1):58-61. PMID:. X-1.
551 Esclamado RM, Burkey BB, Carroll WR, et al. The platysma myocutaneous flap. Indications and caveats. Arch Otolaryngol Head Neck Surg. Jan. 1994;120(1):32-5. X-1. [pmid: 8274253].
552 Ewald DA, Roper SD. Bidirectional synaptic transmission in Necturus taste buds. J Neurosci. Jun. 1994;14(6):3791-804. X-1. [pmid: 8207488].
553 Haapanen ML. Cleft type and speech proficiency. Folia Phoniatr Logop. 1994;46(2):57-63. X-1. [pmid: 8173613].
554 Havlik RJ, Bartlett SP. Mandibular distraction lengthening in the severely hypoplastic mandible: a problematic case with tongue aplasia. J Craniofac Surg. Nov. 1994;5(5):305-10. discussion 11-2. X-1. [pmid: 7833412].
555 Hirano A, Iio Y, Murakami R, et al. Recurrent trismus: twenty-year follow-up result. Cleft Palate Craniofac J. Jul. 1994;31(4):309-12. X-1. [pmid: 7918526].
556 Israel M. Use of the CO2 laser in soft tissue and periodontal surgery. Pract Periodontics Aesthet Dent. Aug. 1994;6(6):57-64. quiz. X-1. [pmid: 7833462].
557 Lo LJ, Noordhoff MS, Chen YR. Cleft lip and hemangioma: a patient with Wolf-Hirschhorn syndrome. Ann Plast Surg. May. 1994;32(5):539-41. X-1. [pmid: 8060081].
558 Martinot VL, Manouvrier S, Anastassov Y, et al. Orodigitofacial syndromes type I and II: clinical and surgical studies. Cleft Palate Craniofac J. Sep. 1994;31(5):401-8. X-1. [pmid: 7986802].
559 Noda T, Morita S, Baba A. Enhanced teratogenic activity of di-n-butyltin diacetate by carbon tetrachloride pretreatment in rats. Food Chem Toxicol. Apr. 1994;32(4):321-7. X-1. [pmid: 8206427].
560 Rass A, Luning C, Wroblewski J, et al. Distribution of C-CAM in developing oral tissues. Anat Embryol (Berl). Sep. 1994;190(3):251-61. X-1. [pmid: 7818095].
561 Rosenberg S. Advancing your practice with dental lasers. Dent Econ. Mar. 1994;84(3):84-5. X-1. [pmid: 8612906].
562 Standoli L. Cross lip flap in vermilion reconstruction. Ann Plast Surg. Feb. 1994;32(2):214-7. X-1. [pmid: 8192375].
563 Trotman CA, McNamara T. Four maxillary incisors: a case report. Spec Care Dentist. May-Jun. 1994;14(3):112-5. X-1. [pmid: 7871471].
564 Tuysuz B, Erginel A, Unutmaz T, et al. Hypoglossia-hypodactylia (Hanhart's) syndrome with sensorineural hearing loss. Turk J Pediatr. Oct-Dec. 1994;36(4):347-52. X-1. [pmid: 7825244].
565 Valentine RL. Periodontal plastic surgery. Dent Today. Oct. 4. 6. 1994;13(10):42-9. X-1. [pmid: 9540577].
566 Wey PD, Neidich JA, Hoffman LA, et al. Midline defects of the orofaciodigital syndrome type VI (Varadi syndrome). Cleft Palate Craniofac J. Sep. 1994;31(5):397-400. X-1. [pmid: 7986801].
567 Whitby KE, Collins TF, Welsh JJ, et al. Developmental effects of combined exposure to ethanol and vitamin A. Food Chem Toxicol. Apr. 1994;32(4):305-20. X-1. [pmid: 8206426].
568 Zuniga JR, Chen N, Miller IJ Jr. Effects of chorda-lingual nerve injury and repair on human taste. Chem Senses. Dec. 1994;19(6):657-65. X-1. [pmid: 7735845].
569 Abitbol TE, Chou CT. An unusual complication following a laterally positioned flap: report of a case. Periodontal Clin Investig. Spring. 1995;17(1):17-8. X-1. [pmid: 9055696].
570 Aderriotis D. Test your diagnostic skills. The van der Woude syndrome. Univ Tor Dent J. 1995;8(2):34. 6. X-1. [pmid: 9584780].
571 Arshad AR. Incomplete midline cleft of lower lip. Cleft Palate Craniofac J. Mar. 1995;32(2):167-9. X-1. [pmid: 7748879].
572 Carvajal R, Miralles R, Ravera MJ, et al. Follow-up of electromyographic and cephalometric findings in patients with unilateral cleft lip and palate after fifteen months of continuous wearing of a special removable appliance. Cleft Palate Craniofac J. Jul. 1995;32(4):323-7. X-1. [pmid: 7548106].
573 Denny AD, Kinney T. Cleft cluster: a strategy for concurrent correction of multiple secondary clefting deformities. J Craniofac Surg. Mar. 1995;6(2):120-5. X-1. [pmid: 8601016].
574 Dohvoma C, Hutchison I, Calvert M. Labiomental intertrigo. An indication for orthognathic surgery. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. May. 1995;79(5):551-3. X-1. [pmid: 7600215].
575 Dommergues M, Lemerrer M, Couly G, et al. Prenatal diagnosis of cleft lip at 11 menstrual weeks using embryoscopy in the van der Woude syndrome. Prenat Diagn. Apr. 1995;15(4):378-81. X-1. [pmid: 7617581].
576 Ema M, Kurosaka R, Amano H, et al. Comparative developmental toxicity of butyltin trichloride, dibutyltin dichloride and tributyltin chloride in rats. J Appl Toxicol. Jul-Aug. 1995;15(4):297-302. X-1. [pmid: 7594199].
577 Goldsmith P, Soames JV, Meikle D. Leiomyomatous hamartoma of the posterior tongue: a case report. J Laryngol Otol. Dec. 1995;109(12):1190-1. X-1. [pmid: 8551154].
578 Greene PE, Peacock ME, Kudryk VL. Periodontal management of a prominent labial frenum in an adolescent with gingival overgrowth. Pediatr Dent. Jan-Feb. 1995;17(1):66-7. X-1. [pmid: 7899110].
579 Herman TE, Siegel MJ. Special imaging casebook. Median mandibular cleft. J Perinatol. Mar-Apr. 1995;15(2):163-4. X-1. [pmid: 7595780].
580 Jain E. Tongue-tie: its impact on breastfeeding. AARN News Lett. May. 1995;51(5):18. X-1. [pmid: 7668076].
581 Khalil KC, Dayal PK, Gopakumar R, et al. Aglossia: a case report. Quintessence Int. May. 1995;26(5):359-60. X-1. [pmid: 7568760].
582 Muda AO, Paradisi M, Angelo C, et al. Lipoid proteinosis: clinical, histologic, and ultrastructural investigations. Cutis. Oct. 1995;56(4):220-4. X-1. [pmid: 8575221].
583 Nurminen T, Rantala K, Kurppa K, et al. Agricultural work during pregnancy and selected structural malformations in Finland. Epidemiology. Jan. 1995;6(1):23-30. X-1. [pmid: 7888440].
584 Olivares-Pakzad BA, Tazelaar HD, Dehner LP, et al. Oropharyngeal hairy polyp with meningothelial elements. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Apr. 1995;79(4):462-8. X-1. [pmid: 7614207].
585 Rimell FL, Shapiro AM, Shoemaker DL, et al. Head and neck manifestations of Beckwith-Wiedemann syndrome. Otolaryngol Head Neck Surg. Sep. 1995;113(3):262-5. X-1. [pmid: 7675487].
586 Rosenquist BE. Median lip fissure. J Craniofac Surg. Sep. 1995;6(5):390-1. X-1. [pmid: 9020720].
587 Strome SE, McClatchey K, Kileny PR, et al. Neonatal choristoma of the tongue containing glial tissue: diagnosis and surgical considerations. Int J Pediatr Otorhinolaryngol. Nov. 1995;33(3):265-73. X-1. [pmid: 8557483].
588 Van Houdenhove B, Joostens P. Burning mouth syndrome. Successful treatment with combined psychotherapy and psychopharmacotherapy. Gen Hosp Psychiatry. Sep. 1995;17(5):385-8. X-1. [pmid: 8522154].
589 Walker PJ, Edwards MJ, Petroff V, et al. Agnathia (severe micrognathia), aglossia and choanal atresia in an infant. J Paediatr Child Health. Aug. 1995;31(4):358-61. X-1. [pmid: 7576899].
590 Will MJ, Ester MS, Ramirez SG, et al. Comparison of cephalometric analysis with ethnicity in obstructive sleep apnea syndrome. Sleep. Dec. 1995;18(10):873-5. X-1. [pmid: 8746394].
591 Yoshihara T, Oda A, Takahashi Y, et al. Fibrous hamartoma of the tongue: report of a case with immunohistochemical and ultrastructural studies. Int J Pediatr Otorhinolaryngol. Oct. 1995;33(2):171-8. X-1. [pmid: 7499050].
592 Abitbol TE, Santi E. Atypical frenum formation at the donor site after mucogingival flap surgery. Compend Contin Educ Dent. Jun. 1996;17(6):630-1. X-1. [pmid: 9051967].
593 Courtens W, Hennequin Y, Blum D, et al. CHARGE association in a neonate exposed in utero to carbon monoxide. Birth Defects Orig Artic Ser. 1996;30(1):407-12. X-1. [pmid: 9125346].
594 Crean SJ, Connor C. Congenital mucoceles: report of two cases. Int J Paediatr Dent. Dec. 1996;6(4):271-5. X-1. [pmid: 9161196].
595 Cusi V, Torrents M, Vila J, et al. Limb body wall complex: analysis of eight fetuses. Birth Defects Orig Artic Ser. 1996;30(1):165-70. X-1. [pmid: 9125325].
596 Ferguson S. Moebius syndrome: a review of the anaesthetic implications. Paediatr Anaesth. 1996;6(1):51-6. X-1. [pmid: 8839089].
597 Hattab FN, al-Khateeb T, Mansour M. Oral manifestations of severe short-limb dwarfism resembling Grebe chondrodysplasia: report of a case. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. May. 1996;81(5):550-5. X-1. [pmid: 8734701].
598 Hayes C, Werler MM, Willett WC, et al. Case-control study of periconceptional folic acid supplementation and oral clefts. Am J Epidemiol. Jun. 15. 1996;143(12):1229-34. X-1. [pmid: 8651221].
599 Inachi S, Mizutani H, Ando Y, et al. Progressive systemic sclerosis sine scleroderma which developed after exposure to epoxy resin polymerization. J Dermatol. May. 1996;23(5):344-6. X-1. [pmid: 8675826].
600 Irvine AD, Dolan OM, Hadden DR, et al. An autosomal dominant syndrome of acromegaloid facial appearance and generalised hypertrichosis terminalis. J Med Genet. Nov. 1996;33(11):972-4. X-1. [pmid: 8950682].
601 Kamata S, Satoh K, Uemura T, et al. Congenital bilateral zygomatico-mandibular fusion with mandibular hypoplasia. Br J Plast Surg. Jun. 1996;49(4):251-3. X-1. [pmid: 8757678].
602 Kinderknecht KE, Kupp LI. Aesthetic solution for large maxillary anterior diastema and frenum attachment. Pract Periodontics Aesthet Dent. Jan-Feb. 1996;8(1):95-102. quiz 4. X-1. [pmid: 9028276].
603 Kuzma PJ, Calkins MD, Kline MD, et al. The anesthetic management of patients with multiple pterygium syndrome. Anesth Analg. Aug. 1996;83(2):430-2. X-1. [pmid: 8694333].
604 McEntee JE, Parker EH, Brown MB, et al. The effects of response interruption, DRO and positive reinforcement on the reduction of hand-mouthing behavior. Behav Interv. 1996;11(3):163-70. PMID:. X-1.
605 Mole B. Lip rejuvenation using chemical abrasion and padding with expanded polytetrafluoroethylene implants. Aesthetic Plast Surg. May-Jun. 1996;20(3):235-42. X-1. [pmid: 8670390].
606 Nagahara K, Miyajima K, Nakamura S, et al. Orthodontic treatment of an open bite patient with oral-facial-digital syndrome. Am J Orthod Dentofacial Orthop. Aug. 1996;110(2):137-44. X-1. [pmid: 8760839].
607 Oostrom CA, Vermeij-Keers C, Gilbert PM, et al. Median cleft of the lower lip and mandible: case reports, a new embryologic hypothesis, and subdivision. Plast Reconstr Surg. Feb. 1996;97(2):313-20. X-1. [pmid: 8559813].
608 Preis S, Majewski F, Hantschmann R, et al. Goldenhar, Mobius and hypoglossia-hypodactyly anomalies in a patient: syndrome or association?. Eur J Pediatr. May. 1996;155(5):385-9. X-1. [pmid: 8741036].
609 Ramba J. Fixation of the tongue below mandible in Pierre Robin syndrome. Acta Chir Plast. 1996;38(2):54-6. X-1. [pmid: 8908731].
610 Shermak MA, Dufresne CR. Nonlethal case of otocephaly and its implications for treatment. J Craniofac Surg. Sep. 1996;7(5):372-5. X-1. [pmid: 9133850].
611 Sullivan TC, Turpin DL, Artun J. A postretention study of patients presenting with a maxillary median diastema. Angle Orthod. 1996;66(2):131-8. X-1. [pmid: 8712491].
612 Varela M, Ramos C. Chondroectodermal dysplasia (Ellis-van Creveld syndrome): a case report. Eur J Orthod. Aug. 1996;18(4):313-8. X-1. [pmid: 8921652].
613 Vega JB, Oziel M, Jackson IT, et al. A new design of a cross-lip vermilion flap. Ann Plast Surg. Feb. 1996;36(2):197-200. X-1. [pmid: 8919388].
614 Watanabe H, Ishikawa I, Suzuki M, et al. Clinical assessments of the erbium:YAG laser for soft tissue surgery and scaling. J Clin Laser Med Surg. Apr. 1996;14(2):67-75. X-1. [pmid: 9484078].
615 Diagnosis at a glance Test yourself: 1997 roundup. Emerg Med. 1997;29(12):15-8. 23. 4. 6 passim. PMID:. X-1, X-2, X-3.
616 Adair SM, Wray IA, Hanes CM, et al. Perceptions associated with dentists' decisions to report hypothetical cases of child maltreatment. Pediatr Dent. Nov-Dec. 1997;19(8):461-5. X-1. [pmid: 9442538].
617 Ananth J, Swartz R, Chung C, et al. Dysarthria: lonely symptom of tardive dystonia. Can J Psychiatry. May. 1997;42(4):428-9. X-1. [pmid: 9161771].
618 Beynon GJ, Thornton FL, Poole C. A randomized, controlled trial of the efficacy of a communication course for first time hearing aid users. Br J Audiol. Oct. 1997;31(5):345-51. X-1. [pmid: 9373743].
619 Bianchi F, Cianciulli D, Pierini A, et al. Congenital malformations and maternal occupation: a registry based case-control study. Occup Environ Med. Apr. 1997;54(4):223-8. X-1. [pmid: 9166126].
620 Chang HH, Kaufman MH. Transient bradycardia in a mouse model for the oromandibulofacial limb hypogenesis syndrome following chorionic villus sampling. J Hand Surg Br. Apr. 1997;22(2):243-9. X-1. [pmid: 9149998].
621 Coulam CB. Hypothesis: antiphospholipid antibodies associated with congenital anomalies?. Early Pregnancy. Jun. 1997;3(2):109-12. X-1. [pmid: 9429851].
622 de Cuebas JO. Nonsurgical treatment of a skeletal vertical discrepancy with a significant open bite. Am J Orthod Dentofacial Orthop. Aug. 1997;112(2):124-31. X-1. [pmid: 9267222].
623 Fox PT, Lancaster JL, Parsons LM, et al. Functional volumes modeling: theory and preliminary assessment. Hum Brain Mapp. 1997;5(4):306-11. X-1. [pmid: 20408233].
624 Harris RJ. Creeping attachment associated with the connective tissue with partial-thickness double pedicle graft. J Periodontol. Sep. 1997;68(9):890-9. X-1. [pmid: 9379335].
625 Hosli IM, Tercanli S, Rehder H, et al. Cystic hygroma as an early first-trimester ultrasound marker for recurrent Fryns' syndrome. Ultrasound Obstet Gynecol. Dec. 1997;10(6):422-4. X-1. [pmid: 9476330].
626 Iregbulem LM. Congenital lower lip sinuses in Nigerian children. Br J Plast Surg. Dec. 1997;50(8):649-50. X-1. [pmid: 9613410].
627 Kaneko K, Takahashi K, Unno A, et al. Lingual cyst in infancy: importance of palpation for diagnosis. Acta Paediatr Jpn. Aug. 1997;39(4):475-7. X-1. [pmid: 9316296].
628 Kitano I, Park S, Kato K, et al. Craniofacial morphology of conotruncal anomaly face syndrome. Cleft Palate Craniofac J. Sep. 1997;34(5):425-9. X-1. [pmid: 9345611].
629 MacDonald MR, Baker KS, Schaefer GB. Marshall-Stickler phenotype associated with von Willebrand disease. Am J Med Genet. Jan. 20. 1997;68(2):121-6. X-1. [pmid: 9028444].
630 McCoy DE. Surgical management of the tight lip syndrome in the Shar-Pei dog. J Vet Dent. Sep. 1997;14(3):95-6. X-1. [pmid: 9571897].
631 Narsete TA. Rotation advancement in traumatic upper lip ectropion. Ann Plast Surg. Dec. 1997;39(6):652-3. X-1. [pmid: 9418929].
632 Ohyama K, Susami T, Kato Y, et al. Freeman-Sheldon syndrome: case management from age 6 to 16 years. Cleft Palate Craniofac J. Mar. 1997;34(2):151-3. X-1. [pmid: 9138511].
633 Olney AH, Schaefer GB, Kolodziej P. Van der Woude syndrome. Ear Nose Throat J. Dec. 1997;76(12):852. X-1. [pmid: 9431772].
634 Rance F, Dutau G. Labial food challenge in children with food allergy. Pediatr Allergy Immunol. Feb. 1997;8(1):41-4. X-1. [pmid: 9260218].
635 Rao S, Oak S, Wagh M, et al. Congenital midline palatomandibular bony fusion with a mandibular cleft and a bifid tongue. Br J Plast Surg. Feb. 1997;50(2):139-41. X-1. [pmid: 9135433].
636 Rashid N, Yusuf H. Median lip fissures and their management. Int J Oral Maxillofac Surg. Aug. 1997;26(4):299-300. X-1. [pmid: 9258726].
637 Shields JA, Shields CL, Deglin E. Retinal capillary hemangioma in Marshall-Stickler syndrome. Am J Ophthalmol. Jul. 1997;124(1):120-2. X-1. [pmid: 9222251].
638 Bacher M, Goz G, Pham T, et al. Three-dimensional analysis of cleft palate topology in newborn infants with reference to the cranial skeleton. Cleft Palate Craniofac J. Sep. 1998;35(5):379-95. X-1. [pmid: 9761556].
639 Beinhoff U, Piza-Katzer H. Double lip in a patient with Ascher's syndrome. Eur J Plast Surg. October. 1998;21(7):370-3. PMID:. X-1.
640 Bennaceur S, Buisson T, Bertolus C, et al. Branchio-oculo-facial syndrome with cleft lip and bilateral dermal thymus. Cleft Palate Craniofac J. Sep. 1998;35(5):454-9. X-1. [pmid: 9761567].
641 Dale RF. Clinical audit activities in surgery. J Qual Clin Pract. Mar. 1998;18(1):47-54. X-1. [pmid: 9563561].
642 Dogliotti P, Nadal E, Ulfe I. Oral-acral syndrome and its correction using maxillary bone distraction osteogenesis. J Craniofac Surg. Mar. 1998;9(2):123-6. X-1. [pmid: 9586539].
643 Hattab FN, Yassin OM, Sasa IS. Oral manifestations of Ellis-van Creveld syndrome: report of two siblings with unusual dental anomalies. J Clin Pediatr Dent. Winter. 1998;22(2):159-65. X-1. [pmid: 9643193].
644 Jones SE, Derrick GM. Difficult intubation in an infant with Pierre Robin syndrome and concomitant tongue tie. Paediatr Anaesth. 1998;8(6):510-1. X-1. [pmid: 9836218].
645 Laffon M, Gouchet A, Quenum M, et al. Eutectic mixture of local anesthetics in adult urology patients: an observational trial. Reg Anesth Pain Med. Sep-Oct. 1998;23(5):502-5. X-1. [pmid: 9773705].
646 Lawson W. Erythematous oral lesions: when to treat, when to leave alone. Consultant. 1998;38(7):1749-52. 57. 60 passim. PMID:. X-1.
647 Leonard MS. The maxillary frenum and surgical treatment. Gen Dent. Nov-Dec. 1998;46(6):614-7. X-1, X-2. [pmid: 10218028].
648 Licht A, Posner J, Leipziger LS. Median cleft lip with associated midline sinuses. J Craniofac Surg. Jul. 1998;9(4):366-70. X-1. [pmid: 9780932].
649 Maeda K, Yamamoto Y, Yasuda M, et al. Delusions of oral parasitosis. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1998;22(1):243-8. X-1. [pmid: 9533179].
650 Nagai K, Nagao M, Nagao M, et al. Oral-facial-digital syndrome type IX in a patient with Dandy-Walker malformation. J Med Genet. Apr. 1998;35(4):342-4. X-1. [pmid: 9598735].
651 Nagore E, Sanchez-Motilla JM, Febrer MI, et al. Congenital lower lip pits (Van der Woude syndrome): presentation of 10 cases. Pediatr Dermatol. Nov-Dec. 1998;15(6):443-5. X-1. [pmid: 9875966].
652 Peacock ME. Frenotomy and keratinized tissue augmentation. Gen Dent. Mar-Apr. 1998;46(2):194-6. X-1. [pmid: 9663077].
653 Vegter F, Mulder JW, Hage JJ. The lip index: an anthropometric tool to evaluate objectively the result of the Abbe flap procedure. Ann Plast Surg. Aug. 1998;41(2):166-70. X-1. [pmid: 9718150].
654 Birbeck GL. Traditional African medicines complicate the management of febrile seizures. Eur Neurol. 1999;42(3):184. X-1. [pmid: 10529549].
655 Bissasu M. Use of lingual frenum in determining the original vertical position of mandibular anterior teeth. J Prosthet Dent. Aug. 1999;82(2):177-81. X-1. [pmid: 10424981].
656 Breault LG, Fowler EB, Moore EA, et al. The free gingival graft combined with the frenectomy: a clinical review. Gen Dent. Sep-Oct. 1999;47(5):514-8. X-1. [pmid: 10687483].
657 Chabolle F, Wagner I, Blumen MB, et al. Tongue base reduction with hyoepiglottoplasty: a treatment for severe obstructive sleep apnea. Laryngoscope. Aug. 1999;109(8):1273-80. X-1. [pmid: 10443833].
658 Coskunfirat OK, Velidedeoglu HV, Demir Z, et al. An unusual case of hypoglossia-hypodactyly syndrome. Ann Plast Surg. Mar. 1999;42(3):333-6. X-1. [pmid: 10096628].
659 Ezquerra F, Berrazueta MJ, Ruiz-Capillas A, et al. New approach to the gummy smile. Plast Reconstr Surg. Sep. 1999;104(4):1143-50. discussion 51-2. X-1. [pmid: 10654758].
660 Hardoy MC, Hardoy MJ, Carta MG, et al. Gabapentin as a promising treatment for antipsychotic-induced movement disorders in schizoaffective and bipolar patients. J Affect Disord. 1999;54(3):315-7. PMID:. X-1. [pmid: 10467977].
661 Hoexter DL. Periodontal aesthetics to enhance a smile. Dent Today. May. 1999;18(5):78-81. X-1. [pmid: 10765835].
662 Ingram C. Melkersson-Rosenthal syndrome or oro-facial granulomatosis (OFG): an update. J N Z Soc Periodontol. 1999;(84):24-5. X-1. [pmid: 10823050].
663 Lam YH, Tang MH. Sonographic features of fetal trisomy 18 at 13 and 14 weeks: four case reports. Ultrasound Obstet Gynecol. May. 1999;13(5):366-9. X-1. [pmid: 10380305].
664 Lin WY, Lo LJ, Chen YR, et al. Bilateral coronoid process hyperplasia with limitation on mouth opening: case report. Changgeng Yi Xue Za Zhi. Mar. 1999;22(1):123-7. X-1. [pmid: 10418221].
665 Lopes MA, Goncalves M, Di Hipolito Junior O, et al. Congenital lower lip pits: case report and review of literature. J Clin Pediatr Dent. Spring. 1999;23(3):275-7. X-1. [pmid: 10686876].
666 Luke MC, Darling TN, Hsu R, et al. Mucosal morbidity in patients with epidermolysis bullosa acquisita. Arch Dermatol. Aug. 1999;135(8):954-9. X-1. [pmid: 10456345].
667 Maupome G, Borges A, Ramirez LE, et al. Perceptions of tooth loss and periodontal problems in an independent elderly population: content-analysis of interview discourse. J Cross Cult Gerontol. Mar. 1999;14(1):43-63. X-1. [pmid: 14617895].
668 Mavili ME, Karamursel S, Vargel I, et al. Bartsocas-Papas syndrome with fusion of the lips and posterior fusion defects of the thoracic vertebrae. Ann Plast Surg. Oct. 1999;43(4):443-5. X-1. [pmid: 10517476].
669 Miller PJ, Grinberg D, Wang TD. Midline cleft. Treatment of the bifid nose. Arch Facial Plast Surg. Jul-Sep. 1999;1(3):200-3. X-1. [pmid: 10937104].
670 Nikhil S, Vineeta, Gupta P. Inverted mesiodens--a case report. J Indian Soc Pedod Prev Dent. Sep. 1999;17(3):111-2. X-1. [pmid: 10863502].
671 Oesterle LJ, Shellhart WC. Maxillary midline diastemas: a look at the causes. J Am Dent Assoc. Jan. 1999;130(1):85-94. X-1. [pmid: 9919036].
672 Pantanowitz L, Berk M. Auto-amputation of the tongue associated with flupenthixol induced extrapyramidal symptoms. Int Clin Psychopharmacol. Mar. 1999;14(2):129-31. X-1. [pmid: 10220129].
673 Tan HK, Smith JD, Goh DY. Unfused hypoplastic tongue in a newborn. Int J Pediatr Otorhinolaryngol. Jun. 15. 1999;49(1):53-61. X-1. [pmid: 10428405].
674 Wallstrom M, Sand L, Nilsson F, et al. The long-term effect of nicotine on the oral mucosa. Addiction. Mar. 1999;94(3):417-23. X-1. [pmid: 10605870].
675 Wood GJ, Zadeh HH. Potential adjunctive applications of hypnosis in the management of periodontal diseases. Am J Clin Hypn. Jan. 1999;41(3):212-25. X-1. [pmid: 10554383].
676 Xue SA. Speaking fundamental frequency and resonance characteristics of young children with Class III malocclusions in North China. Asia Pac J Speech Lang Hear. 1999;4(1):53-8. PMID:. X-1.
677 Yamamura K, Yotsuyanagi T, Okamoto T, et al. Pain relief of oral ulcer by dibucaine-film. Pain. Dec. 1999;83(3):625-6. X-1. [pmid: 10568871].
678 Yeow VK, Chen PK, Lin WY, et al. Midface distraction osteogenesis in cleft patients: a case report. Ann Acad Med Singapore. Sep. 1999;28(5):757-9. X-1. [pmid: 10597366].
679 Yi NN, Yeow VK, Lee ST. Epidemiology of cleft lip and palate in Singapore--a 10-year hospital-based study. Ann Acad Med Singapore. Sep. 1999;28(5):655-9. X-1. [pmid: 10597349].
680 Arseneault L, Tremblay RE, Boulerice B, et al. Minor physical anomalies and family adversity as risk factors for violent delinquency in adolescence. Am J Psychiatry. Jun. 2000;157(6):917-23. X-1. [pmid: 10831471].
681 Baxter AM, Shaw MJ, Warren K. Dental and oral lesions in two patients with focal dermal hypoplasia (Goltz syndrome). Br Dent J. Nov. 25. 2000;189(10):550-3. X-1. [pmid: 11128257].
682 Benesch M, Eber E, Pfleger A, et al. Recurrent lower respiratory tract infections in a 14-year-old boy with tracheobronchomegaly (Mounier-Kuhn syndrome). Pediatr Pulmonol. Jun. 2000;29(6):476-9. X-1. [pmid: 10821730].
683 Britto JA, Ragoowansi RH, Sommerlad BC. Double tongue, intraoral anomalies, and cleft palate--case reports and a discussion of developmental pathology. Cleft Palate Craniofac J. Jul. 2000;37(4):410-5. X-1. [pmid: 10912721].
684 Carmichael SL, Shaw GM. Maternal life event stress and congenital anomalies. Epidemiology. Jan. 2000;11(1):30-5. X-1. [pmid: 10615840].
685 De Felice C, Di Maggio G, Zagordo L, et al. Hypoplastic or absent mandibular frenulum: a new predictive sign of infantile hypertrophic pyloric stenosis. J Pediatr. Mar. 2000;136(3):408-10. X-1. [pmid: 10700703].
686 De Moor RJ, De Witte AM, De Bruyne MA. Tongue piercing and associated oral and dental complications. Endod Dent Traumatol. Oct. 2000;16(5):232-7. X-1. [pmid: 11202888].
687 DeRowe A, Woodson BT. A minimally invasive technique for tongue base stabilization in obstructive sleep apnea. Operative Techniques in Otolaryngology - Head & Neck Surgery. 2000;11(1):41-6. PMID:. X-1.
688 Dromey C. Articulatory kinematics in patients with Parkinson disease using different speech treatment approaches. J Med Speech Lang Pathol. 2000;8(3):155-61. PMID:. X-1.
689 Fowler EB, Breault LG. Early creeping attachment after frenectomy: a case report. Gen Dent. Sep-Oct. 2000;48(5):591-3. X-1. [pmid: 11199640].
690 Fowler EB, Breault LG, Galvin BG. Enhancing physiologic pigmentation utilizing a free gingival graft. Pract Periodontics Aesthet Dent. Mar. 2000;12(2):193-6. X-1. [pmid: 11404960].
691 Jacobsen PL, Carpenter WM. MIND: a method of diagnosing oral pathology. Dent Today. Dec. 2000;19(12):58-61. X-1. [pmid: 12524836].
692 Kara CO, Kara IG. Double lip. Internet Journal of Advanced Nursing Practice. 2000;4(2). 5p. PMID:. X-1, X-2.
693 Kondo E, Aoba TJ. Nonsurgical and nonextraction treatment of skeletal Class III open bite: its long-term stability. Am J Orthod Dentofacial Orthop. Mar. 2000;117(3):267-87. X-1. [pmid: 10715087].
694 Konst EM, Weersink-Braks H, Rietveld T, et al. An intelligibility assessment of toddlers with cleft lip and palate who received and did not receive presurgical infant orthopedic treatment. J Commun Disord. 2000;33(6):483-501. PMID:. X-1. [pmid: 11141029].
695 Liptak JM, Canfield PJ, Hunt GB. Dermoid cyst in the tongue of a dog. Aust Vet J. Mar. 2000;78(3):160-1. X-1. [pmid: 10860152].
696 Meregalli G, Vermeulen AC, Ollevier F. The use of chironomid deformation in an in situ test for sediment toxicity. Ecotoxicol Environ Saf. Nov. 2000;47(3):231-8. X-1. [pmid: 11139175].
697 Miura H, Isogai E, Mizugai H, et al. Perceived oral health status, oral function and related behaviour among the patients of Behçet's disease. Asia Pac J Public Health. 2000;12(2):98-101. PMID:. X-1. [pmid: 11836926].
698 Nagasao T, Urushidate S, Yokoi K, et al. A case of congenital midline sinus of the upper lip. Eur J Plast Surg. July. 2000;23(5):289-93. PMID:. X-1.
699 Naidoo S. A profile of the oro-facial injuries in child physical abuse at a children's hospital. Child Abuse Negl. Apr. 2000;24(4):521-34. X-1. [pmid: 10798841].
700 Newton JT, Travess HC. Oral complications. Eur Eat Disord Rev. 2000;8(2):83-7. PMID:. X-1.
701 Niechajev I. Lip enhancement: surgical alternatives and histologic aspects. Plast Reconstr Surg. Mar. 2000;105(3):1173-83. discussion 84-7. X-1. [pmid: 10724279].
702 Ohkubo C, Hanatani S, Hosoi T, et al. Neutral zone approach for denture fabrication for a partial glossectomy patient: a clinical report. J Prosthet Dent. Oct. 2000;84(4):390-3. X-1. [pmid: 11044843].
703 Ozgur F, Tuncbilek G. Bilateral congenital pits of the upper lip. Ann Plast Surg. Dec. 2000;45(6):658-61. X-1. [pmid: 11128769].
704 Peticolas T, Tilliss TS, Cross-Poline GN. Oral and perioral piercing: a unique form of self-expression. J Contemp Dent Pract. Aug. 15. 2000;1(3):30-46. X-1. [pmid: 12167881].
705 Prasad CN, Marsh JL, Long RE Jr., et al. Quantitative 3D maxillary arch evaluation of two different infant managements for unilateral cleft lip and palate. Cleft Palate Craniofac J. Nov. 2000;37(6):562-70. X-1. [pmid: 11108526].
706 Rice JH. Laser use in fixed, removable, and implant dentistry. Dent Clin North Am. Oct. 2000;44(4):767-77. X-1. [pmid: 11048270].
707 Saif MW, Takimoto CH. Double take: an intriguing diagnosis. Macroglossia in a patient with recurrent multiple myeloma. Consultant. 2000;40(8):1438-40. PMID:. X-1.
708 Schellenberg JB, Maislin G, Schwab RJ. Physical findings and the risk for obstructive sleep apnea. The importance of oropharyngeal structures. Am J Respir Crit Care Med. Aug. 2000;162(2 Pt 1):740-8. X-1. [pmid: 10934114].
709 Thomas S, Tandon S. Hurler syndrome: a case report. J Clin Pediatr Dent. Summer. 2000;24(4):335-8. X-1. [pmid: 11314421].
710 Troell RJ, Li KK, Powell NB, et al. Radiofrequency tongue base reduction in sleep-disordered breathing. Operative Techniques in Otolaryngology - Head & Neck Surgery. 2000;11(1):47-9. PMID:. X-1.
711 Yamada A, Konno N, Imai Y, et al. Treatment of hypoglossia-hypodactyly syndrome without extremeity anomalies. Plast Reconstr Surg. Aug. 2000;106(2):274-9. X-1. [pmid: 10946924].
712 Abe S, Ishihara K, Okuda K. Prevalence of potential respiratory pathogens in the mouths of elderly patients and effects of professional oral care. Arch Gerontol Geriatr. Feb. 2001;32(1):45-55. X-1. [pmid: 11251238].
713 Aglioti SM, Tassinari G, Fabri M, et al. Taste laterality in the split brain. Eur J Neurosci. Jan. 2001;13(1):195-200. X-1. [pmid: 11135018].
714 Arvidsson A, Stirling C, Sennerby L, et al. Reactions in the oral mucous membrane after exposure to Carisolv--combined results from a clinical screening test in humans and an experimental study in rats. Gerodontology. Dec. 2001;18(2):109-13. X-1. [pmid: 11794736].
715 Aydin Y, Yucel A, Yildirim MA, et al. Reconstruction of shallow upper buccal sulcus deformity secondary to cleft lip and palate repair. J Craniofac Surg. Sep. 2001;12(5):490-4. X-1. [pmid: 11572257].
716 Baujat G, Faure C, Zaouche A, et al. Oroesophageal motor disorders in Pierre Robin syndrome. J Pediatr Gastroenterol Nutr. Mar. 2001;32(3):297-302. X-1. [pmid: 11345179].
717 Beard WL, Holcombe SJ, Hinchcliff KW. Effect of a tongue-tie on upper airway mechanics during exercise following sternothyrohyoid myectomy in clinically normal horses. Am J Vet Res. May. 2001;62(5):779-82. X-1. [pmid: 11341403].
718 Bienengraber V, Malek FA, Moritz KU, et al. Is it possible to prevent cleft palate by prenatal administration of folic acid? An experimental study. Cleft Palate Craniofac J. Jul. 2001;38(4):393-8. X-1. [pmid: 11420020].
719 Bressmann T, Sader R. Speech rate in cleft lip and palate speakers with compensatory articulation. Clin Linguist Phon. 2001;15(1-2):129-32. X-1. [pmid: 21269112].
720 Cerajewska TL, Singh GD. Changes in soft tissue facial profile of craniofacial microsomia patients: geometric morphometrics. Int J Adult Orthodon Orthognath Surg. 2001;16(1):61-71. X-1. [pmid: 11563398].
721 Cho B. Unilateral complete cleft lip and palate repair using lip adhesion and passive alveolar molding appliance. J Craniofac Surg. Mar. 2001;12(2):148-56. X-1. [pmid: 11314626].
722 Chua CN, Ainsworth J. Ocular management of harlequin syndrome. Arch Ophthalmol. Mar. 2001;119(3):454-5. X-1. [pmid: 11231785].
723 Cornelisse CJ, Rosenstein DS, Derksen FJ, et al. Computed tomographic study of the effect of a tongue-tie on hyoid apparatus position and nasopharyngeal dimensions in anesthetized horses. Am J Vet Res. Dec. 2001;62(12):1865-9. X-1. [pmid: 11763172].
724 De Smet L, Schollen W. Hypoglossia-hypodactyly syndrome: report of 2 patients. Genet Couns. 2001;12(4):347-52. X-1. [pmid: 11837603].
725 Devine JC, Rogers SN, McNally D, et al. A comparison of aesthetic, functional and patient subjective outcomes following lip-split mandibulotomy and mandibular lingual releasing access procedures. Int J Oral Maxillofac Surg. Jun. 2001;30(3):199-204. X-1. [pmid: 11420901].
726 Docimo SG. Subcutaneous frenulum flap (SCUFF) for iatrogenic or primary megameatus and reoperative hypospadias repair. Urology. Aug. 2001;58(2):271-3. X-1. [pmid: 11489717].
727 Dodd MJ, Dibble S, Miaskowski C, et al. A comparison of the affective state and quality of life of chemotherapy patients who do and do not develop chemotherapy-induced oral mucositis. J Pain Symptom Manage. 2001;21(6):498-505. PMID:. X-1. [pmid: 11397608].
728 Eaton D, Billings K, Timmons C, et al. Congenital foregut duplication cysts of the anterior tongue. Arch Otolaryngol Head Neck Surg. Dec. 2001;127(12):1484-7. X-1. [pmid: 11735820].
729 Fox LE, Rau MT. Augmentative and alternative communication for adults following glossectomy and laryngectomy surgery. Augment Altern Commun. 2001;17(3):161-6. PMID:. X-1.
730 Galyon SW, Frodel JL. Lip and perioral defects. Otolaryngol Clin North Am. Jun. 2001;34(3):647-66. X-1. [pmid: 11447007].
731 Gatti AF, Moreti MM, Cardoso SV, et al. Mucus extravasation phenomenon in newborn babies: report of two cases. Int J Paediatr Dent. Jan. 2001;11(1):74-7. X-1. [pmid: 11309877].
732 Hartsfield JK Jr., Hickman TA, Everett ET, et al. Analysis of the EPHX1 113 polymorphism and GSTM1 homozygous null polymorphism and oral clefting associated with maternal smoking. Am J Med Genet. Jul. 22. 2001;102(1):21-4. X-1. [pmid: 11471167].
733 Ishii K, Tamaoka A, Shoji S. A case of primary focal lingual dystonia induced by speaking. Eur J Neurol. Sep. 2001;8(5):507. X-1. [pmid: 11554920].
734 Kara IG, Kara CO. Ascher syndrome. Otolaryngol Head Neck Surg. Feb. 2001;124(2):236-7. X-1. [pmid: 11226966].
735 Kilic N, Kiristioglu I, Balkan E, et al. Oromandibular limb hypogenesis and gastroschisis. J Pediatr Surg. Jul. 2001;36(7):E15. X-1. [pmid: 11431800].
736 Kondoh T, Yoshinaga M, Matsumoto T, et al. Severe cervical kyphosis in osteopathia striata with cranial sclerosis: case report. Pediatr Radiol. Sep. 2001;31(9):659-62. X-1. [pmid: 11512010].
737 Kumar A, Kuriakose S. Incontinentia pigmentii acromians with seizure disorder: a case report. J Indian Soc Pedod Prev Dent. Dec. 2001;19(4):145-7. X-1. [pmid: 12396091].
738 Kumin L, Von Hagel KC, Bahr DC. An effective oral motor intervention protocol for infants and toddlers with low muscle tone. Infant-Toddler Intervention. 2001;11(3-4):181-200. PMID:. X-1.
739 Lee OY, Mayer EA, Schmulson M, et al. Gender-related differences in IBS symptoms. Am J Gastroenterol. Jul. 2001;96(7):2184-93. X-1. [pmid: 11467651].
740 Lindsey WH. Reliability of the melolabial flap for alar reconstruction. Arch Facial Plast Surg. Jan-Mar. 2001;3(1):33-7. X-1. [pmid: 11176717].
741 Lopez Jimenez J, Romero Dominguez A, Gimenez Prats MJ, et al. Characteristics and dental treatment of partial trisomy 9. Med Oral. Aug-Oct. 2001;6(4):290-5. X-1. [pmid: 11500644].
742 Lotze M, Flor H, Grodd W, et al. Phantom movements and pain. An fMRI study in upper limb amputees. Brain. Nov. 2001;124(Pt 11):2268-77. X-1. [pmid: 11673327].
743 Marcusson A, Akerlind I, Paulin G. Quality of life in adults with repaired complete cleft lip and palate. Cleft Palate Craniofac J. Jul. 2001;38(4):379-85. X-1. [pmid: 11420018].
744 Massad JJ, Anderson JF. Hamular frenum modification: a removable denture prosthesis retention and stability enhancement. Int J Periodontics Restorative Dent. Apr. 2001;21(2):183-9. X-1. [pmid: 11829392].
745 Nanba K, Ito K. Palatal radicular multigrooves associated with severe periodontal defects in maxillary central incisors. J Clin Periodontol. Apr. 2001;28(4):372-5. X-1. [pmid: 11314895].
746 Noda T, Yamano T, Shimizu M. Effects of maternal age on teratogenicity of di-n-butyltin diacetate in rats. Toxicology. Oct. 30. 2001;167(3):181-9. X-1. [pmid: 11578797].
747 Schulze BR, Tariverdian G, Komposch G, et al. Misclassification risk of patients with bilateral cleft lip and palate and manifestations of median facial dysplasia: A new variant of del(22q11.2) syndrome?. Am J Med Genet. Apr. 1. 2001;99(4):280-5. X-1. [pmid: 11251993].
748 Serrano Martinez C, Silvestre Donat FJ, Bagan Sebastian JV, et al. Hereditary epidermolysis bullosa. Dental management of three cases. Med Oral. Jan-Feb. 2001;6(1):48-56. X-1. [pmid: 11488131].
749 Shuman IE. Bipolar versus monopolar electrosurgery: clinical applications. Dent Today. Dec. 2001;20(12):74-6. 8. 81. X-1. [pmid: 11775284].
750 Stephen LX, Behardien N, Beighton P. Focal dermal hypoplasia: management of complex dental features. J Clin Pediatr Dent. Summer. 2001;25(4):259-61. X-1. [pmid: 11497004].
751 Tanabe A, Kusumoto K, Suzuki K, et al. Treatment of Setleis syndrome. Case report. Scand J Plast Reconstr Surg Hand Surg. Mar. 2001;35(1):107-11. X-1. [pmid: 11291343].
752 Trixler M, Tenyi T, Csabi G, et al. Minor physical anomalies in schizophrenia and bipolar affective disorder. Schizophr Res. Dec. 1. 2001;52(3):195-201. X-1. [pmid: 11705713].
753 Ugwu BT, Momoh JT. Van der Woude syndrome with mental retardation: case report. East Afr Med J. Feb. 2001;78(2):111-2. X-1. [pmid: 11682943].
754 Vergo TJ Jr. Prosthodontics for pediatric patients with congenital/developmental orofacial anomalies: a long-term follow-up. J Prosthet Dent. Oct. 2001;86(4):342-7. X-1. [pmid: 11677526].
755 Whitehill TL, Samman N, Wong LLN, et al. Speech errors associated with dentofacial abnormalities in Cantonese speakers. J Med Speech Lang Pathol. 2001;9(3):177-90. PMID:. X-1.
756 Who's sore-y now?… displays of infection with the herpes simplex virus. POZ. 2002;(78):17. PMID:. X-1.
757 Abe H, Tomita D, Wakamatsu S. Mandibular reconstructive surgery in a patient with median cleft of the lower lip and mandible. Int J Oral Maxillofac Surg. Oct. 2002;31(5):549-52. X-1. [pmid: 12418573].
758 Albino JEN. A psychologist's guide to oral diseases and their treatment. Prof Psychol Res Pr. 2002;33(2):176-82. PMID:. X-1.
759 Ameh EA, Mshelbwala P. Intralingual foregut duplication cyst: a case report. Niger Postgrad Med J. Mar. 2002;9(1):32-3. X-1. [pmid: 11932758].
760 Arangannal P, Muthu MS, Nirmal L. Van der Woude syndrome: a case report. J Indian Soc Pedod Prev Dent. Sep. 2002;20(3):102-3. X-1. [pmid: 12435007].
761 Baker P, Spedding C. The aetiology of gingival recession. Dent Update. Mar. 2002;29(2):59-62. X-1. [pmid: 11928341].
762 Bouza MD, Simón MA, Seoane JM. An evaluation of pharmacological treatment combined with stress inoculation training in the management of oral Lichen Planus. Psychol Health. 2002;17(6):793-9. PMID:. X-1.
763 Carach B, Woods M, Scott P. Maxillonasal dysplasia (Binder syndrome): a lateral cephalometric assessment. Aust Orthod J. Nov. 2002;18(2):82-91. X-1. [pmid: 12462685].
764 Cho DY, Liau WR. Comparison of endonasal endoscopic surgery and sublabial microsurgery for prolactinomas. Surg Neurol. Dec. 2002;58(6):371-5. discussion 5-6. X-1. [pmid: 12517610].
765 Conus P, Zullino D, Baumann P. Clozapine is more efficacious for tongue dystonia than olanzapine. Psychopharmacology (Berl). Jun. 2002;162(1):89. X-1. [pmid: 12107624].
766 Corbetta M, Burton H, Sinclair RJ, et al. Functional reorganization and stability of somatosensory-motor cortical topography in a tetraplegic subject with late recovery. Proc Natl Acad Sci USA. Dec. 24. 2002;99(26):17066-71. X-1. [pmid: 12477938].
767 De Serpa Pinto MV, De Magalhaes MH, Nunes FD. Moebius syndrome with oral involvement. Int J Paediatr Dent. Nov. 2002;12(6):446-9. X-1. [pmid: 12452989].
768 Fadiga L, Craighero L, Buccino G, et al. Speech listening specifically modulates the excitability of tongue muscles: a TMS study. Eur J Neurosci. Jan. 2002;15(2):399-402. X-1. [pmid: 11849307].
769 Ferrario VF, Serrao G, Ciusa V, et al. Cephalometric and in vivo measurements of maxillomandibular anteroposterior discrepancies: a preliminary regression study. Angle Orthod. Dec. 2002;72(6):579-84. X-1. [pmid: 12518952].
770 Franklin SH, Naylor JR, Lane JG. The effect of a tongue-tie in horses with dorsal displacement of the soft palate. Equine Vet J Suppl. Sep. 2002;(34):430-3. X-1. [pmid: 12405729].
771 Guerrerosantos J, Trabanino C. Lower lip reconstruction with tongue flap in paramedian bilateral congenital sinuses. Plast Reconstr Surg. Jan. 2002;109(1):236-9. X-1. [pmid: 11786817].
772 Guner U, Celik N, Ozek C, et al. Van der Woude syndrome. Scand J Plast Reconstr Surg Hand Surg. 2002;36(2):103-5. X-1. [pmid: 12038200].
773 Gurenlian JR. DHDx & oral medicine. Case study: herpes labialis. Access. 2002;16(1):38. PMID:. X-1.
774 Innocenti M, Moscatelli G, Lopez S. Efficacy of gelclair in reducing pain in palliative care patients with oral lesions: preliminary findings from an open pilot study. J Pain Symptom Manage. Nov. 2002;24(5):456-7. X-1. [pmid: 12547044].
775 Ishii M, Ishii Y, Moriyama T, et al. Seventeen-year follow-up of a patient with median cleft of the lower lip, mandible, and tongue with flexion contracture: a case report. Cleft Palate Craniofac J. Sep. 2002;39(5):555-9. X-1. [pmid: 12190345].
776 Kawamata T, Iseki H, Ishizaki R, et al. Minimally invasive endoscope-assisted endonasal trans-sphenoidal microsurgery for pituitary tumors: experience with 215 cases comparing with sublabial trans-sphenoidal approach. Neurol Res. Apr. 2002;24(3):259-65. X-1. [pmid: 11958419].
777 King NM, Sanares AM. Oral-facial-digital syndrome, Type I: a case report. J Clin Pediatr Dent. Winter. 2002;26(2):211-5. X-1. [pmid: 11878279].
778 Lee P. Unilateral tongue swelling from use of the laryngeal mask airway with the Guedel airway as a bite guard. Internet Journal of Anesthesiology. 2002;5(4). 4p. PMID:. X-1.
779 Leston JM, Santos AA, Varela-Centelles PI, et al. Oral mucosa: variations from normalcy, part II. Cutis. Mar. 2002;69(3):215-7. X-1. [pmid: 11930907].
780 Mandell DL, Ranganathan S, Bluestone CD. Neonatal lingual choristoma with respiratory and gastric epithelium. Arch Otolaryngol Head Neck Surg. Nov. 2002;128(11):1321-4. X-1. [pmid: 12431180].
781 Marx I, Op't Hof J. The Er,Cr:YSGG hydrokinetic laser system for dentistry--clinical applications. Sadj. Aug. 2002;57(8):323-6. X-1. [pmid: 12428527].
782 Minsk L. The frenectomy as an adjunct to periodontal treatment. Compend Contin Educ Dent. May. 2002;23(5):424-6. 8. X-1. [pmid: 12060961].
783 Moretti R, Torre P, Antonello RM, et al. Gabapentin treatment of glossopharyngeal neuralgia: a follow-up of four years of a single case. Eur J Pain. 2002;6(5):403-7. X-1. [pmid: 12160515].
784 Morris AJ, Roche SA, Bentham P, et al. A dental risk management protocol for electroconvulsive therapy. J ECT. Jun. 2002;18(2):84-9. X-1. [pmid: 12195136].
785 Onyeaso CO, Fasola AO, Arowojolu MO. Dentofacial findings in Down's syndrome: report of case. Afr J Med Med Sci. Mar. 2002;31(1):71-4. X-1. [pmid: 12518935].
786 Oredugba FA, Savage KO. Anthropometric finding in Nigerian children with sickle cell disease. Pediatr Dent. Jul-Aug. 2002;24(4):321-5. X-1. [pmid: 12212874].
787 Sancho MA, Albert A, Cusi V, et al. Upper lip fistulas: three new cases. Cleft Palate Craniofac J. Jul. 2002;39(4):457-60. X-1. [pmid: 12071794].
788 Schonauer F, La Rusca I, Sordino D, et al. Endoscopic release of intraoral synechiae in popliteal pterygium syndrome. Ann Plast Surg. Nov. 2002;49(5):550-2. X-1. [pmid: 12439026].
789 Scott K, Nunley JR. Dermatologic look-alikes. Tongues take a licking. Clinical Advisor for Nurse Practitioners. 2002;5(9):38. PMID:. X-1.
790 Shimoyama T, Kato T, Horie N, et al. Oropharyngeal airway appliance for infant with upper airway obstruction: report of a case. J Clin Pediatr Dent. Fall. 2002;27(1):25-8. X-1. [pmid: 12413168].
791 Stephen LX, Beighton PH. Oro-dental manifestations of the Schwartz-Jampel syndrome. J Clin Pediatr Dent. Fall. 2002;27(1):67-70. X-1. [pmid: 12413175].
792 Sumitomo S, Ogawa S, Hirai K, et al. Congenital sinus of the upper lip with idiopathic precocious puberty. Oral Dis. Nov. 2002;8(6):308-9. X-1. [pmid: 12477063].
793 Swansburg EO, Fairchild WL, Fryer BJ, et al. Mouthpart deformities and community composition of Chironomidae (Diptera) larvae downstream of metal mines in New Brunswick, Canada. Environ Toxicol Chem. Dec. 2002;21(12):2675-84. X-1. [pmid: 12463564].
794 Tarbox J, Wallace MD, Tarbox RSF. Successful generalized parent training and failed schedule thinning of response blocking for automatically maintained object mouthing. Behav Interv. 2002;17(3):169-78. PMID:. X-1.
795 Terezhalmy GT, Moore WS, Bsoul SA, et al. Focal dermal hypoplasia (Goltz-Gorlin syndrome). Quintessence Int. Oct. 2002;33(9):706-7. X-1. [pmid: 12666897].
796 Tomita H, Ohtuka K. Taste disturbance after tonsillectomy. Acta Otolaryngol Suppl. 2002;122(546):164-72. X-1. [pmid: 12132617].
797 van Lieshout PH, Rutjens CA, Spauwen PH. The dynamics of interlip coupling in speakers with a repaired unilateral cleft-lip history. J Speech Lang Hear Res. Feb. 2002;45(1):5-19. X-1. [pmid: 14748635].
798 Yamada T, Mori Y, Minami K, et al. Surgical results of primary lip repair using the triangular flap method for the treatment of complete unilateral cleft lip and palate: a three-dimensional study in infants to four-year-old children. Cleft Palate Craniofac J. Sep. 2002;39(5):497-502. X-1. [pmid: 12190336].
799 Yamashita S, Sato S, Kakiuchi Y, et al. Lidocaine toxicity during frequent viscous lidocaine use for painful tongue ulcer. J Pain Symptom Manage. 2002;24(5):543-5. PMID:. X-1. [pmid: 12547053].
800 Yildirim I, Aydin Y, Cinar C, et al. Management of total lower face cleft. Plast Reconstr Surg. Feb. 2002;109(2):683-7. X-1. [pmid: 11818853].
801 Photo essay: focus on signs and symptoms. Oral and perioral lesions: a collage. Consultant. 2003;43(12):1420. 2. 4-6 passim. PMID:. X-1.
802 Al-Ghamdi K, Crawford PJ. Focal dermal hypoplasia -- oral and dental findings. Int J Paediatr Dent. Mar. 2003;13(2):121-6. X-1. [pmid: 12605631].
803 Avcu N, Kanli A. The prevalence of tongue lesions in 5150 Turkish dental outpatients. Oral Dis. Jul. 2003;9(4):188-95. X-1. [pmid: 12974518].
804 Backman B, Grever-Sjolander AC, Holm AK, et al. Children with Down Syndrome: oral development and morphology after use of palatal plates between 6 and 18 months of age. Int J Paediatr Dent. Sep. 2003;13(5):327-35. X-1. [pmid: 12924988].
805 Bender M. Beauty. Why do my lips feel more dry and chapped now than they did last winter?. Health (Time IncHealth). 2003;17(6):36. PMID:. X-1.
806 Bhola M, Newell DH, Hancock EB. Acellular dermal allograft for vestibuloplasty--an alternative to autogenous soft tissue grafts in preprosthetic surgical procedures: a clinical report. J Prosthodont. Jun. 2003;12(2):133-7. X-1. [pmid: 12964686].
807 Biber JT. Oral piercing: the hole story. Northwest Dent. Jan-Feb. 2003;82(1):13-7. 34. X-1. [pmid: 12640773].
808 Bitar MA, Kumar S. Plunging congenital epidermoid cyst of the oral cavity. Eur Arch Otorhinolaryngol. Apr. 2003;260(4):223-5. X-1. [pmid: 12709808].
809 Burns-Naas LA, Stump DG, Webber S, et al. Absence of reproductive and developmental toxicity in rats following oral dosing with nelfinavir. Regul Toxicol Pharmacol. Dec. 2003;38(3):304-16. X-1. [pmid: 14623481].
810 Capon-Degardin N, Martinot-Duquennoy V, Auvray G, et al. Lower lip repair in Van der Woude syndrome. Eur J Pediatr Surg. Apr. 2003;13(2):92-6. X-1. [pmid: 12776239].
811 Din SU. Atypical tongue-tie due to congenital tongue-palate fusion. J Coll Physicians Surg Pak. Aug. 2003;13(8):459-60. X-1. [pmid: 12921684].
812 Epstein JB, Truelove EL, Oien H, et al. Oral topical doxepin rinse: anesthetic effect in normal subjects. Pain Res Manag. Winter. 2003;8(4):195-7. X-1. [pmid: 14679413].
813 Field D, Garland M, Williams K. Correlates of specific childhood feeding problems. J Paediatr Child Health. May-Jun. 2003;39(4):299-304. X-1. [pmid: 12755939].
814 Fu AS, Mehta NR, Forgione AG, et al. Maxillomandibular relationship in TMD patients before and after short-term flat plane bite plate therapy. Cranio. Jul. 2003;21(3):172-9. X-1. [pmid: 12889672].
815 Gilmore R, Aram J, Powell J, et al. Treatment of oro-facial hypersensitivity following brain injury. Brain Inj. Apr. 2003;17(4):347-54. X-1. [pmid: 12637186].
816 Ginsberg DL. Serotonin reuptake inhibitor-induced burning mouth syndrome. Primary Psychiatry. 2003;10(6):15. PMID:. X-1.
817 Guyuron B, Behmand RA. Caudal nasal deviation. Plast Reconstr Surg. Jun. 2003;111(7):2449-57. discussion 58-9. X-1. [pmid: 12794495].
818 Imarengiaye CO, Ogunsakin A. Negative pressure pulmonary oedema following tracheal tube obstruction in a paediatric patient: a preventable anaesthesia related morbidity. Niger Postgrad Med J. Sep. 2003;10(3):162-4. X-1. [pmid: 14692058].
819 Janssens de Bisthoven L, Gerhardt A. Chironomidae (Diptera, Nematocera) fauna in three small streams of Skania, Sweden. Environ Monit Assess. Mar. 2003;83(1):89-102. X-1. [pmid: 12666723].
820 Karabiyik L. Airway management of a patient with Weill-Marchesani syndrome. J Clin Anesth. May. 2003;15(3):214-6. X-1. [pmid: 12770659].
821 Karakaya D, Baris S, Belet N, et al. Anaesthetic and airway management in a child with Hanhart's syndrome. Paediatr Anaesth. Mar. 2003;13(3):263-6. X-1. [pmid: 12641691].
822 Konst EM, Rietveld T, Peters HFM, et al. Phonological development of toddlers with unilateral cleft lip and palate who were treated with and without infant orthopedics: a randomized clinical trial. Cleft Palate Craniofac J. 2003;40(1):32-9. PMID:. X-1. [pmid: 12498603].
823 Lee J, Hida K, Seki T, et al. Pierre-Robin syndrome associated with Chiari type I malformation. Childs Nerv Syst. Jun. 2003;19(5-6):380-3. X-1. [pmid: 12748800].
824 Levenson JL. Burning mouth syndrome as a side effect of SSRIs. J Clin Psychiatry. 2003;64(3):336-7. PMID:. X-1. [pmid: 12716278].
825 Lockhart E. Mental health needs of children and adolescents with cleft lip and/or palate. Clin Child Psychol Psychiatry. 2003;8(1):7-16. PMID:. X-1.
826 Longo F, Maremonti P, Mangone GM, et al. Midline (dermoid) cysts of the floor of the mouth: report of 16 cases and review of surgical techniques. Plast Reconstr Surg. Nov. 2003;112(6):1560-5. X-1. [pmid: 14578785].
827 Mady K, Sader R, Hoole PH, et al. Speech evaluation and swallowing ability after intra-oral cancer. Clin Linguist Phon. Jun-Aug. 2003;17(4-5):411-20. X-1. [pmid: 12945617].
828 Maina G, Bogetto F. “Burning mouth syndrome as a side effect of SSRIs”: Reply. J Clin Psychiatry. 2003;64(3):337-8. PMID:. X-1.
829 Nash RW. Closing a large central diastema using a pressed ceramic. Dent Today. Nov. 2003;22(11):62-5. X-1. [pmid: 14650338].
830 Neef JA. Clip & file. Dermadilemma… lip-licking dermatitis (atopic dermatitis). Physician Assist. 2003;27(6):49-50. PMID:. X-1.
831 Oji C, Uguru CC, Mgbokwere U, et al. A technique of tongue fixation after total mandibulectomy: the Oji spatula. Br J Oral Maxillofac Surg. Dec. 2003;41(6):392-5. X-1. [pmid: 14614868].
832 Padilla CD, Cutiongco EM, Sia JM. Birth defects ascertainment in the Philippines. Southeast Asian J Trop Med Public Health. Suppl 3. 2003;34:239-43. X-1. [pmid: 15906745].
833 Patel V, Theroux MC, Reilly J. Popliteal pterygium syndrome with syngnathia. Paediatr Anaesth. Jan. 2003;13(1):80-2. X-1. [pmid: 12535046].
834 Petersen PE. Tobacco and oral health--the role of the world health organization. Oral Health Prev Dent. 2003;1(4):309-15. X-1. [pmid: 15643759].
835 Pidgeon K. Breastfeeding Harry. Midwifery Matters. 2003;(99):15-6. PMID:. X-1.
836 Pohl RF, Schwarz S, Sczesny S, et al. Hindsight bias in gustatory judgments. Exp Psychol. 2003;50(2):107-15. X-1. [pmid: 12693195].
837 Roane HR, Kelly ML, Fisher WW. The effects of noncontingent access to food on the rate of object mouthing across three settings. J Appl Behav Anal. 2003;36(4):579-82. X-1. [pmid: 14768675].
838 Serrano-Martinez MC, Bagan JV, Silvestre FJ, et al. Oral lesions in recessive dystrophic epidermolysis bullosa. Oral Dis. Sep. 2003;9(5):264-8. X-1. [pmid: 14628894].
839 Skrinjaric I, Jukic J, Skrinjaric K, et al. Dental and minor physical anomalies in children with developmental disorders--a discriminant analysis. Coll Antropol. Dec. 2003;27(2):769-78. X-1. [pmid: 14746170].
840 Temizsoylu MD, Avki S. Complete ventral ankyloglossia in three related dogs. J Am Vet Med Assoc. Nov. 15. 2003;223(10):1443-5. 33. X-1. [pmid: 14627093].
841 Thorp MA, de Waal PJ, Prescott CA. Extreme microglossia. Int J Pediatr Otorhinolaryngol. May. 2003;67(5):473-7. X-1. [pmid: 12697349].
842 Trindade IE, Yamashita RP, Suguimoto RM, et al. Effects of orthognathic surgery on speech and breathing of subjects with cleft lip and palate: acoustic and aerodynamic assessment. Cleft Palate Craniofac J. Jan. 2003;40(1):54-64. X-1. [pmid: 12498606].
843 Wam Y. Prenatal sonographic diagnosis of congenital epulis. J Diagn Med Conogr. 2003;19(4):255-7. PMID:. X-1.
844 Watts MM, Pascoe D, Carroll K. Exposure to 17 alpha-ethinylestradiol and bisphenol A--effects on larval moulting and mouthpart structure of Chironomus riparius. Ecotoxicol Environ Saf. Feb. 2003;54(2):207-15. X-1. [pmid: 12550099].
845 Whitaker-Menezes D, Jones SC, Friedman TM, et al. An epithelial target site in experimental graft-versus-host disease and cytokine-mediated cytotoxicity is defined by cytokeratin 15 expression. Biol Blood Marrow Transplant. Sep. 2003;9(9):559-70. X-1. [pmid: 14506658].
846 Winn DW 2nd. Lasers in dentistry: soft tissue capabilities. Pract Proced Aesthet Dent. Nov-Dec. 2003;15(10):803-5. X-1. [pmid: 14969217].
847 Wu JK, Kozakewich HP, Mulliken JB. Partial oral duplication: a defect in ectomesenchymal migration?. Plast Reconstr Surg. Nov. 2003;112(6):1645-8. X-1. [pmid: 14578796].
848 Zimmermann A, Sader R, Hoole P, et al. The influence of oral cavity tumour treatment on the voice quality and on fundamental frequency. Clin Linguist Phon. Jun-Aug. 2003;17(4-5):273-81. X-1. [pmid: 12945602].
849 Zuber TJ. Photo quiz: test your clinical acumen. Do you recognize these disorders?. Consultant. 2003;43(6):710. PMID:. X-1.
850 Botulinum toxin injections reduce incapacitating perioral dystonia in Meige's syndrome. Dental Abstracts. 2004;49(3):187-8. PMID:. X-1.
851 CPD clinical quiz. Dent Health. 2004;43(6):13. PMID:. X-1.
852 Picture quiz. Nursing & Residential Care. 2004;6(11):562. PMID:. X-1.
853 Therapies for recurrent herpes simplex labialis. Dental Abstracts. 2004;49(3):142-3. PMID:. X-1.
854 Batra P, Duggal R, Parkash H. “Craniofacial and dental manifestations of a case of Proteus syndrome”. J Indian Soc Pedod Prev Dent. Sep. 2004;22(3):154-7. X-1. [pmid: 15573665].
855 Davidson S, Guinn C, Gacharna D. Diagnosis and treatment of negative pressure pulmonary edema in a pediatric patient: a case report. Aana j. Oct. 2004;72(5):337-8. X-1. [pmid: 15529728].
856 De Benedittis M, Petruzzi M, Favia G, et al. Oro-dental manifestations in Hallopeau-Siemens-type recessive dystrophic epidermolysis bullosa. Clin Exp Dermatol. Mar. 2004;29(2):128-32. X-1. [pmid: 14987265].
857 Dissemond J, Haberer D, Franckson T, et al. The Van der Woude syndrome: a case report and review of the literature. J Eur Acad Dermatol Venereol. Sep. 2004;18(5):611-3. X-1. [pmid: 15324408].
858 Domingos AC, Lopes SL, Almeida SM, et al. Poland-Moebius syndrome: a case with oral anomalies. Oral Dis. Nov. 2004;10(6):404-7. X-1. [pmid: 15533220].
859 Ferrario VF, Dellavia C, Colombo A, et al. Three-dimensional assessment of nose and lip morphology in subjects with down syndrome. Ann Plast Surg. Dec. 2004;53(6):577-83. X-1. [pmid: 15602256].
860 Ginsberg DL. September. Primary Psychiatry. 2004;11(9):23-4. PMID:. X-1.
861 Gottlieb EL, Brazones MM, Malerman AJ, et al. Early orthodontic treatment, part 2. J Clin Orthod. Mar. 2004;38(3):135-54. X-1. [pmid: 15075487].
862 Gremeau-Richard C, Woda A, Navez ML, et al. Topical clonazepam in stomatodynia: a randomised placebo-controlled study. Pain. Mar. 2004;108(1-2):51-7. X-1. [pmid: 15109507].
863 Haghighi K, Milles M, Cleveland D, et al. Epignathus teratoma with bifid tongue and median glossal salivary mass: report of a case. J Oral Maxillofac Surg. Mar. 2004;62(3):379-83. X-1. [pmid: 15015174].
864 Hanemann JA, Oliveira DT, Gomes MF, et al. Congenital double lip associated to hemangiomas: report of a case. Med Oral. Mar-Apr. 2004;9(2):156-8. 5. 6. X-1. [pmid: 14990882].
865 Hilgers JJ, Tracey SG. Clinical uses of diode lasers in orthodontics. J Clin Orthod. May. 2004;38(5):266-73. X-1. [pmid: 15178881].
866 Kita H, Kochi S, Yamada A, et al. Mandibular widening by distraction osteogenesis in the treatment of a constricted mandible and telescopic bite. Cleft Palate Craniofac J. Nov. 2004;41(6):664-73. X-1. [pmid: 15516173].
867 Konst EM, Prahl C, Weersink-Braks H, et al. Cost-effectiveness of infant orthopedic treatment regarding speech in patients with complete unilateral cleft lip and palate: a randomized three-center trial in the Netherlands (Dutchcleft). Cleft Palate Craniofac J. Jan. 2004;41(1):71-7. X-1. [pmid: 14697066].
868 Lisson JA, Hanke I, Trankmann J. Vertical changes in patients with complete unilateral and bilateral cleft lip, alveolus and palate. J Orofac Orthop. May. 2004;65(3):246-58. X-1. [pmid: 15160251].
869 Lohmander A, Lillvik M, Friede H. The impact of early infant jaw-orthopaedics on early speech production in toddlers with unilateral cleft lip and palate. Clin Linguist Phon. Jun-Aug. 2004;18(4-5):259-84. X-1. [pmid: 15259572].
870 Malfait F, De Coster P, Hausser I, et al. The natural history, including orofacial features of three patients with Ehlers-Danlos syndrome, dermatosparaxis type (EDS type VIIC). Am J Med Genet A. Nov. 15. 2004;131(1):18-28. X-1. [pmid: 15389701].
871 Martinez EA, Moore BC, Schaumloffel J, et al. Effects of exposure to a combination of zinc- and lead-spiked sediments on mouthpart development and growth in Chironomus tentans. Environ Toxicol Chem. Mar. 2004;23(3):662-7. X-1. [pmid: 15285360].
872 Murphy SM, Rea S, McGovern E, et al. Cleft palate and congenital synechiae syndrome: a case report. Cleft Palate Craniofac J. Mar. 2004;41(2):206-7. X-1. [pmid: 14989681].
873 Nduka CV, Cohen PR. Advisor forum. Refractory lip blister. Clinical Advisor for Nurse Practitioners. 2004;7(5):53-5. PMID:. X-1.
874 Parrini S, Di Maggio G, Latini G, et al. Abnormal oral mucosal light reflectance in infantile hypertrophic pyloric stenosis. J Pediatr Gastroenterol Nutr. Jul. 2004;39(1):53-5. X-1. [pmid: 15187781].
875 Randerath WJ, Galetke W, Domanski U, et al. Tongue-muscle training by intraoral electrical neurostimulation in patients with obstructive sleep apnea. Sleep. Mar. 15. 2004;27(2):254-9. X-1. [pmid: 15124719].
876 Reichwage DP, Barjenbruch T, Lemberg K, et al. Esthetic contemporary dentistry and soft tissue recontouring with the diode laser. J Indiana Dent Assoc. Spring. 2004;83(1):13-5. X-1. [pmid: 15266733].
877 Riley JL III, Gilbert GH, Heft MW. Oral health attitudes and communication with laypersons about orofacial pain among middle-aged and older adults. Pain. 2004;107(1-2):116-24. PMID:. X-1. [pmid: 14715397].
878 Rogers JM, Brannen KC, Barbee BD, et al. Methanol exposure during gastrulation causes holoprosencephaly, facial dysgenesis, and cervical vertebral malformations in C57BL/6J mice. Birth Defects Res B Dev Reprod Toxicol. Apr. 2004;71(2):80-8. X-1. [pmid: 15098201].
879 Salamone FN, Myer CM 3rd. Van der Woude syndrome: the most common cleft syndrome. Otolaryngol Head Neck Surg. Jul. 2004;131(1):141. X-1. [pmid: 15243571].
880 Sharon-Buller A, Sela M. CO2-laser treatment of ulcerative lesions. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Mar. 2004;97(3):332-4. X-1. [pmid: 15024356].
881 Shashikiran ND, Subba Reddy VV, Patil R. “Moebius syndrome”: a case report. J Indian Soc Pedod Prev Dent. Sep. 2004;22(3):96-9. X-1. [pmid: 15573654].
882 Sorrenti G, Piccin O, Scaramuzzino G, et al. Tongue base reduction with hyoepiglottoplasty for the treatment of severe OSA. Acta Otorhinolaryngol Ital. Aug. 2004;24(4):204-10. X-1. [pmid: 15688905].
883 van Hagen MA, Janss LL, van den Broek J, et al. The use of a genetic-counselling program by Dutch breeders for four hereditary health problems in boxer dogs. Prev Vet Med. Apr. 30. 2004;63(1-2):39-50. X-1. [pmid: 15099715].
884 Van Hougenhouck-Tulleken W, Chan I, Hamada T, et al. Clinical and molecular characterization of lipoid proteinosis in Namaqualand, South Africa. Br J Dermatol. Aug. 2004;151(2):413-23. X-1. [pmid: 15327549].
885 Velepic MS, Sasso A, Velepic MM, et al. Combined anomalies of the palate in Mohr syndrome: is preoperative electromyography of the palate useful?. J Pediatr Surg. Feb. 2004;39(2):220-2. X-1. [pmid: 14966745].
886 Walinski CJ. Dental lasers: possibilities and benefits. J Mass Dent Soc. Fall. 2004;53(3):6-8. X-2, X-2. [pmid: 15503933].
887 Zaffe D, Vitale MC, Martignone A, et al. Morphological, histochemical, and immunocytochemical study of CO2 and Er:YAG laser effect on oral soft tissues. Photomed Laser Surg. Jun. 2004;22(3):185-9. X-1. [pmid: 15315724].
888 A POEM for your practice: patient-oriented evidence that matters. Tongue-tie in a newborn has minimal effect on breastfeeding success. Contemp Pediatr. 2005;22(5):96. PMID:. X-1.
889 Tongue-tie in babies is distressing but simple to repair. Australian Midwifery News. 2005;5(3):29. PMID:. X-1.
890 Acikgoz A, Ozden FO, Fisgin T, et al. Oral and dental findings in Fanconi's anemia. Pediatr Hematol Oncol. Sep. 2005;22(6):531-9. X-1. [pmid: 16169820].
891 Ahluwalia K, Ro M, Erwin K, et al. Racial disparities in oral cancer risk and outcomes. J Cancer Educ. Summer. 2005;20(2):70-1. X-1. [pmid: 16083368].
892 Azevedo RA, Souza VF, Sarmento VA, et al. Hemifacial hyperplasia: a case report. Quintessence Int. Jun. 2005;36(6):483-6. X-1. [pmid: 15954255].
893 Azorin D, Enriquez de Salamanca J, de Prada I, et al. Congenital melanotic macules and Sebaceous Choristoma arising on the tongue of a newborn: epidermal choristoma?. J Cutan Pathol. Mar. 2005;32(3):251-3. X-1. [pmid: 15701089].
894 Barakzai SZ, Dixon PM. Conservative treatment for thoroughbred racehorses with intermittent dorsal displacement of the soft palate. Vet Rec. Sep. 17. 2005;157(12):337-40. X-1. [pmid: 16170000].
895 Bots CP, Brand HS, Veerman EC, et al. The management of xerostomia in patients on haemodialysis: comparison of artificial saliva and chewing gum. Palliat Med. Apr. 2005;19(3):202-7. X-1. [pmid: 15920934].
896 Bressmann T, Thind P, Uy C, et al. Quantitative three-dimensional ultrasound analysis of tongue protrusion, grooving and symmetry: data from 12 normal speakers and a partial glossectomee. Clin Linguist Phon. Sep-Nov. 2005;19(6-7):573-88. X-1. [pmid: 16206485].
897 Bressmann T, Uy C, Irish JC. Analysing normal and partial glossectomee tongues using ultrasound. Clin Linguist Phon. 2005;19(1):35-52. PMID:. X-1. [pmid: 15702826].
898 Charrow J. A 22-month-old boy with slow development. Pediatr Ann. Apr. 2005;34(4):270. 3. X-1. [pmid: 15871431].
899 Chuangsuwanich T, Sunsaneevithayakul P, Muangsomboon K, et al. Ectrodactyly-ectodermal dysplasia-clefting (EEC) syndrome presenting with a large nephrogenic cyst, severe oligohydramnios and hydrops fetalis: a case report and review of the literature. Prenat Diagn. Mar. 2005;25(3):210-5. X-1. [pmid: 15791665].
900 Deinzer R, Granrath N, Spahl M, et al. Stress, oral health behaviour and clinical outcome. Br J Health Psychol. May. 2005;10(Pt 2):269-83. X-1. [pmid: 15969854].
901 Dierks EJ. No convincing premise for efficacy of prophylactic adenotonsillar ablation. Arch Otolaryngol Head Neck Surg. Oct. 2005;131(10):918. X-1. [pmid: 16230598].
902 Drevensek M, Papic JS. The influence of the respiration disturbances on the growth and development of the orofacial complex. Coll Antropol. Jun. 2005;29(1):221-5. X-1. [pmid: 16117326].
903 Edwards PD, Rahbar R, Ferraro NF, et al. Lymphatic malformation of the lingual base and oral floor. Plast Reconstr Surg. Jun. 2005;115(7):1906-15. X-1. [pmid: 15923836].
904 Ferguson MM, Ponnambalam Y. Aplasia of the parotid gland in Down syndrome. Br J Oral Maxillofac Surg. Apr. 2005;43(2):113-7. X-1. [pmid: 15749210].
905 Girshin M, Parikh SR, Leyvi G, et al. Intraoperative oxygen desaturation and electrocardiographic changes in a patient with Hanhart syndrome. J Cardiothorac Vasc Anesth. Aug. 2005;19(4):546-7. X-1. [pmid: 16085267].
906 Gontijo I, Navarro RS, Haypek P, et al. The applications of diode and Er:YAG lasers in labial frenectomy in infant patients. J Dent Child (Chic). Jan-Apr. 2005;72(1):10-5. X-1. [pmid: 16119069].
907 Gurlek A, Alaybeyoglu NY, Demir CY, et al. The continuing scourge of congenital syphilis in 21st century: a case report. Int J Pediatr Otorhinolaryngol. Aug. 2005;69(8):1117-21. X-1. [pmid: 16005354].
908 Jackson IT, Keskin M, Yavuzer R, et al. Compartmentalization of massive vascular malformations. Plast Reconstr Surg. Jan. 2005;115(1):10-21. X-1. [pmid: 15622226].
909 Kamata S, Kamiyama M, Sawai T, et al. Assessment of obstructive apnea by using polysomnography and surgical treatment in patients with Beckwith-Wiedemann syndrome. J Pediatr Surg. Mar. 2005;40(3):E17-9. X-1. [pmid: 15793707].
910 Kwak IS, Lee W. Mouthpart deformity and developmental retardation exposure of Chironomus plumosus (Diptera: Chironomidae) to tebufenozide. Bull Environ Contam Toxicol. Nov. 2005;75(5):859-65. X-1. [pmid: 16400571].
911 Lancioni GE, Smaldone A, O'Reilly MF, et al. Automatic prompting to reduce persistent tongue protrusion in a woman with severe to profound mental retardation. Percept Mot Skills. Oct. 2005;101(2):515-8. X-1. [pmid: 16383088].
912 Marchesan IQ. Lingual frenulum: quantitative evaluation proposal. Int J Orofacial Myology. Nov. 2005;31:39-48. X-1. [pmid: 16739711].
913 Merritt L. Part 1. Understanding the embryology and genetics of cleft lip and palate. Adv Neonatal Care. Apr. 2005;5(2):64-71. X-1. [pmid: 15806447].
914 Mintz SM, Siegel MA, Seider PJ. An overview of oral frena and their association with multiple syndromic and nonsyndromic conditions. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Mar. 2005;99(3):321-4. X-2, X-2. [pmid: 15716839].
915 Mumcu G, Cimilli H, Sur H, et al. Prevalence and distribution of oral lesions: a cross-sectional study in Turkey. Oral Dis. Mar. 2005;11(2):81-7. X-1. [pmid: 15752080].
916 Mylniczenko ND, Manharth AL, Clayton LA, et al. Successful treatment of mandibular squamous cell carcinoma in a Malayan sun bear (Helarctos malayanus). J Zoo Wildl Med. Jun. 2005;36(2):346-8. X-1. [pmid: 17323584].
917 Niccoli-Filho W, Murilo-Santos L, Schubert M, et al. Treatment of developmental defect of upper lip with carbon dioxide laser radiation (CO2): first surgical time. J Cosmet Laser Ther. Jun. 2005;7(2):97-100. X-1. [pmid: 16537216].
918 Niikura K, Takeshita N, Chida N. A novel inhibitor of vacuolar ATPase, FR202126, prevents alveolar bone destruction in experimental periodontitis in rats. J Toxicol Sci. Dec. 2005;30(4):297-304. X-1. [pmid: 16404138].
919 Nixon IJ, Wynne DM, Geddes NK. Labial pit and ectopic salivary gland tissue. Int J Pediatr Otorhinolaryngol. Jan. 2005;69(1):127-30. X-1. [pmid: 15627461].
920 Oberoi S, Vargervik K. Hypoplasia and hypodontia in Van der Woude syndrome. Cleft Palate Craniofac J. Sep. 2005;42(5):459-66. X-1. [pmid: 16149825].
921 Oberoi S, Vargervik K. Velocardiofacial syndrome with single central incisor. Am J Med Genet A. Jan. 15. 2005;132a(2):194-7. X-1. [pmid: 15578625].
922 Olshan AF, Shaw GM, Millikan RC, et al. Polymorphisms in DNA repair genes as risk factors for spina bifida and orofacial clefts. Am J Med Genet A. Jun. 15. 2005;135(3):268-73. X-1. [pmid: 15887293].
923 Ruscello DM, Douglas C, Tyson T, et al. Macroglossia: a case study. J Commun Disord. Mar-Apr. 2005;38(2):109-22. X-1. [pmid: 15571712].
924 Shott SR. Pediatric sleep disordered breathing -- macroglossia. Operative Techniques in Otolaryngology - Head & Neck Surgery. 2005;16(4):251-6. PMID:. X-1.
925 Singh DJ, Bartlett SP. Congenital mandibular hypoplasia: analysis and classification. J Craniofac Surg. Mar. 2005;16(2):291-300. X-1. [pmid: 15750428].
926 Stone M. A guide to analysing tongue motion from ultrasound images. Clin Linguist Phon. Sep-Nov. 2005;19(6-7):455-501. X-1. [pmid: 16206478].
927 Tanrikulu R, Erol B, Gorgun B, et al. Congenital alveolar synechiae - a case report. Br Dent J. Jan. 22. 2005;198(2):81-2. X-1. [pmid: 15702100].
928 Ugar-Cankal D, Denizci S, Hocaoglu T. Prevalence of tongue lesions among Turkish schoolchildren. Saudi Med J. Dec. 2005;26(12):1962-7. X-1. [pmid: 16380783].
929 Zhu H, Curry S, Wen S, et al. Are the betaine-homocysteine methyltransferase (BHMT and BHMT2) genes risk factors for spina bifida and orofacial clefts?. Am J Med Genet A. Jun. 15. 2005;135(3):274-7. X-1. [pmid: 15887275].
930 Ziai MN, Benson AG, Djalilian HR. Congenital lip pits and van der Woude syndrome. J Craniofac Surg. Sep. 2005;16(5):930-2. X-1. [pmid: 16192885].
931 Editorial. Clin Linguist Phon. 2006;20(2-3):89. PMID:. X-1, X-2.
932 Abdolsamadi H, Hamian M. An investigation on therapeutic effect of zinc sulfate in patients with geographic tongue. J Dent (Tehran). 2006;18(4):63. PMID:. X-1.
933 Alpoz AR, Coker M, Celen E, et al. The oral manifestations of Maroteaux-Lamy syndrome (mucopolysaccharidosis VI): a case report. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. May. 2006;101(5):632-7. X-1. [pmid: 16632276].
934 Azrak B, Kaevel K, Hofmann L, et al. Dystrophic epidermolysis bullosa: oral findings and problems. Spec Care Dentist. May-Jun. 2006;26(3):111-5. X-1. [pmid: 16774188].
935 Bagga S, Bhat KM, Bhat GS, et al. Esthetic management of the upper labial frenum: a novel frenectomy technique. Quintessence Int. Nov-Dec. 2006;37(10):819-23. X-1. [pmid: 17078281].
936 Bower C, Miller M, Payne J, et al. Folate intake and the primary prevention of non-neural birth defects. Aust N Z J Public Health. Jun. 2006;30(3):258-61. X-1. [pmid: 16800203].
937 Bressmann T. Speech adaptation to a self-inflicted cosmetic tongue split: perceptual and ultrasonographic analysis. Clin Linguist Phon. Apr-May. 2006;20(2-3):205-10. X-1. [pmid: 16428238].
938 Cannella HI, O'Reilly MF, Lancioni GE. Treatment of hand mouthing in individuals with severe to profound developmental disabilities: a review of the literature. Res Dev Disabil. Sep-Oct. 2006;27(5):529-44. X-1. [pmid: 16188422].
939 Charrier JB, Rouillon I, Roger G, et al. Congenital isolated midline sinus of the upper lip: clinical and embryological approaches. Cleft Palate Craniofac J. Jul. 2006;43(4):488-91. X-1. [pmid: 16854208].
940 Chidzonga MM, Mahomva L. Congenital double lower lip: report of a case. Int J Paediatr Dent. Nov. 2006;16(6):448-9. X-1. [pmid: 17014546].
941 Covelli E, Leonardi A, Indrizzi E, et al. Unknown posttraumatic foreign body in facial region. J Craniofac Surg. Jan. 2006;17(1):191-4. X-1. [pmid: 16432434].
942 Engelking LJ, Evers BM, Richardson JA, et al. Severe facial clefting in Insig-deficient mouse embryos caused by sterol accumulation and reversed by lovastatin. J Clin Invest. Sep. 2006;116(9):2356-65. X-1. [pmid: 16955138].
943 Fallon T, Buikstra E, Cameron M, et al. Implementation of oral health recommendations into two residential aged care facilities in a regional Australian city. Int J Evid Based Healthc. Sep. 2006;4(3):162-79. X-1. [pmid: 21631764].
944 Faye-Petersen O, David E, Rangwala N, et al. Otocephaly: report of five new cases and a literature review. Fetal Pediatr Pathol. Sep-Oct. 2006;25(5):277-96. X-1. [pmid: 17438667].
945 Ghassibe M, Bayet B, Revencu N, et al. Orofacial clefting: update on the role of genetics. B-ent. Suppl 4. 2006;2:20-4. X-1. [pmid: 17366841].
946 Goraya JS, Virdi V, Parmar V. Recurrent nocturnal tongue biting in a child with hereditary chin trembling. J Child Neurol. Nov. 2006;21(11):985-7. X-1. [pmid: 17092470].
947 Griffin JD Jr. Correction of congenitally missing lateral incisors with porcelain veneers. Pract Proced Aesthet Dent. Sep. 2006;18(8):475-80. quiz 81. X-1. [pmid: 17061684].
948 Halkjaer L, Melsen B, McMillan AS, et al. Influence of sensory deprivation and perturbation of trigeminal afferent fibers on corticomotor control of human tongue musculature. Exp Brain Res. Apr. 2006;170(2):199-205. X-1. [pmid: 16328282].
949 Harner C. Not a folk belief… “Ankyloglossia: to clip or not to clip? That's the question” in the Dec. 27, 2005 issue of The ASHA Leader. ASHA Lead. 2006;11(3):4. PMID:. X-1.
950 Higashikawa M, Hadano K, Hatta T. The core factor of improvement in recovery from aphasia extracted by factor analysis. Psychologia. 2006;49(3):143-51. PMID:. X-1.
951 Johnson PRV. Tongue-tie -- exploding the myths. Infant. 2006;2(3):96-9. PMID:. X-1, X-2.
952 Kirbschus A, Gesch D, Kaduk W, et al. The influence of craniofacial growth in a case of transverse facial cleft. J Orofac Orthop. May. 2006;67(3):215-24. X-1. [pmid: 16736122].
953 Kirzioglu Z, Erturk MS. Congenital lower lip pits (Van der Woude syndrome): report of a case. J Contemp Dent Pract. Feb. 15. 2006;7(1):134-40. X-1. [pmid: 16491156].
954 Kormanik KE, Bersu ET, Bentz ML. Dermoid sinus and cyst of the lip. J Craniofac Surg. Jan. 2006;17(1):162-6. X-1. [pmid: 16432426].
955 Kupers R, Fumal A, de Noordhout AM, et al. Transcranial magnetic stimulation of the visual cortex induces somatotopically organized qualia in blind subjects. Proc Natl Acad Sci USA. 2006;103(35):13256-60. X-1. [pmid: 16916936].
956 Lahiri A, Kok K, Sharp I, et al. Acute exacerbation of macroglossia leading to necrosis of the anterior third of the tongue. J Plast Reconstr Aesthet Surg. 2006;59(8):871-3. X-1. [pmid: 16876088].
957 Lancioni GE, O'Reilly MF, Singh NN, et al. Microswitch clusters promote adaptive responses and reduce finger mouthing in a boy with multiple disabilities. Behav Modif. Nov. 2006;30(6):892-900. X-1. [pmid: 17050769].
958 Lazarus C. Tongue strength and exercise in healthy individuals and in head and neck cancer patients. Semin Speech Lang. Nov. 2006;27(4):260-7. X-1. [pmid: 17117352].
959 Lin DD, Gailloud P, McCarthy EF, et al. Oromaxillofacial osseous abnormality in Sturge-Weber syndrome: case report and review of the literature. AJNR Am J Neuroradiol. Feb. 2006;27(2):274-7. X-1. [pmid: 16484391].
960 Lo YL, Fook-Chong S. Magnetic brainstem stimulation of the hypoglossal nerve in normal subjects. Eur J Neurol. Apr. 2006;13(4):419-22. X-1. [pmid: 16643323].
961 Lopez-Jornet P, Camacho-Alonso F. Oral and dental complications of intra-oral piercing. J Adolesc Health. Nov. 2006;39(5):767-9. X-1. [pmid: 17046520].
962 Mandel L. An unusual pattern of dental damage with salivary gland aplasia. J Am Dent Assoc. Jul. 2006;137(7):984-9. X-1. [pmid: 16803825].
963 Marneros A, Gutmann P, Uhlmann F. Self-amputation of penis and tongue after use of Angel's Trumpet. Eur Arch Psychiatry Clin Neurosci. Oct. 2006;256(7):458-9. X-1. [pmid: 16783491].
964 Martorelli de Lima AF, da Silva RC, Joly JC, et al. Coronally positioned flap with subepithelial connective tissue graft for root coverage: various indications and flap designs. J Int Acad Periodontol. Apr. 2006;8(2):53-60. X-1. [pmid: 16623180].
965 Mohta A, Sharma M. Congenital oral cysts in neonates: report of two cases. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Nov. 2006;102(5):e36-8. X-1. [pmid: 17052622].
966 Ng ML, Bailey RL. Acoustic changes related to laryngeal examination with a rigid telescope. Folia Phoniatr Logop. 2006;58(5):353-62. X-1. [pmid: 16966836].
967 Niikura K. Comparative analysis of the effects of a novel vacuolar adenosine 5'-triphosphatase inhibitor, FR202126, and doxycycline on bone loss caused by experimental periodontitis in rats. J Periodontol. Jul. 2006;77(7):1211-6. X-1. [pmid: 16805684].
968 Noguchi T, Jinbu Y, Itoh H, et al. Epignathus combined with cleft palate, lobulated tongue, and lingual hamartoma: report of a case. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Apr. 2006;101(4):481-6. X-1. [pmid: 16545713].
969 Oji C, Chukwuneke F, Mgbor N. Tobacco-pouch suture technique for the treatment of vascular lesions of the lip in Enugu, Nigeria. Br J Oral Maxillofac Surg. Jun. 2006;44(3):245-7. X-1. [pmid: 16009473].
970 Park JW, Cai J, McIntosh I, et al. High throughput SNP and expression analyses of candidate genes for non-syndromic oral clefts. J Med Genet. Jul. 2006;43(7):598-608. X-1. [pmid: 16415175].
971 Potting CM, Uitterhoeve R, Op Reimer WS, et al. The effectiveness of commonly used mouthwashes for the prevention of chemotherapy-induced oral mucositis: a systematic review. Eur J Cancer Care (Engl). Dec. 2006;15(5):431-9. X-1. [pmid: 17177899].
972 Pugh P, Watson AR. Transition from gastrostomy to oral feeding following renal transplantation. Adv Perit Dial. 2006;22:153-7. X-1. [pmid: 16983960].
973 Rifai S, Bouayad H, Kay G, et al. Bifid tongue and mandibular cleft in three mule foals. Vet Rec. Jan. 21. 2006;158(3):97-8. X-1. [pmid: 16428665].
974 Sala Marti S, Merino Tessore MD, Escuin Henar T. Prosthetic assessment in cleft lip and palate patients: a case report with oronasal communication. Med Oral Patol Oral Cir Bucal. Nov-Dec. 2006;11(6):E493-6. X-1. [pmid: 17072253].
975 Shipster C, Oliver B, Morgan A. Speech and oral motor skills in children with Beckwith Wiedemann Syndrome: Pre- and post-tongue reduction surgery. Advances in Speech Language Pathology. 2006;8(1):45-55. PMID:. X-1.
976 Silverman EP, Sapienza CM, Saleem A, et al. Tutorial on maximum inspiratory and expiratory mouth pressures in individuals with idiopathic Parkinson disease (IPD) and the preliminary results of an expiratory muscle strength training program. NeuroRehabilitation. 2006;21(1):71-9. X-1. [pmid: 16720940].
977 Suda N, Takada J, Ohyama K. Orthodontic treatment in a patient with Van der Woude's syndrome. Am J Orthod Dentofacial Orthop. May. 2006;129(5):696-705. X-1. [pmid: 16679212].
978 Suraseranivongse S, Kaosaard R, Intakong P, et al. A comparison of postoperative pain scales in neonates. Br J Anaesth. Oct. 2006;97(4):540-4. X-1. [pmid: 16885171].
979 Szarmach IJ, Wawrzyn-Sobczak K, Kaczynska J, et al. Recession occurrence in patients treated with fixed appliances--preliminary report. Adv Med Sci. Suppl 1. 2006;51:213-6. X-1. [pmid: 17458093].
980 Tan SS, Tan HK, Lim CS, et al. A novel stent for the treatment of persistent buccopharyngeal membrane. Int J Pediatr Otorhinolaryngol. Sep. 2006;70(9):1645-9. X-1. [pmid: 16797730].
981 Tirone L, Moscatiello F, Molea G. Reconstruction of the upper lip and philtrum. J Plast Reconstr Aesthet Surg. 2006;59(8):865-6. X-1. [pmid: 16876086].
982 Tomlinson JK, Liem NT, Savarirayan R, et al. Isolated and syndromic syngnathism: management, implications, and genetics. Ann Plast Surg. Aug. 2006;57(2):231-5. X-1. [pmid: 16862010].
983 Tuncali D, Barutcu AY, Terzioglu A, et al. Two cases of congenital midline upper lip sinuses associated with miscellaneous deformities. J Oral Maxillofac Surg. Apr. 2006;64(4):734-7. X-1. [pmid: 16546661].
984 Varkey P, Tan NC, Chen HC. Corrosive injury of oral cavity--a rare presentation. J Plast Reconstr Aesthet Surg. 2006;59(10):1110-3. X-1. [pmid: 16996438].
985 Whitehill TL, Ciocca V, Chan JC, et al. Acoustic analysis of vowels following glossectomy. Clin Linguist Phon. Apr-May. 2006;20(2-3):135-40. X-1. [pmid: 16428229].
986 Yamada T, Mishima K, Fujiwara K, et al. Cleft lip and palate in mice treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin: a morphological in vivo study. Congenit Anom (Kyoto). Mar. 2006;46(1):21-5. X-1. [pmid: 16643595].
987 Lamotrigine: birth defects. Prescrire Int. Apr. 2007;16(88):71. X-1. [pmid: 17465033].
988 Adler-Bock M, Bernhardt BM, Gick B, et al. The use of ultrasound in remediation of North American English /r/ in 2 adolescents. Am J Speech Lang Pathol. 2007;16(2):128-39. X-1. [pmid: 17456891].
989 Agag R, Sacks J, Silver L. Congenital midline cervical cleft. Cleft Palate Craniofac J. Jan. 2007;44(1):98-101. X-1. [pmid: 17214531].
990 Al Kaissi A, Ben Chehida F, Gharbi H, et al. Persistent torticollis, facial asymmetry, grooved tongue, and dolicho-odontoid process in connection with atlas malformation complex in three family subjects. Eur Spine J. Dec. Suppl 3. 2007;16:265-70. X-1. [pmid: 17245565].
991 Alacam A, Kolcuoglu N. Effects of two types of appliances on orofacial dysfunctions of disabled children. British Journal of Developmental Disabilities. 2007;53 part 2(105):111-23. PMID:. X-1.
992 Almeida AL, Madeira LC, Freitas KC, et al. Cross-sectional evaluation of the presence of gingival recession in individuals with cleft lip and palate. J Periodontol. Jan. 2007;78(1):29-36. X-1. [pmid: 17199536].
993 Andreou AM, Pauws E, Jones MC, et al. TBX22 missense mutations found in patients with X-linked cleft palate affect DNA binding, sumoylation, and transcriptional repression. Am J Hum Genet. Oct. 2007;81(4):700-12. X-1. [pmid: 17846996].
994 Brookes JT, Canady JW. Surgical correction of congenital lower lip sinuses in Van der Woude syndrome. Cleft Palate Craniofac J. Sep. 2007;44(5):555-7. X-1. [pmid: 17760491].
995 Burkhart N. Oral exams. Median rhomboid glossitis. RDH. 2007;27(7):58. PMID:. X-1.
996 Celli D, Gasperoni E, Deli R. Long-term outcome in a patient with a dentoskeletal open-bite malocclusion treated without extraction. World J Orthod. Winter. 2007;8(4):344-56. X-1. [pmid: 18092520].
997 Cheng KK. Oral mucositis and quality of life of Hong Kong Chinese patients with cancer therapy. Eur J Oncol Nurs. Feb. 2007;11(1):36-42. X-1. [pmid: 17258505].
998 Daneshpazhooh M, Nazemi TM, Bigdeloo L, et al. Mucocutaneous findings in 100 children with Down syndrome. Pediatr Dermatol. May-Jun. 2007;24(3):317-20. X-1. [pmid: 17542890].
999 de Entrambasaguas M, Plaza-Costa A, Casal J, et al. Labial dystonia after facial and trigeminal neuropathy controlled with a maxillary splint. Mov Disord. Jul. 15. 2007;22(9):1355-8. X-1. [pmid: 17486646].
1000 Demir T, Kecik D, Cehreli ZC. Kenny-Caffey Syndrome: oral findings and 4-year follow-up of overlay denture therapy. J Dent Child (Chic). Sep-Dec. 2007;74(3):236-40. X-1. [pmid: 18482522].
1001 Diniz MB, Lima LM, Sacono NT, et al. Clinical manifestations and oral findings in Fraser syndrome. J Dent Child (Chic). Sep-Dec. 2007;74(3):231-5. X-1. [pmid: 18482521].
1002 Emmorey K, Mehta S, Grabowski TJ. The neural correlates of sign versus word production. Neuroimage. May. 15. 2007;36(1):202-8. X-1. [pmid: 17407824].
1003 Eski M, Nisanci M, Aktas A, et al. Congenital double lip: review of 5 cases. Br J Oral Maxillofac Surg. Jan. 2007;45(1):68-70. X-1. [pmid: 15946777].
1004 Fliedner M, Baguet B, Blankart J, et al. Palifermin for patients with haematological malignancies: shifting nursing practice from symptom relief to prevention of oral mucositis. Eur J Oncol Nurs. 2007;11(Suppl1):S19-26. X-1. [pmid: 17540295].
1005 Ghosh A, Tibrewal SR, Thapa R. PHACES syndrome with congenital hypothyroidism. Indian Pediatr. Feb. 2007;44(2):144-7. X-1. [pmid: 17351309].
1006 Goold AL, Koch BL, Willging JP. Lingual hamartoma in an infant: CT and MR imaging. AJNR Am J Neuroradiol. Jan. 2007;28(1):30-1. X-1. [pmid: 17213419].
1007 Kahyaoglu O, Cavusoglu H, Musluman AM, et al. Transsellar transsphenoidal rhino-oral encephalocele. Turk Neurosurg. Oct. 2007;17(4):264-8. X-1. [pmid: 18050070].
1008 Kapferer I, Benesch T, Gregoric N, et al. Lip piercing: prevalence of associated gingival recession and contributing factors. A cross-sectional study. J Periodontal Res. Apr. 2007;42(2):177-83. X-1. [pmid: 17305877].
1009 Kara CO, Kara IG. Persistent buccopharyngeal membrane. Otolaryngol Head Neck Surg. Jun. 2007;136(6):1021-2. X-1. [pmid: 17548001].
1010 Kazi R, Prasad VM, Kanagalingam J, et al. Analysis of formant frequencies in patients with oral or oropharyngeal cancers treated by glossectomy. Int J Lang Commun Disord. Sep-Oct. 2007;42(5):521-32. X-1. [pmid: 17729144].
1011 Kennett J, Weinberg J. Advisor forum: follow-ups. Slow-healing split lip. Clinical Advisor for Nurse Practitioners. 2007;10(3):126. PMID:. X-1.
1012 Kivovics P, Jahn M, Borbely J, et al. Frequency and location of traumatic ulcerations following placement of complete dentures. Int J Prosthodont. Jul-Aug. 2007;20(4):397-401. X-1. [pmid: 17695871].
1013 Kreiger PA, Ernst LM, Elden LM, et al. Hamartomatous tongue lesions in children. Am J Surg Pathol. Aug. 2007;31(8):1186-90. X-1. [pmid: 17667541].
1014 Letra A, de Almeida AL, Kaizer R, et al. Intraoral features of Apert's syndrome. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. May. 2007;103(5):e38-41. X-1. [pmid: 17466880].
1015 Martelli-Junior H, Chaves MR, Swerts MS, et al. Clinical and genetic features of Van der Woude syndrome in two large families in Brazil. Cleft Palate Craniofac J. May. 2007;44(3):239-43. X-1. [pmid: 17477759].
1016 Mitchell C, Oeltjen J, Panthaki Z, et al. Nasolabial aesthetics. J Craniofac Surg. Jul. 2007;18(4):756-65. X-1. [pmid: 17667661].
1017 Moorman VJ, Marshall JF, Jann HW. Persistent dorsal displacement of the soft palate attributable to a frenulum of the epiglottis in a racing Thoroughbred. J Am Vet Med Assoc. Sep. 1. 2007;231(5):751-4. X-1. [pmid: 17764438].
1018 Mouly SJ, Orler JB, Tillet Y, et al. Efficacy of a new oral lubricant solution in the management of psychotropic drug-induced xerostomia: a randomized controlled trial. J Clin Psychopharmacol. Oct. 2007;27(5):437-43. X-1. [pmid: 17873673].
1019 Ninkovic M, Spanio di Spilimbergo S, Ninkovic M. Lower lip reconstruction: introduction of a new procedure using a functioning gracilis muscle free flap. Plast Reconstr Surg. Apr. 15. 2007;119(5):1472-80. X-1. [pmid: 17415241].
1020 Okano J, Suzuki S, Shiota K. Involvement of apoptotic cell death and cell cycle perturbation in retinoic acid-induced cleft palate in mice. Toxicol Appl Pharmacol. May. 15. 2007;221(1):42-56. X-1. [pmid: 17442359].
1021 O'Neill A, de Leon J. Two case reports of oral ulcers with lamotrigine several weeks after oxcarbazepine withdrawal. Bipolar Disord. May. 2007;9(3):310-3. X-1. [pmid: 17430308].
1022 Pradhan M, Sankar H. Short humerus: an additional antenatal sonographic feature of OFDS type II. J Clin Ultrasound. Sep. 2007;35(7):390-4. X-1. [pmid: 17410589].
1023 Pratap A, Agrawal A, Bhatta N, et al. Congenital unilateral lower lip palsy and eventration of diaphragm. Singapore Med J. Aug. 2007;48(8):e209-11. X-1. [pmid: 17657367].
1024 Richter GT, Suen J, North PE, et al. Arteriovenous malformations of the tongue: a spectrum of disease. Laryngoscope. Feb. 2007;117(2):328-35. X-1. [pmid: 17277629].
1025 Roing M, Hirsch JM, Holmstrom I. The uncanny mouth - a phenomenological approach to oral cancer. Patient Educ Couns. Aug. 2007;67(3):301-6. X-1. [pmid: 17374473].
1026 Romero M, Franco B, del Pozo JS, et al. Buccal anomalies, cephalometric analysis and genetic study of two sisters with orofaciodigital syndrome type I. Cleft Palate Craniofac J. Nov. 2007;44(6):660-6. X-1. [pmid: 18177199].
1027 Sakaguchi K, Mehta NR, Abdallah EF, et al. Examination of the relationship between mandibular position and body posture. Cranio. Oct. 2007;25(4):237-49. X-1. [pmid: 17983123].
1028 Senoo H, Iida S, Kishino M, et al. Solitary congenital granular cell lesion of the tongue. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Jul. 2007;104(1):e45-8. X-1. [pmid: 17577543].
1029 Shaiova L, Mori M, Anderson K, et al. Administration of morphine sulfate extended-release capsules via gastrostomy: dissolution study and case reports. J Palliat Med. Oct. 2007;10(5):1063-7. X-1. [pmid: 17985962].
1030 Sharma CG, Pradeep AR. Localized attachment loss in Pendred syndrome: incidental?. J Periodontol. May. 2007;78(5):948-54. X-1. [pmid: 17470031].
1031 Simpson AP, Meinhold G. Compensatory articulations in a case of congenital aglossia. Clin Linguist Phon. Jul. 2007;21(7):543-56. X-1. [pmid: 17564856].
1032 Sparling JD, Hong CH, Brahim JS, et al. Oral findings in 58 adults with tuberous sclerosis complex. J Am Acad Dermatol. May. 2007;56(5):786-90. X-1. [pmid: 17239986].
1033 Steinmetz J, Holm-Knudsen R, Sorensen MK, et al. Hemodynamic differences between propofol-remifentanil and sevoflurane anesthesia for repair of cleft lip and palate in infants. Paediatr Anaesth. Jan. 2007;17(1):32-7. X-1. [pmid: 17184429].
1034 Stevenson DA, Bleyl SB, Maxwell T, et al. Mandibulofacial dysostosis in a patient with a de novo 2;17 translocation that disrupts the HOXD gene cluster. Am J Med Genet A. May. 15. 2007;143a(10):1053-9. X-1. [pmid: 17431905].
1035 Udagawa A, Arikawa K, Shimizu S, et al. A simple reconstruction for congenital unilateral lower lip palsy. Plast Reconstr Surg. Jul. 2007;120(1):238-44. X-1. [pmid: 17572570].
1036 Villa MP, Malagola C, Pagani J, et al. Rapid maxillary expansion in children with obstructive sleep apnea syndrome: 12-month follow-up. Sleep Med. Mar. 2007;8(2):128-34. X-1. [pmid: 17239661].
1037 Viltuznik J, Weinberg JM. Advisor forum: treating Fordyce gland hyperplasia. Clinical Advisor for Nurse Practitioners. 2007;10(10):95. PMID:. X-1.
1038 Wrench AA. Advances in EPG palate design. Advances in Speech Language Pathology. 2007;9(1):3-12. PMID:. X-1.
1039 Zaidi FN, Krimm RF, Whitehead MC. Exuberant neuronal convergence onto reduced taste bud targets with preservation of neural specificity in mice overexpressing neurotrophin in the tongue epithelium. J Neurosci. Dec. 12. 2007;27(50):13875-81. X-1. [pmid: 18077699].
1040 Formulations. Miconazole nitrate 2%, deoxy-D-glucose 0.2%, and hydrocortisone 0.4% lip balm. Int J Pharm Compd. 2008;12(3):265. PMID:. X-1.
1041 letters. Midwifery Matters. 2008;(117):31. PMID:. X-1, X-2.
1042 Bolwig TG. Electroconvulsive therapy: an option in pain management. Acta Psychiatr Scand. Dec. 2008;118(6):505-6. X-1. [pmid: 19032705].
1043 Choi Y, Dodd V, Watson J, et al. Perspectives of African Americans and dentists concerning dentist-patient communication on oral cancer screening. Patient Educ Couns. Apr. 2008;71(1):41-51. X-1. [pmid: 18242933].
1044 Cole A, Lynch P, Slator R. A new grading of Pierre Robin sequence. Cleft Palate Craniofac J. Nov. 2008;45(6):603-6. X-1. [pmid: 18956939].
1045 Cozzi F, Totonelli G, Frediani S, et al. The effect of glossopexy on weight velocity in infants with Pierre Robin syndrome. J Pediatr Surg. Feb. 2008;43(2):296-8. X-1. [pmid: 18280277].
1046 da Silva Dalben G, Richieri-Costa A, de Assis Taveira LA. Tooth abnormalities and soft tissue alterations in patients with G/BBB syndrome. Oral Dis. Nov. 2008;14(8):747-53. X-1. [pmid: 18627501].
1047 da Silva Dalben G, Richieri-Costa A, de Assis Taveira LA. Tooth abnormalities and soft tissue changes in patients with velocardiofacial syndrome. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Aug. 2008;106(2):e46-51. X-1. [pmid: 18554940].
1048 ElHassan NO, Jones LR, Ray RM, et al. A neonate with microphthalmia and median clefting of the lower lip and mandible. Am J Perinatol. Jan. 2008;25(1):1-4. X-1. [pmid: 18050036].
1049 Faulks D, Collado V, Mazille MN, et al. Masticatory dysfunction in persons with Down's syndrome. Part 1: aetiology and incidence. J Oral Rehabil. Nov. 2008;35(11):854-62. X-1. [pmid: 18702629].
1050 Fearon JA. Rare craniofacial clefts: a surgical classification. J Craniofac Surg. Jan. 2008;19(1):110-2. X-1. [pmid: 18216674].
1051 Fontenelle LF, Leite MAA. Treatment-resistant self-mutilation, tics, and obsessive-compulsive disorder in neuroacanthocytosis: A mouth guard as a therapeutic approach. J Clin Psychiatry. 2008;69(7):1186-7. PMID:. X-1. [pmid: 18687019].
1052 Fujioka M, Oka K, Kitamura R, et al. Upper lip pressure ulcers in very low birth weight infants due to fixation of the endotracheal tube. J Neonatal Nurs. 2008;14(6):207-10. PMID:. X-1.
1053 Genc G, Sarac A, Erkek Atay N, et al. Floating-Harbor syndrome: case report. Minerva Pediatr. Apr. 2008;60(2):249-51. X-1. [pmid: 18449141].
1054 Gillison ML. Human papillomavirus-related diseases: Oropharynx cancers and potential implications for adolescent HPV vaccination. J Adolesc Health. 2008;43(4, Suppl 1):S52-S60. X-1. [pmid: 18809146].
1055 Gkantidis N, Kolokitha OE, Topouzelis N. Management of maxillary midline diastema with emphasis on etiology. J Clin Pediatr Dent. Summer. 2008;32(4):265-72. X-1, X-2. [pmid: 18767455].
1056 Grewal J, Carmichael SL, Ma C, et al. Maternal periconceptional smoking and alcohol consumption and risk for select congenital anomalies. Birth Defects Res A Clin Mol Teratol. Jul. 2008;82(7):519-26. X-1. [pmid: 18481814].
1057 Hennings JM, Krause E, Botzel K, et al. Successful treatment of tardive lingual dystonia with botulinum toxin: case report and review of the literature. Prog Neuropsychopharmacol Biol Psychiatry. Jul. 1. 2008;32(5):1167-71. X-1. [pmid: 17936461].
1058 Hillan R. Division of tongue tie: wicked and barbaric?. Pract Midwife. Nov. 2008;11(10):22-5. X-1. [pmid: 19054951].
1059 Isik D, Bulut O, Bekerecioglu M. Congenital lateral cleft palate and lateral palatal synechiae. Scand J Plast Reconstr Surg Hand Surg. 2008;42(6):325-7. X-1. [pmid: 18991178].
1060 Kapferer I, Hienz S, Ulm C. Labial piercing and localized periodontal destruction - partial periodontal regeneration following periodontal debridement and free gingival graft. Dent Traumatol. Feb. 2008;24(1):112-4. X-1. [pmid: 18173679].
1061 Karabulut R, Sonmez K, Turkyilmaz Z, et al. Ankyloglossia and effects on breast-feeding, speech problems and mechanical/social issues in children. B-ent. 2008;4(2):81-5. X-1. [pmid: 18681203].
1062 Koenig LJ, Lynch DP, Yancey KB. Segmental odontomaxillary dysplasia presenting with facial hypertrichosis, commissural lip clefting, and hyperlinear palms. Pediatr Dermatol. Jul-Aug. 2008;25(4):491-2. X-1. [pmid: 18789102].
1063 Kotlow L. Lasers and soft tissue treatments for the pediatric dental patient. Alpha Omegan. Sep. 2008;101(3):140-51. X-1. [pmid: 19127931].
1064 Kotlow L. Lasers and pediatric dental care. Gen Dent. Nov-Dec. 2008;56(7):618-27. X-1. [pmid: 19014020].
1065 Krauel L, Parri FJ, Munoz E, et al. Van der Woude Syndrome and lower lip pits treatment. J Oral Maxillofac Surg. Mar. 2008;66(3):589-92. X-1. [pmid: 18280401].
1066 Kravitz ND, Kusnoto B. Soft-tissue lasers in orthodontics: an overview. Am J Orthod Dentofacial Orthop. Apr. 2008;133(4 Suppl):S110-4. X-1. [pmid: 18407017].
1067 Lertsirivorakul J, Hall RK. Solitary median maxillary central incisor syndrome occurring together with oromandibular-limb hypogenesis syndrome type 1: a case report of this previously unreported combination of syndromes. Int J Paediatr Dent. Jul. 2008;18(4):306-11. X-1. [pmid: 18328045].
1068 Lonyai A, Kodama S, Burger D, et al. Fetal Hox11 expression patterns predict defective target organs: a novel link between developmental biology and autoimmunity. Immunol Cell Biol. May-Jun. 2008;86(4):301-9. X-1. [pmid: 18301381].
1069 Magno AF, Enoki C, Ito IY, et al. In-vivo evaluation of the contamination of Super Slick elastomeric rings by Streptococcus mutans in orthodontic patients. Am J Orthod Dentofacial Orthop. Apr. 2008;133(4 Suppl):S104-9. X-1. [pmid: 18407016].
1070 Mandal K. Correlation of simple anterior open bite with bionator in an 8 year old female. International Medical Journal. 2008;15(5):389-91. PMID:. X-1.
1071 Mello-Moura AC, Cadioli IC, Correa MS, et al. Early diagnosis and surgical treatment of the lower labial frenum in infancy: a case report. J Clin Pediatr Dent. Spring. 2008;32(3):181-3. X-1. [pmid: 18524265].
1072 Menezes R, Letra A, Ruff J, et al. Studies of genes in the FGF signaling pathway and oral clefts with or without dental anomalies. Am J Med Genet A. Jun. 15. 2008;146a(12):1614-7. X-1. [pmid: 18478591].
1073 Meshulam-Derazon S, Levin L, Adler N, et al. Lip analysis and macrocheilia in young Jewish Israeli men. Plast Reconstr Surg. Dec. 2008;122(6):220e-1e. X-1. [pmid: 19050499].
1074 Mitsukawa N, Hosaka Y. Secondary correction of deformities of the vermilion with exposed oral mucosa after cleft lip repair. J Craniofac Surg. Sep. 2008;19(5):1370-3. X-1. [pmid: 18812865].
1075 Omoti AE, Omoti CE, Waziri-Erameh JM. Multiple ocular and other congenital anomalies in a hiv positive child. Am J Case Rep. 2008;9:229-32. X-1.
1076 Otto M, Gluckman H. The treatment of peri-mucositis and peri-implantitis 2. Sadj. Jun. 2008;63(5):312-4. X-1. [pmid: 18811085].
1077 Park K, Kwak IS. Characterization of heat shock protein 40 and 90 in Chironomus riparius larvae: effects of di(2-ethylhexyl) phthalate exposure on gene expressions and mouthpart deformities. Chemosphere. Dec. 2008;74(1):89-95. X-1. [pmid: 18977013].
1078 Perkiomaki MR, Alvesalo L. Palatine ridges and tongue position in Turner syndrome subjects. Eur J Orthod. Apr. 2008;30(2):163-8. X-1. [pmid: 18281708].
1079 Rinne T, Clements SE, Lamme E, et al. A novel translation re-initiation mechanism for the p63 gene revealed by amino-terminal truncating mutations in Rapp-Hodgkin/Hay-Wells-like syndromes. Hum Mol Genet. Jul. 1. 2008;17(13):1968-77. X-1. [pmid: 18364388].
1080 Roing M, Hirsch JM, Holmstrom I. Living in a state of suspension--a phenomenological approach to the spouse's experience of oral cancer. Scand J Caring Sci. Mar. 2008;22(1):40-7. X-1. [pmid: 18269421].
1081 Roshkind DM. The practical use of lasers in general practice. Alpha Omegan. Sep. 2008;101(3):152-61. X-1. [pmid: 19127932].
1082 Safar A, Carpenter B, Vaccani JP. Congenital heterotopic gastrointestinal cyst of the oral cavity: case report and review of the literature. J Otolaryngol Head Neck Surg. Jun. 2008;37(3):E100-1. X-1. [pmid: 19137646].
1083 Salles F, Anchieta M, Costa Bezerra P, et al. Complete and isolated congenital aglossia: case report and treatment of sequelae using rapid prototyping models. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Mar. 2008;105(3):e41-7. X-1. [pmid: 18280945].
1084 Savasta S, Chiapedi S, Perrini S, et al. Pai syndrome: a further report of a case with bifid nose, lipoma, and agenesis of the corpus callosum. Childs Nerv Syst. Jun. 2008;24(6):773-6. X-1. [pmid: 18369643].
1085 Scardina GA, Pisano T, Carini F, et al. Burning mouth syndrome: an evaluation of in vivo microcirculation. J Am Dent Assoc. Jul. 2008;139(7):940-6. X-1. [pmid: 18594080].
1086 Sedghizadeh PP, Kumar SK, Gorur A, et al. Toxic epidermal necrolysis with a rare long-term oral complication requiring surgical intervention. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Apr. 2008;105(4):e29-33. X-1. [pmid: 18329565].
1087 Shaikh MF, Naik N, Shah C. Duplication of hemi mandible and oral cavity, presentation of an adult patient--a case report. J Plast Reconstr Aesthet Surg. 2008;61(2):183-5. X-1. [pmid: 18024251].
1088 Sherman JA. Oral surgery simplified with radiosurgery. Dent Today. Feb. 2008;27(2):123-4. 6. X-1. [pmid: 18330196].
1089 Shetty K, Trajtenberg C, Patel C, et al. Maxillary frenectomy using a carbon dioxide laser in a pediatric patient: a case report. Gen Dent. Jan-Feb. 2008;56(1):60-3. X-1. [pmid: 18254562].
1090 Siqueira MA, de Souza Silva J, Silva FW, et al. Dental treatment in a patient with epidermolysis bullosa. Spec Care Dentist. May-Jun. 2008;28(3):92-5. X-1. [pmid: 18489655].
1091 Song LJ, Xu YM, Hu XY, et al. Urethral substitution using autologous lingual mucosal grafts: an experimental study. BJU Int. Mar. 2008;101(6):739-43. X-1. [pmid: 17922872].
1092 Souto LR. Congenital bilateral lower lip pits associated with fistulae of the minor salivary glands: case report of the principal Van der Woude syndrome's trait. Aesthetic Plast Surg. Jan. 2008;32(1):172-4. X-1. [pmid: 17805920].
1093 Spitz SD. Lasers in prosthodontics: clinical realities of a dental laser in a prosthodontic practice. Alpha Omegan. Dec. 2008;101(4):188-94. X-1. [pmid: 19166083].
1094 Suda S, Takagai S, Inoshima-Takahashi K, et al. Electroconvulsive therapy for burning mouth syndrome. Acta Psychiatr Scand. Dec. 2008;118(6):503-4. X-1. [pmid: 18764838].
1095 Talwar N, Mohan S, Ravi B, et al. Lithium-induced enlargement of a lingual thyroid. Singapore Med J. Mar. 2008;49(3):254-5. X-1. [pmid: 18363010].
1096 Vasseur Maurer S, Schwab G, Osterheld MC, et al. A 16-month-old boy vomits a double tongue: intraluminal duplication of the cervical esophagus in children. Dis Esophagus. 2008;21(2):186-8. X-1. [pmid: 18269657].
1097 Waddington C. Products of interest. “Products to make life easier”. ORL Head Neck Nurs. 2008;26(2):16-7. PMID:. X-1. [pmid: 19097456].
1098 Yaday S, Singh I, Singh J, et al. Medullary carcinoma in a lingual thyroid. Singapore Med J. Mar. 2008;49(3):251-3. X-1. [pmid: 18363009].
1099 Hot papers in the literature. J Womens Health. 2009;18(1):133-7. PMID:. X-2.
1100 Atzeni M, Ceratola E, Zaccheddu E, et al. Surgical correction and MR imaging of double lip in Ascher syndrome: record of a case and a review of the literature. Eur Rev Med Pharmacol Sci. Jul-Aug. 2009;13(4):309-11. X-1. [pmid: 19694346].
1101 Bai Y, Jia J, Huang XX, et al. Sclerotherapy of microcystic lymphatic malformations in oral and facial regions. J Oral Maxillofac Surg. Feb. 2009;67(2):251-6. X-1. [pmid: 19138596].
1102 Barakzai SZ, Finnegan C, Dixon PM, et al. Use of tongue ties in thoroughbred racehorses in the United Kingdom, and its association with surgery for dorsal displacement of the soft palate. Vet Rec. Sep. 5. 2009;165(10):278-81. X-1. [pmid: 19734559].
1103 Bhattacharya V, Khanna S, Bashir SA, et al. Cleft palate associated with hamartomatous bifid tongue. Report of two cases. J Plast Reconstr Aesthet Surg. Nov. 2009;62(11):1442-5. X-1. [pmid: 18572001].
1104 Bozkurt M, Kulahci Y, Zor F, et al. Reconstruction of the lower lip in Van der Woude syndrome. Ann Plast Surg. Apr. 2009;62(4):451-5. X-1. [pmid: 19325355].
1105 Bressmann T, Jacobs H, Quintero J, et al. Speech outcomes for partial glossectomy surgery: Measures of speech articulation and listener perception. Canadian Journal of Speech-Language Pathology and Audiology. 2009;33(4):204-10. PMID:. X-1.
1106 Breugem CC, Mink van der Molen AB. What is ‘Pierre Robin sequence’?. J Plast Reconstr Aesthet Surg. Dec. 2009;62(12):1555-8. X-1. [pmid: 18977702].
1107 Butow KW, Hoogendijk CF, Zwahlen RA. Pierre Robin sequence: appearances and 25 years of experience with an innovative treatment protocol. J Pediatr Surg. Nov. 2009;44(11):2112-8. X-1. [pmid: 19944218].
1108 Ceyhan AM, Yildirim M, Basak PY, et al. Traumatic lingual ulcer in a child: Riga-Fede disease. Clin Exp Dermatol. Mar. 2009;34(2):186-8. X-1. [pmid: 19187299].
1109 Chakravarti A, Tatatavarthy S, Sahni JK. Type VIII oral-facial-digital syndrome. A rare case series of a forgotten syndrome subtype. Int J Pediatr Otorhinolaryngol Extra. September. 2009;4(3):118-22. PMID:. X-1.
1110 Chen J, Shen W, Cui J, et al. Mucosa Z-plasty for correction of transverse facial cleft. J Craniofac Surg. May. 2009;20(3):903-4. X-1. [pmid: 19390454].
1111 Clark HM, O'Brien K, Calleja A, et al. Effects of directional exercise on lingual strength. J Speech Lang Hear Res. Aug. 2009;52(4):1034-47. X-1. [pmid: 19641080].
1112 Deane SA, Cistulli PA, Ng AT, et al. Comparison of mandibular advancement splint and tongue stabilizing device in obstructive sleep apnea: a randomized controlled trial. Sleep. May. 2009;32(5):648-53. X-1. [pmid: 19480232].
1113 Desiate A, Cantore S, Tullo D, et al. 980 nm diode lasers in oral and facial practice: current state of the science and art. Int J Med Sci. 2009;6(6):358-64. X-1. [pmid: 19960121].
1114 Domingo DL, Trujillo MI, Council SE, et al. Hutchinson-Gilford progeria syndrome: oral and craniofacial phenotypes. Oral Dis. Apr. 2009;15(3):187-95. X-1. [pmid: 19236595].
1115 Falabella V, Pigatto PD, Spadari F, et al. Burning mouth syndrome and electroconvulsive therapy. Acta Psychiatr Scand. Jul. 2009;120(1):83-4. X-1. [pmid: 19291078].
1116 Finigan V. ‘It's on the tip of my tongue’: evaluation of a new frenulotomy service in Northern England. MIDIRS Midwifery Digest. 2009;19(3):395-400. PMID:. X-1.
1117 Ghanekar J, Sangrampurkar S, Hulinaykar R, et al. Ellis van Creveld syndome. J Assoc Physicians India. Jul. 2009;57:532-4. X-1. [pmid: 20329417].
1118 Glade RS, Buckmiller LM. CO2 laser resurfacing of intraoral lymphatic malformations: a 10-year experience. Int J Pediatr Otorhinolaryngol. Oct. 2009;73(10):1358-61. X-1. [pmid: 19628286].
1119 Hickey B, Jauhar S. Gingival veneers. Dent Update. Sep. 2009;36(7):422-4. 6. 8. X-1. [pmid: 19810398].
1120 Ichida M, Komuro Y, Yanai A. Consideration of median cleft lip with frenulum labii superior. J Craniofac Surg. Sep. 2009;20(5):1370-4. X-1. [pmid: 19816259].
1121 Karahan S, Kul BC. Ankyloglossia in dogs: a morphological and immunohistochemical study. Anat Histol Embryol. Apr. 2009;38(2):118-21. X-1. [pmid: 19007356].
1122 Kim SC, Nam KC, Rah DK, et al. Assessment of the cleft nasal deformity using a regression equation. Cleft Palate Craniofac J. Mar. 2009;46(2):197-203. X-1. [pmid: 19254059].
1123 Kim SM, Lee JH, Jabaiti S, et al. Tbx22 expressions during palatal development in fetuses with glucocorticoid-/alcohol-induced C57BL/6N cleft palates. J Craniofac Surg. Sep. 2009;20(5):1316-26. X-1. [pmid: 19816249].
1124 Kumar S, Tiwary SK, Khanna AK. An accessory tongue. Singapore Med J. May. 2009;50(5):e172. X-1. [pmid: 19495501].
1125 Lancioni GE, Singh NN, O'Reilly MF, et al. Upgraded technology for contingent stimulation of mouth wiping by two persons with drooling and profound developmental disabilities. Res Dev Disabil. Jul-Aug. 2009;30(4):793-8. X-1. [pmid: 19117722].
1126 Lima LM, Diniz MB, dos Santos-Pinto L. Moebius syndrome: clinical manifestations in a pediatric patient. Pediatr Dent. Jul-Aug. 2009;31(4):289-93. X-1. [pmid: 19722436].
1127 Lomke MA. Clinical applications of dental lasers. Gen Dent. Jan-Feb. 2009;57(1):47-59. X-1. [pmid: 19146143].
1128 Miziara ID, Filho BC, Oliveira R, et al. Group psychotherapy: an additional approach to burning mouth syndrome. J Psychosom Res. Nov. 2009;67(5):443-8. X-1. [pmid: 19837207].
1129 Mockbil N, Huggare J. Uniformity in selection for subsidized orthodontic care--focus on borderline treatment need. Swed Dent J. 2009;33(1):19-25. X-1. [pmid: 19522314].
1130 Mori Y, Susami T, Chikazu D, et al. Unilateral expansion of a narrow mandibular dental arch combined with bimaxillary osteotomies in a patient with hypoglossia. Int J Oral Maxillofac Surg. Jun. 2009;38(6):689-93. X-1. [pmid: 19406615].
1131 Moriyama T, Matsumoto S, Makiishi T. Root coverage technique with enamel matrix derivative. Bull Tokyo Dent Coll. May. 2009;50(2):97-104. X-1. [pmid: 19815997].
1132 Narayanan H, Reddy P, Raghuram C. Difficult airway in a patient with cleft palate: a case report. Internet Journal of Anesthesiology. 2009;21(1). 4p. PMID:. X-1.
1133 Neiswanger K, Walker K, Klotz CM, et al. Whorl patterns on the lower lip are associated with nonsyndromic cleft lip with or without cleft palate. Am J Med Genet A. Dec. 2009;149a(12):2673-9. X-1. [pmid: 19921634].
1134 Nejatidanesh F, Peimannia E, Savabi O. Effect of labial frenum notch size and palatal vault depth on stress concentration in a maxillary complete denture: a finite element study. J Contemp Dent Pract. 2009;10(3):59-66. X-1. [pmid: 19430627].
1135 Nowak P, Noras L, Jochem J, et al. Histaminergic activity in a rodent model of Parkinson's disease. Neurotox Res. Apr. 2009;15(3):246-51. X-1. [pmid: 19384597].
1136 Oki K, Ogawa R, Lu F, et al. The inferior labial artery island flap. J Plast Reconstr Aesthet Surg. Sep. 2009;62(9):e294-7. X-1. [pmid: 18407813].
1137 Parkins GE, Boamah MO. Congenital maxillomandibular syngnathia: case report. J Craniomaxillofac Surg. Jul. 2009;37(5):276-8. X-1. [pmid: 19231229].
1138 Peterson JD, Peterson VA, Mendonca MT. Exposure to coal combustion residues during metamorphosis elevates corticosterone content and adversely affects oral morphology, growth, and development in Rana sphenocephala. Comp Biochem Physiol C Toxicol Pharmacol. Jan. 2009;149(1):36-9. X-1. [pmid: 18627796].
1139 Pizolato RA, Silva De Freitas Fernandes F, Beatriz Duarte Gaviao M. Deglutition and temporomandibular disorders in children. Minerva Stomatol. Nov-Dec. 2009;58(11-12):567-76. X-1. [pmid: 20027127].
1140 Potting C, Mistiaen P, Poot E, et al. A review of quality assessment of the methodology used in guidelines and systematic reviews on oral mucositis. J Clin Nurs. Jan. 2009;18(1):3-12. X-1. [pmid: 19120727].
1141 Prashantha DK, Pal PK. Serpentine tongue: A rare manifestation following initiation of levodopa therapy in a patient with Parkinson's disease. Parkinsonism Relat Disord. Nov. 2009;15(9):718-9. X-1. [pmid: 19157953].
1142 Putwatana P, Sanmanowong P, Oonprasertpong L, et al. Relief of radiation-induced oral mucositis in head and neck cancer. Cancer Nurs. Jan-Feb. 2009;32(1):82-7. X-1. [pmid: 19104205].
1143 Rison RA, Beydoun SR. Teaching Video NeuroImages: tongue myokymia following head and neck radiotherapy for nasopharyngeal carcinoma. Neurology. 2009;72(14):1. PMID:. X-1.
1144 Ruviere DB, Costa MM, Cunha RF. Conservative management of severe intrusion in a primary tooth: a 4-year follow-up. J Dent Child (Chic). Jan-Apr. 2009;76(1):87-91. X-1. [pmid: 19341586].
1145 Ryan AJ, Lin F, Atayee RS. Ketamine mouthwash for mucositis pain. J Palliat Med. Nov. 2009;12(11):989-91. X-1. [pmid: 19708855].
1146 Saito K, Imate Y, Fukuda T, et al. Successful stereotactic radiosurgery with the CyberKnife of a giant arteriovenous malformation of the tongue: a case report. Stereotact Funct Neurosurg. 2009;87(3):182-90. X-1. [pmid: 19494567].
1147 Sorrentino JM, Tarnow DP. The semilunar coronally repositioned flap combined with a frenectomy to obtain root coverage over the maxillary central incisors. J Periodontol. Jun. 2009;80(6):1013-7. X-1, X-3. [pmid: 19485834].
1148 Suda S, Takei N. “Burning mouth syndrome and electroconvulsive therapy”: Reply. Acta Psychiatr Scand. 2009;120(1):84. PMID:. X-1.
1149 Thexton AJ, Crompton AW, Owerkowicz T, et al. Impact of rhythmic oral activity on the timing of muscle activation in the swallow of the decerebrate pig. J Neurophysiol. 2009;101(3):1386-93. X-1. [pmid: 19073808].
1150 Toker H, Ozdemir H. Gingival recession: epidemiology and risk indicators in a university dental hospital in Turkey. Int J Dent Hyg. May. 2009;7(2):115-20. X-1. [pmid: 19413547].
1151 Tsirevelou P, Papamanthos M, Chlopsidis P, et al. Epidermoid cyst of the floor of the mouth: two case reports. Cases J. 2009;2:9360. X-1. [pmid: 20062607].
1152 Tsung LTH, Cruickshank K. Mother tongue and bilingual minority education in china. Int J Biling Educ Biling. 2009;12(5):549-63. PMID:. X-1.
1153 Wiegand S, Eivazi B, Zimmermann AP, et al. Microcystic lymphatic malformations of the tongue: diagnosis, classification, and treatment. Arch Otolaryngol Head Neck Surg. Oct. 2009;135(10):976-83. X-1. [pmid: 19841334].
1154 Yang HM, Woo YJ, Won SY, et al. Course and distribution of the lingual nerve in the ventral tongue region: anatomical considerations for frenectomy. J Craniofac Surg. Sep. 2009;20(5):1359-63. X-1, X-3. [pmid: 19816256].
1155 Zhang X, Ju Z, Wang C, et al. The single needle method for urethrovesical anastomosis with strengthened posterior fixation during laparoscopic radical prostatectomy. J Huazhong Univ Sci Technolog Med Sci. Dec. 2009;29(6):745-9. X-1. [pmid: 20037820].
1156 Zheng JW, Yang XJ, Wang YA, et al. Intralesional injection of Pingyangmycin for vascular malformations in oral and maxillofacial regions: an evaluation of 297 consecutive patients. Oral Oncol. Oct. 2009;45(10):872-6. X-1. [pmid: 19628423].
1157 Aminabadi NA, Ebrahimi A, Oskouei SG. Chondroectodermal dysplasia (Ellis-van Creveld syndrome): a case report. J Oral Sci. Jun. 2010;52(2):333-6. X-1. [pmid: 20587962].
1158 Andrade NN, Raikwar K. Congenital benign teratoma of the tongue with bifid tip, ankyloglossia and polydactyly: report of a case. Br J Oral Maxillofac Surg. Sep. 2010;48(6):e29-30. X-1. [pmid: 20579786].
1159 Babaji P. Oral abnormalities in the Ellis-van Creveld syndrome. Indian J Dent Res. Jan-Mar. 2010;21(1):143-5. X-1. [pmid: 20427928].
1160 Baghestani S, Sadeghi N, Yavarian M, et al. Lower lip pits in a patient with van der Woude syndrome. J Craniofac Surg. Sep. 2010;21(5):1380-1. X-1. [pmid: 20818247].
1161 Batra YK, Rakesh SV, Menon P, et al. Successful airway management with left-molar laryngoscopy in glossopalatal ankylosis: a case report. Acta Anaesthesiol Belg. 2010;61(4):215-6. X-1. [pmid: 21388081].
1162 Beneng K, Renton T, Yilmaz Z, et al. Sodium channel Na v 1.7 immunoreactivity in painful human dental pulp and burning mouth syndrome. BMC Neurosci. 2010;11:71. X-1. [pmid: 20529324].
1163 Bernhardt M, Stemberger J, Charest M. Intervention for speech production in children and adolescents: Models of speech production and therapy approaches. Introduction to the issue. Canadian Journal of Speech-Language Pathology and Audiology. 2010;34(3):157-67. PMID:. X-2.
1164 Bolan M, Derech CD, Correa M, et al. Palatal expansion in a patient with solitary median maxillary central incisor syndrome. Am J Orthod Dentofacial Orthop. Oct. 2010;138(4):493-7. X-1. [pmid: 20889056].
1165 Bressmann T, Flowers H, Wong W, et al. Coronal view ultrasound imaging of movement in different segments of the tongue during paced recital: findings from four normal speakers and a speaker with partial glossectomy. Clin Linguist Phon. Aug. 2010;24(8):589-601. X-1. [pmid: 20524849].
1166 Chetty-John S, Piwnica-Worms K, Bryant J, et al. Fibrocystic disease of liver and pancreas; under-recognized features of the X-linked ciliopathy oral-facial-digital syndrome type 1 (OFD I). Am J Med Genet A. Oct. 2010;152a(10):2640-5. X-1. [pmid: 20818665].
1167 Davison L. Feeding fix… Solution for babies with tongue-tie (July 2010). Parents. 2010;85(9):18. PMID:. X-1.
1168 Deliberador TM, Santos FR, Bosco AF, et al. Simultaneous application of combination of three surgical techniques for treatment of gingival recession: a case report. Bull Tokyo Dent Coll. 2010;51(4):201-5. X-1. [pmid: 21139373].
1169 Eker E, Tellioglu AT. Upper lip augmentation with double-row subcutaneous pedicled V-Y flaps in Mobius syndrome. J Craniofac Surg. Sep. 2010;21(5):1604-7. X-1. [pmid: 20856056].
1170 Felicio AC, Godeiro-Junior C, Moriyama TS, et al. Speech-induced lingual dystonia. Arq Neuropsiquiatr. 2010;68(4):653-5. PMID:. X-1. [pmid: 20730328].
1171 Gant N, Stinear CM, Byblow WD. Carbohydrate in the mouth immediately facilitates motor output. Brain Res. Sep. 2. 2010;1350:151-8. X-1. [pmid: 20388497].
1172 Genovese MD, Olivi G. Use of laser technology in orthodontics: hard and soft tissue laser treatments. Eur J Paediatr Dent. Mar. 2010;11(1):44-8. X-1. [pmid: 20359282].
1173 Grasseschi MF. Minimal scar repair of unilateral cleft lip. Plast Reconstr Surg. Feb. 2010;125(2):620-8. X-1. [pmid: 20124847].
1174 Grishkevich VM. Post-burn philtrum restoration. Burns. Aug. 2010;36(5):698-702. X-1. [pmid: 19969425].
1175 Guven E, Ugurlu AM, Basaran K, et al. Reconstruction of intraoral defects with superior labial artery musculo-mucosal flap: a preliminary clinical study. Kulak Burun Bogaz Ihtis Derg. May-Jun. 2010;20(3):118-22. X-1. [pmid: 20465536].
1176 He X, Shi B, Jiang S, et al. 110 infants with unrepaired unilateral cleft lip: An anthropometric analysis of the lip and nasal deformities. Int J Oral Maxillofac Surg. Sep. 2010;39(9):847-52. X-1. [pmid: 20466518].
1177 Hozyasz KK, Oltarzewski M, Lugowska I. Whole blood citrulline concentrations in newborns with non-syndromic oral clefts--a preliminary report. Asia Pac J Clin Nutr. 2010;19(2):217-22. X-1. [pmid: 20460235].
1178 Ito M, Kimura H, Yoshida K, et al. Effectiveness of milnacipran for the treatment of chronic pain in the orofacial region. Clin Neuropharmacol. Mar-Apr. 2010;33(2):79-83. X-1. [pmid: 20375656].
1179 Joethy J, Por YC, Vincent Y. A unique presentation of epignathus. J Craniofac Surg. Sep. 2010;21(5):1651-4. X-1. [pmid: 20856072].
1180 Kays SA, Hind JA, Gangnon RE, et al. Effects of dining on tongue endurance and swallowing-related outcomes. J Speech Lang Hear Res. 2010;53(4):898-907. X-1. [pmid: 20689047].
1181 Laaksonen JP, Rieger J, Happonen RP, et al. Speech after radial forearm free flap reconstruction of the tongue: a longitudinal acoustic study of vowel and diphthong sounds. Clin Linguist Phon. Jan. 2010;24(1):41-54. X-1. [pmid: 20030552].
1182 Langer-Jaesrich M, Kohler HR, Gerhardt A. Assessing toxicity of the insecticide thiacloprid on Chironomus riparius (Insecta: Diptera) using multiple end points. Arch Environ Contam Toxicol. May. 2010;58(4):963-72. X-1. [pmid: 19937322].
1183 Lindsay RW, Hadlock TA, Cheney ML. Upper lip elongation in Mobius syndrome. Otolaryngol Head Neck Surg. Feb. 2010;142(2):286-7. X-1. [pmid: 20115991].
1184 Margolis FS. Oral pathology of tots and teens. Dimens Dent Hyg. 2010;8(2):58-61. PMID:. X-1, X-2.
1185 Nakano Y, Somiya H, Shibui T, et al. A case of congenital midline fistula of the upper lip. Bull Tokyo Dent Coll. 2010;51(1):31-4. X-1. [pmid: 20574132].
1186 O'Sullivan JB, Earley MJ. Primary calvarial bone grafting in oro-ocular clefts. J Plast Reconstr Aesthet Surg. May. 2010;63(5):769-73. X-1. [pmid: 19464971].
1187 Pae CU. Milnacipran for chronic pain in the orofacial region. Clin Neuropharmacol. Sep-Oct. 2010;33(5):270. X-1. [pmid: 20864840].
1188 Paranaiba LM, Miranda RT, Martelli DR, et al. Cleft lip and palate: series of unusual clinical cases. Braz J Otorhinolaryngol. Sep-Oct. 2010;76(5):649-53. X-1. [pmid: 20963351].
1189 Patel NP, Tantri MD. Median cleft of the upper lip: a rare case. Cleft Palate Craniofac J. Nov. 2010;47(6):642-4. X-1. [pmid: 20500055].
1190 Patel S, Chandarana S, Husein M, et al. Diagnosis and management of a neonatal intralingual cyst of foregut origin. Int J Pediatr Otorhinolaryngol Extra. January. 2010;5(1):1-4. PMID:. X-1.
1191 Rabbitts JA, Groenewald CB, Dietz NM, et al. Perioperative opioid requirements are decreased in hypoxic children living at altitude. Paediatr Anaesth. Dec. 2010;20(12):1078-83. X-1. [pmid: 21199116].
1192 Sharma D, Prabhakar H, Bithal PK, et al. Predicting difficult laryngoscopy in acromegaly: a comparison of upper lip bite test with modified Mallampati classification. J Neurosurg Anesthesiol. Apr. 2010;22(2):138-43. X-1. [pmid: 20118795].
1193 Takahashi H, Kawaguchi N, Ito S, et al. Is tongue atrophy reversible in anti-MuSK myasthenia gravis? Six-year observation. J Neurol Neurosurg Psychiatry. Jun. 2010;81(6):701-2. X-1. [pmid: 20522876].
1194 Takenoshita M, Sato T, Kato Y, et al. Psychiatric diagnoses in patients with burning mouth syndrome and atypical odontalgia referred from psychiatric to dental facilities. Neuropsychiatr Dis Treat. 2010;6:699-705. X-1. [pmid: 21127687].
1195 Toka O, Karl M, Dittrich S, et al. Dental aspects in patients with DiGeorge syndrome. Quintessence Int. Jul-Aug. 2010;41(7):551-6. X-1. [pmid: 20614041].
1196 Trotter S. Raising awareness amongst parents of treatments for tongue-tie. MIDIRS Midwifery Digest. 2010;20(1):83-5. PMID:. X-1.
1197 Voller RJ. Soft-tissue lasers and procedures. RDH. 2010;30(5):63-73. PMID:. X-1.
1198 Wong Y-M. Tongue acupuncture and autism spectrum disorder. J Altern Complement Med. 2010;16(12):1247-8. PMID:. X-1. [pmid: 21114403].
1199 Yasuda M, Okada E, Nagai Y, et al. Reactive proliferation of endothelial cells and pericytes associated with arteriovenous malformation. J Dermatol. Apr. 2010;37(4):363-6. X-1. [pmid: 20507408].
1200 Akabaliev V, Sivkov S, Mantarkov M, et al. Minor physical anomalies in patients with bipolar I disorder and normal controls. J Affect Disord. Dec. 2011;135(1-3):193-200. X-1. [pmid: 21846578].
1201 Al Jabbari YS. Frenectomy for improvement of a problematic conventional maxillary complete denture in an elderly patient: a case report. J Adv Prosthodont. Dec. 2011;3(4):236-9. X-1. [pmid: 22259708].
1202 Alter GJ. Labia minora reconstruction using clitoral hood flaps, wedge excisions, and YV advancement flaps. Plast Reconstr Surg. Jun. 2011;127(6):2356-63. X-1. [pmid: 21311388].
1203 Amir LH, James JP, Kelso G, et al. Accreditation of midwife lactation consultants to perform infant tongue-tie release. Int J Nurs Pract. Dec. 2011;17(6):541-7. X-1, X-2. [pmid: 22103819].
1204 Artzi Z, Chaturvedi R. Dual root coverage of severely traumatized maxillary central incisors: a divided soft tissue management approach. Quintessence Int. Oct. 2011;42(9):737-43. X-1. [pmid: 21909498].
1205 Awan ZA, Haggblad E, Wester T, et al. Diffuse reflectance spectroscopy: systemic and microvascular oxygen saturation is linearly correlated and hypoxia leads to increased spatial heterogeneity of microvascular saturation. Microvasc Res. May. 2011;81(3):245-51. X-1. [pmid: 21376735].
1206 Baciliero U, Spanio di Spilimbergo S, Riga M, et al. Respiratory distress in Pierre Robin sequence: an experience with mandible traction by wires. Int J Oral Maxillofac Surg. May. 2011;40(5):464-70. X-1. [pmid: 21237615].
1207 Bahetwar SK, Pandey RK, Bahetwar TS. Popliteal pterygium syndrome: orofacial and general features. J Indian Soc Pedod Prev Dent. Oct-Dec. 2011;29(4):333-5. X-1. [pmid: 22016320].
1208 Beeler-Marfisi J, Gallastegui Menoyo A, Beck A, et al. Gelatinous marrow transformation and hematopoietic atrophy in a miniature horse stallion. Vet Pathol. Mar. 2011;48(2):451-5. X-1. [pmid: 20587692].
1209 Bosio JA, Bradley TG, Hefti AF. Moving an incisor across the midline: a treatment alternative in an adolescent patient. Am J Orthod Dentofacial Orthop. Apr. 2011;139(4):533-43. X-1. [pmid: 21457865].
1210 Chaubal TV, Dixit MB. Ankyloglossia and its management. J Indian Soc Periodontol. Jul. 2011;15(3):270-2. X-2, X-3. [pmid: 22028516].
1211 Chi L, Comyn FL, Mitra N, et al. Identification of craniofacial risk factors for obstructive sleep apnoea using three-dimensional MRI. Eur Respir J. Aug. 2011;38(2):348-58. X-1. [pmid: 21233264].
1212 Coelho RF, Chauhan S, Orvieto MA, et al. Influence of modified posterior reconstruction of the rhabdosphincter on early recovery of continence and anastomotic leakage rates after robot-assisted radical prostatectomy. Eur Urol. Jan. 2011;59(1):72-80. X-1. [pmid: 20801579].
1213 Corlew S, Fan VY. A model for building capacity in international plastic surgery: ReSurge International. Ann Plast Surg. Dec. 2011;67(6):568-70. X-1. [pmid: 22123536].
1214 Cortelezzi A, Paggi AC, Rodriguez M, et al. Taxonomic and nontaxonomic responses to ecological changes in an urban lowland stream through the use of Chironomidae (Diptera) larvae. Sci Total Environ. Mar. 1. 2011;409(7):1344-50. X-1. [pmid: 21276601].
1215 Gathwala G, Singh J, Dalal P, et al. Hypoglossia-hypodactyly syndrome in a newborn. J Craniomaxillofac Surg. Mar. 2011;39(2):99-101. X-1. [pmid: 20673638].
1216 Halli R, Kini Y, Kharkar V, et al. Treatment of midline cleft of the mandible-A 2-stage approach. J Craniofac Surg. Jan. 2011;22(1):220-2. X-1. [pmid: 21233749].
1217 Harrison JS, Conlan MJ, Deas DE. An alternative donor site for an epithelialized-free soft-tissue autograft. Compend Contin Educ Dent. Mar. 2011;32(2):e29-31. X-1. [pmid: 23738833].
1218 Hartinger M, Tripoliti E, Hardcastle WJ, et al. Effects of medication and subthalamic nucleus deep brain stimulation on tongue movements in speakers with Parkinson's disease using electropalatography: a pilot study. Clin Linguist Phon. Mar. 2011;25(3):210-30. X-1. [pmid: 21158488].
1219 Hegde K, Puthran RM, Nair G, et al. Ellis van Creveld syndrome--a report of two siblings. BMJ Case Rep. 2011;2011. X-1. [pmid: 22675019].
1220 Heliovaara A. Maxillary dental arch dimensions in 6-year-old children with articulatory speech disorders. Folia Phoniatr Logop. 2011;63(5):242-6. X-1. [pmid: 21266823].
1221 Hirai N, Matsune K, Ohashi H. Craniofacial and oral features of Sotos syndrome: differences in patients with submicroscopic deletion and mutation of NSD1 gene. Am J Med Genet A. Dec. 2011;155a(12):2933-9. X-1. [pmid: 22012791].
1222 Jefferson GD. Adult with oral cavity lesion. AAO-HNSF Patient of the Month Program. 2011;40(5):1-25. PMID:. X-1.
1223 Kaya D, Taner TU. Management of an adult with spaced dentition, class III malocclusion and open-bite tendency. Eur J Dent. Jan. 2011;5(1):121-9. X-1. [pmid: 21228963].
1224 Kim JP, Park JJ, Lee EJ, et al. Intraoral removal of a thyroglossal duct cyst using a frenotomy incision. Thyroid. Dec. 2011;21(12):1381-4. X-1. [pmid: 22136269].
1225 Kim SW, Kavanagh K, Orbach DB, et al. Long-term outcome of radiofrequency ablation for intraoral microcystic lymphatic malformation. Arch Otolaryngol Head Neck Surg. Dec. 2011;137(12):1247-50. X-1. [pmid: 22183906].
1226 Laaksonen JP, Rieger J, Harris J, et al. A longitudinal acoustic study of the effects of the radial forearm free flap reconstruction on sibilants produced by tongue cancer patients. Clin Linguist Phon. Apr. 2011;25(4):253-64. X-1. [pmid: 21091207].
1227 Lin HS, Yin HL, Chui C, et al. Spinal cheiro-oral syndrome: a common neurological entity in an unusual site. Neurol Neurochir Pol. Nov-Dec. 2011;45(6):583-9. X-1. [pmid: 22212989].
1228 Lopez-Jornet P, Camacho-Alonso F, De la Mano-Espinosa T. Complementary and alternative medical therapies in patients with burning mouth syndrome. J Altern Complement Med. Apr. 2011;17(4):289-90. X-1. [pmid: 21417931].
1229 Lumbau A, Schinocca L, Chessa G. Influence of posture on swallowing. Eur J Paediatr Dent. Sep. 2011;12(3):171-4. X-1. [pmid: 22077685].
1230 Magliocca KR, Ricalde P, Vincek V, et al. Bronchogenic cyst with intraoral and extraoral components. J Oral Maxillofac Surg. Oct. 2011;69(10):2604-7. X-1. [pmid: 21549475].
1231 Mangus BD, Goudy SL. Cleft tongue and choristomas: A case report. Int J Pediatr Otorhinolaryngol Extra. September. 2011;6(3):135-6. X-1.
1232 Marenzi G, Urciuolo V, Cimmino P, et al. Frenulectomy: proposal of a new surgical approach and case report. Minerva Stomatol. Jan-Feb. 2011;60(1-2):51-6. X-1, X-2. [pmid: 21252849].
1233 Miamoto CB, Ramos-Jorge ML, Ferreira MC, et al. Dental trauma in individuals with severe cerebral palsy: prevalence and associated factors. Braz Oral Res. Jul-Aug. 2011;25(4):319-23. X-1. [pmid: 21860919].
1234 Mignogna MD, Adamo D, Schiavone V, et al. Burning mouth syndrome responsive to duloxetine: a case report. Pain Med. Mar. 2011;12(3):466-9. X-1. [pmid: 21223496].
1235 Mittal M, Murray AM, Sandler PJ. Maxillary labial fraenectomy: indications and technique. Dent Update. Apr. 2011;38(3):159-62. X-2. [pmid: 21667829].
1236 Mohamed El-Massry MA, Ali TS, Hussain AI, et al. Duplicated, translocated maxilla and upper lip: a case report of a rare congenital anomaly. J Craniomaxillofac Surg. Mar. 2011;39(2):96-8. X-1. [pmid: 20673636].
1237 Montebugnoli L, Tiberio C, Venturi M. A rare case of congenital epidermoid cyst of the hard palate. BMJ Case Rep. 2011;2011. X-1. [pmid: 22675054].
1238 Mutaf M, Gunal E, Turkmen A, et al. Correction of tethered upper lip deformity following bilateral cleft lip repair. Ann Plast Surg. Jun. 2011;66(6):627-32. X-1. [pmid: 21467914].
1239 Nashwan AJ. Use of chlorhexidine mouthwash in children receiving chemotherapy: a review of literature. J Pediatr Oncol Nurs. Sep-Oct. 2011;28(5):295-9. X-1. [pmid: 21821553].
1240 Neef NE, Paulus W, Neef A, et al. Reduced intracortical inhibition and facilitation in the primary motor tongue representation of adults who stutter. Clin Neurophysiol. Sep. 2011;122(9):1802-11. X-1. [pmid: 21377925].
1241 Pair J. Movement of a maxillary central incisor across the midline. Angle Orthod. Mar. 2011;81(2):341-9. X-1. [pmid: 21208089].
1242 Patney A, Pai KM, Sholapurkar AA. Kocher Debre Semelaigne syndrome and associated orofacial aspects: report of a case. J Oral Sci. Mar. 2011;53(1):129-32. X-1. [pmid: 21467826].
1243 Pedro RL, Andrade LH, Maia LC. The importance of oral-clinical findings for the correct diagnosis of Ellis-van Creveld syndrome. Gen Dent. Sep-Oct. 2011;59(5):e206-9. X-1. [pmid: 22313832].
1244 Perrin E, Ota KS. Tongue lesion with sensation of fullness in the mouth. Am Fam Physician. Apr. 1. 2011;83(7):839-40. X-1. [pmid: 21524051].
1245 Rorick NK, Kinoshita A, Weirather JL, et al. Genomic strategy identifies a missense mutation in WD-repeat domain 65 (WDR65) in an individual with Van der Woude syndrome. Am J Med Genet A. Jun. 2011;155a(6):1314-21. X-1. [pmid: 21574244].
1246 Sarode GS, Desai RS, Sarode SC, et al. Van der Woude syndrome with an unusual intraoral finding. Indian J Dent Res. Jan-Feb. 2011;22(1):164-5. X-1. [pmid: 21525698].
1247 Sforza C, Elamin F, Rosati R, et al. Three-dimensional assessment of nose and lip morphology in North Sudanese subjects with Down syndrome. Angle Orthod. Jan. 2011;81(1):107-14. X-1. [pmid: 20936962].
1248 Sherratt S. Written media coverage of aphasia: A review. Aphasiology. 2011;25(10):1132-52. PMID:. X-1.
1249 Srivastava A, Parihar A, Soni R, et al. Surgical management of a rare case of congenital doubleupper lip. Case Rep Med. 2011;2011(824634). X-1.
1250 Sugimoto K. The dubious effect of milnacipran for the treatment of burning mouth syndrome. Clin Neuropharmacol. Jul-Aug. 2011;34(4):170-3. X-1. [pmid: 21738026].
1251 Suhaili DN, Somasundaram S, Lau SH, et al. Duplication of lower lip and mandible--a rare diprosopus. Int J Pediatr Otorhinolaryngol. Jan. 2011;75(1):131-3. X-1. [pmid: 21067822].
1252 Torres CP, Gomes-Silva JM, Mellara TS, et al. Dental care management in a child with recessive dystrophic epidermolysis bullosa. Braz Dent J. 2011;22(6):511-6. X-1. [pmid: 22189648].
1253 Tuli A, Sachdev V, Singh A, et al. Physical and dental manifestations of oral-facial-digital syndrome type I. J Indian Soc Pedod Prev Dent. Dec. 2011;29(6 Suppl 2):S83-6. X-1. [pmid: 22169845].
1254 Yang Y, Sun M, Ma Q, et al. Bleomycin A5 sclerotherapy for cervicofacial lymphatic malformations. J Vasc Surg. Jan. 2011;53(1):150-5. X-1. [pmid: 20843632].
1255 Zadeh HH. Minimally invasive treatment of maxillary anterior gingival recession defects by vestibular incision subperiosteal tunnel access and platelet-derived growth factor BB. Int J Periodontics Restorative Dent. Nov-Dec. 2011;31(6):653-60. X-1. [pmid: 22140667].
1256 Burning mouth syndrome diagnosis. Dental Abstracts. 2012;57(6):313-4. PMID:. X-1.
1257 Journal club. Another year, another top-10 list. Contemp Pediatr. 2012;29(3):17. PMID:. X-1, X-2.
1258 Bajnrauh R. The Regan fellowship: a window into international surgical care. Ann Plast Surg. Nov. 2012;69(5):500-1. X-1. [pmid: 23038135].
1259 Baser NT, Terzioglu A, Aslan G. Reconstruction of vermilion deficiencies: the running V-flap technique. J Plast Reconstr Aesthet Surg. Oct. 2012;65(10):1331-4. X-1. [pmid: 22647568].
1260 Bhojwani KM, Hegde MC, Alva A, et al. Papillary carcinoma in a lingual thyroid: an unusual presentation. Ear Nose Throat J. Jul. 2012;91(7):289-91. X-1. [pmid: 22829035].
1261 Bonet C, Penarrocha-Oltra D, Minguez JM, et al. Oral teratomas: a report of 5 cases. J Oral Maxillofac Surg. Dec. 2012;70(12):2809-13. X-1. [pmid: 22883319].
1262 Brown A. A tale of two tongue ties. MIDIRS Midwifery Digest. 2012;22(3):379-82. PMID:. X-1.
1263 Buretic-Tomljanovic A, Petaros A, Suc EG, et al. Craniofacial morphologic and anthropometric features of Croatian schizophrenia patients and non-psychiatric controls--a pilot study. Anthropol Anz. 2012;69(4):379-97. X-1. [pmid: 23350152].
1264 Čakrta O, Vyhnálekc M, Slabý K, et al. Balance rehabilitation therapy by tongue electrotactile biofeedback in patients with degenerative cerebellar disease. NeuroRehabilitation. 2012;31(4):429-34. PMID:. X-1. [pmid: 23232167].
1265 Castro CH, De Carvalho MF, Veloso DC, et al. An alternative technique using a gutta percha points and blue methylene to excision of congenital fistula of lower lip in patient with Van der Woude syndrome. Stomatologija. 2012;14(2):60-4. X-1. [pmid: 23037784].
1266 Chang CH, Fan YH, Tong-Long Lin A, et al. Bladder outlet obstruction due to labial agglutination. J Chin Med Assoc. Jan. 2012;75(1):40-2. X-1. [pmid: 22240536].
1267 Cioffi I, Piccolo A, Tagliaferri R, et al. Pain perception following first orthodontic archwire placement--thermoelastic vs superelastic alloys: a randomized controlled trial. Quintessence Int. Jan. 2012;43(1):61-9. X-1. [pmid: 22259810].
1268 de Figueredo AA, de Pochat VD, Barreto TF, et al. Management of an unusual presentation of Ascher syndrome. J Craniofac Surg. Nov. 2012;23(6):e570-1. X-1. [pmid: 23172481].
1269 Desrosiers TA, Lawson CC, Meyer RE, et al. Maternal occupational exposure to organic solvents during early pregnancy and risks of neural tube defects and orofacial clefts. Occup Environ Med. Jul. 2012;69(7):493-9. X-1. [pmid: 22447643].
1270 Devishree, Gujjari SK, Shubhashini PV. Frenectomy: a review with the reports of surgical techniques. J Clin Diagn Res. Nov. 2012;6(9):1587-92. X-2. [pmid: 23285469].
1271 Di Veroli A, Goretti E, Paumen ML, et al. Induction of mouthpart deformities in chironomid larvae exposed to contaminated sediments. Environ Pollut. Jul. 2012;166:212-7. X-1. [pmid: 22516711].
1272 Di Veroli A, Selvaggi R, Goretti E. Chironomid mouthpart deformities as indicator of environmental quality: a case study in Lake Trasimeno (Italy). J Environ Monit. May. 2012;14(5):1473-8. X-1. [pmid: 22453512].
1273 Drake-Lee A, Sandhu D. The future training of surgeons to manage patients with cleft lip and palate disorders. Br J Hosp Med (Lond). Feb. 2012;73(2):101-5. X-1. [pmid: 22504753].
1274 Ellis H. Anatomy of the salivary glands. Surgery (United Kingdom). November. 2012;30(11):569-72. X-1.
1275 Eswara U. Dystrophic epidermolysis bullosa in a child. Contemp Clin Dent. Jan. 2012;3(1):90-2. X-1. [pmid: 22557906].
1276 Farronato G, Salvadori S, Giannini L, et al. Congenital macroglossia: surgical and orthodontic management. Prog Orthod. May. 2012;13(1):92-8. X-3. [pmid: 22583592].
1277 Feldman HS, Jones KL, Lindsay S, et al. Prenatal alcohol exposure patterns and alcohol-related birth defects and growth deficiencies: a prospective study. Alcohol Clin Exp Res. Apr. 2012;36(4):670-6. X-1. [pmid: 22250768].
1278 Fischer KR, Alaa K, Schlagenhauf U, et al. Root coverage with a modified lateral sliding flap - a case series. Eur J Esthet Dent. Summer. 2012;7(2):120-8. X-1. [pmid: 22645727].
1279 Garca MF, Goktas U, Isik Y, et al. Is the coexistence of intraoral synechia and cleft palate anomaly a sequence?. J Craniofac Surg. May. 2012;23(3):e194-5. X-1. [pmid: 22627430].
1280 Gargari M, Autili N, Petrone A, et al. Using the diode laser in the lower labial frenum removal. Oral Implantol (Rome). Apr. 2012;5(2-3):54-7. X-1. [pmid: 23285407].
1281 Garib DG, Janson G, dos Santos PB, et al. Orthodontic movement of a maxillary incisor through the midpalatal suture: a case report. Angle Orthod. Mar. 2012;82(2):370-9. X-1. [pmid: 21883023].
1282 Germa A, Marret S, Thiriez G, et al. Neonatal factors associated with alteration of palatal morphology in very preterm children: the EPIPAGE cohort study. Early Hum Dev. Jun. 2012;88(6):413-20. X-1. [pmid: 22088785].
1283 Grandi D. The “Interdisciplinary Orofacial Examination Protocol for Children and Adolescents”: a resource for the interdisciplinary assessment of the stomatognatic system. Int J Orofacial Myology. Nov. 2012;38:15-26. X-1. [pmid: 23362750].
1284 Hekman JP, Karas AZ, Dreschel NA. Salivary cortisol concentrations and behavior in a population of healthy dogs hospitalized for elective procedures. Appl Anim Behav Sci. Nov. 2012;141(3-4). X-1. [pmid: 24204086].
1285 Hou T, Hu S, Jiang X. Tongue coblation via the ventral approach for obstructive sleep apnea-hypopnea syndrome surgery. Laryngoscope. Nov. 2012;122(11):2582-6. X-1. [pmid: 22965646].
1286 Hou T, Shao J, Fang S. The definition of the V zone for the safety space of functional surgery of the tongue. Laryngoscope. Jan. 2012;122(1):66-70. X-1. [pmid: 22183629].
1287 Jackson R. Improving breastfeeding outcomes: the impact of tongue-tie. Community Pract. Jun. 2012;85(6):42-4. X-2. [pmid: 22779397].
1288 Kaneko T, Horie N, Shimoyama T. Congenital mucocele in the tongue: report of a case. J Oral Maxillofac Surg. Nov. 2012;70(11):2596-9. X-1. [pmid: 22520564].
1289 Kim SJ, Choi JY, Baek SH. Evaluation of canting correction of the maxillary transverse occlusal plane and change of the lip canting in Class III two-jaw orthognathic surgery. Angle Orthod. Nov. 2012;82(6):1092-7. X-1. [pmid: 22515938].
1290 Kornstein AN. Ulthera for silicone lip correction. Plast Reconstr Surg. Jun. 2012;129(6):1014e-5e. X-1. [pmid: 22634679].
1291 Lopatin S. Dental care for your special needs kid?. Yup! Exceptional Parent. 2012;42(8):49. PMID:. X-1.
1292 Manjila S, Miller EA, Vadera S, et al. Duplication of the pituitary gland associated with multiple blastogenesis defects: Duplication of the pituitary gland (DPG)-plus syndrome. Case report and review of literature. Surg Neurol Int. Jan. 2012;3(1). X-1.
1293 Marquezan M, de Freitas AO, Nojima LI. Miniscrew covering: an alternative to prevent traumatic lesions. Am J Orthod Dentofacial Orthop. Feb. 2012;141(2):242-4. X-1. [pmid: 22284292].
1294 McGee TL, Grima MT, Hewson ID, et al. First Australian experiences with an oral volume restriction device to change eating behaviors and assist with weight loss. Obesity (Silver Spring). Jan. 2012;20(1):126-33. X-1. [pmid: 22016093].
1295 Mello SM, Paulo CAR, Alves C. Oral considerations in the management of sickle cell disease: a case report. Oral Health Dent Manag. Sep. 2012;11(3):125-8. X-1. [pmid: 22976572].
1296 Nguyen-Hieu T, Ha Thi BD, Do Thu H, et al. Gingival recession associated with predisposing factors in young vietnamese: a pilot study. Oral Health Dent Manag. Sep. 2012;11(3):134-44. X-1. [pmid: 22976574].
1297 Prakash S, Ahuja S, Rathod C. Dopa responsive burning mouth syndrome: restless mouth syndrome or oral variant of restless legs syndrome?. J Neurol Sci. Sep. 15. 2012;320(1-2):156-60. X-1. [pmid: 22819057].
1298 Saccomanno S, Antonini G, D'Alatri L, et al. Causal relationship between malocclusion and oral muscles dysfunction: a model of approach. Eur J Paediatr Dent. Dec. 2012;13(4):321-3. X-1. [pmid: 23270292].
1299 Sant' Anna AE, Hazarbassanov RM, de Freitas D, et al. Minor salivary glands and labial mucous membrane graft in the treatment of severe symblepharon and dry eye in patients with Stevens-Johnson syndrome. Br J Ophthalmol. Feb. 2012;96(2):234-9. X-1. [pmid: 21527414].
1300 Sant'Anna EF, Marquezan M, Sant'Anna CF. Impacted incisors associated with supernumerary teeth treated with a modified Haas appliance. Am J Orthod Dentofacial Orthop. Dec. 2012;142(6):863-71. X-1. [pmid: 23195372].
1301 Scott SE, Khwaja M, Low EL, et al. A randomised controlled trial of a pilot intervention to encourage early presentation of oral cancer in high risk groups. Patient Educ Couns. 2012;88(2):241-8. PMID:. X-1. [pmid: 22521755].
1302 Seidel AC, Rossetti LP, Mangolim AS, et al. Aneurysm of the superior labial artery. Ann Vasc Surg. Jul. 2012;26(5):733.e5-7. X-1. [pmid: 22664296].
1303 Sheikh S, Pallagatti S, Gupta D, et al. Tuberculous osteomyelitis of mandibular condyle: a diagnostic dilemma. Dentomaxillofac Radiol. Feb. 2012;41(2):169-74. X-1. [pmid: 22074872].
1304 Spiliopoulos M, Jayakar P, Spiliopoulos D. Facial dysmorphism and skin manifestations in a patient with inherited systemic hyalinosis. J Pediatr. Mar. 2012;160(3):523. X-1. [pmid: 22048044].
1305 Stavropoulos D, Tarnow P, Mohlin B, et al. Comparing patients with Apert and Crouzon syndromes--clinical features and cranio-maxillofacial surgical reconstruction. Swed Dent J. 2012;36(1):25-34. X-1. [pmid: 22611902].
1306 Svee A, Frykholm P, Linder A, et al. Early release of interalveolar synechiae under general anesthesia through fiberscopic nasal intubation. J Craniofac Surg. Jul. 2012;23(4):e299-302. X-1. [pmid: 22801158].
1307 Torres JN, Caracas HC, Bolognese AM, et al. Conservative approach for a patient with extreme delay in maxillary lateral incisor development. Am J Orthod Dentofacial Orthop. Jun. 2012;141(6):773-82. X-1. [pmid: 22640679].
1308 Tweed V. Quick fix: cold sores. Better Nutrition. 2012;74(4):10. PMID:. X-1.
1309 van den Elzen ME, Versnel SL, Duivenvoorden HJ, et al. Assessing nonacceptance of the facial appearance in adult patients after complete treatment of their rare facial cleft. Aesthetic Plast Surg. Aug. 2012;36(4):938-45. X-1. [pmid: 22527587].
1310 Van Lierde K, Galiwango G, Hodges A, et al. Impact of tongue reduction on overall speech intelligibility, articulation and oromyofunctional behavior in 4 children with Beckwith-Wiedemann syndrome. Folia Phoniatr Logop. 2012;64(2):55-63. X-1. [pmid: 22095257].
1311 Wehby GL, Murray JC, Wilcox A, et al. Smoking and body weight: evidence using genetic instruments. Econ Hum Biol. Mar. 2012;10(2):113-26. X-1. [pmid: 22024417].
1312 Yang JR. Twenty-one cases of hemorrhoids treated with bloodletting at Yinjiao (GV 28). World Journal of Acupuncture - Moxibustion. 2012;22(3):63-4. X-1.
1313 Amooei AB, Rahnama A. A rare case of epignathus combined with soft cleft palate, bifida tongue, and lingual lipoma. Journal of Kerman University of Medical Sciences. October. 2013;20(5):520-5. X-1.
1314 Bachmeyer MH, Gulotta CS, Piazza CC. Liquid to baby food fading in the treatment of food refusal. Behav Interv. 2013;28(4):281-98. PMID:. X-1.
1315 Bafna Y, Khandelwal V, Bafna M, et al. Management of sublingual ulceration in a 12-month-old child. BMJ Case Rep. 2013;2013. X-1. [pmid: 23975923].
1316 Barbosa MV, Nahas FX, Ferreira LM. Anatomy of the depressor septi nasi muscle: the basis for correction of deformities of the nose/lip junction. J Plast Surg Hand Surg. Apr. 2013;47(2):102-5. X-1. [pmid: 23402537].
1317 Barwood CHS, Murdoch BE, Goozee JV, et al. Investigating the neural basis of stuttering using transcranial magnetic stimulation: Preliminary case discussions. Speech, Language and Hearing. 2013;16(1):18-27. PMID:. X-1.
1318 Bhusari PA, Verma S, Maheshwari S, et al. Modified frenectomy: a review of 3 cases with concerns for esthetics. Gen Dent. Aug. 2013;61(5):56-9. X-1. [pmid: 23928441].
1319 Bosecker J. Hydrogen peroxide in dentistry. RDH. 2013;33(6):60-90. PMID:. X-1.
1320 Camargo ZA, Marchesan IQ, Oliveira LR, et al. Lingual frenectomy and alveolar tap production: an acoustic and perceptual study. Logoped Phoniatr Vocol. Dec. 2013;38(4):157-66. X-1. [pmid: 23826654].
1321 Chen CH, Liao HT, Shyu VB, et al. Inverted-T lip reduction for lower lip repair in Van der Woude syndrome: a review and comparison of aesthetic results. Int J Oral Maxillofac Surg. Feb. 2013;42(2):198-203. X-1. [pmid: 23290085].
1322 Cilingir A, Bilhan H, Baysal G, et al. The impact of frenulum height on strains in maxillary denture bases. J Adv Prosthodont. Nov. 2013;5(4):409-15. X-1. [pmid: 24353878].
1323 Crincoli V, Perillo L, Di Bisceglie MB, et al. Friction forces during sliding of various brackets for malaligned teeth: an in vitro study. ScientificWorldJournal. 2013;2013:871423. X-1. [pmid: 23533364].
1324 de Queiroz AM, de Siqueira Melara T, Fernandes Ferreira PD, et al. Dental findings and special care in patients with Angelman syndrome: a report of three cases. Spec Care Dentist. Jan-Feb. 2013;33(1):40-5. X-1. [pmid: 23278148].
1325 De Santis D, Bertossi D, Zanotti G, et al. Nd-YAP laser assisted frenulectomy: a case series on 23 patients. Minerva Stomatol. 2013. Aug. 1. X-1. [pmid: 23903443].
1326 Douglas PS. Rethinking “posterior” tongue-tie. Breastfeed Med. Dec. 2013;8(6):503-6. X-2. [pmid: 24143939].
1327 Eigen M. Psychoanalytic taste buds. Psychoanal Rev. Oct. 2013;100(5):665-7. X-1. [pmid: 24063267].
1328 Falci SGM, Mesquita ATM, Romanach MJ, et al. Oral leiomyomatous hamartoma associated with upper lip midline malformation: Case report and review of the literature. Int J pediatr Otorhinolaryngol Extra. January. 2013;8(1):e17-e21. X-1.
1329 Fortuna G, Chainani-Wu N, Lozada-Nur F, et al. Epidermolysis Bullosa Oropharyngeal Severity (EBOS) score: a multicenter development and reliability assessment. J Am Acad Dermatol. Jan. 2013;68(1):83-92. X-1. [pmid: 22575158].
1330 Ghoshal S, Kumar R, Jha V, et al. Oral carcinoma in two young recipients of stem cell transplant. Clin Cancer Investig J. January-April. 2013;2(1):83-5. X-1.
1331 Gomez-Moreno G, Aguilar-Salvatierra A, Guardia J, et al. The efficacy of a topical sialogogue spray containing 1% malic acid in patients with antidepressant-induced dry mouth: a double-blind, randomized clinical trial. Depress Anxiety. Feb. 2013;30(2):137-42. X-1. [pmid: 23124914].
1332 Harrison-Woolrych M, Paterson H, Tan M. Exposure to the smoking cessation medicine varenicline during pregnancy: a prospective nationwide cohort study. Pharmacoepidemiol Drug Saf. Oct. 2013;22(10):1086-92. X-1. [pmid: 23926076].
1333 Hilton S. The wonder of breast milk. Pract Midwife. Jul-Aug. 2013;16(7):37-8. 40. X-1. [pmid: 23909203].
1334 Hopp RN, de Siqueira DC, Sena-Filho M, et al. Oral vascular malformation in a patient with hereditary hemorrhagic telangiectasia: a case report. Spec Care Dentist. May-Jun. 2013;33(3):150-3. X-1. [pmid: 23600987].
1335 Ingstrup KG, Liang H, Olsen J, et al. Maternal bereavement in the antenatal period and oral cleft in the offspring. Hum Reprod. Apr. 2013;28(4):1092-9. X-1. [pmid: 23293222].
1336 Janiszewska-Olszowska J, Gawrych E, Dydyk A, et al. Oro-palatal dysplasia Bettex-Graf--clinical findings, genetic background, treatment. J Craniomaxillofac Surg. Jan. 2013;41(1):e29-32. X-1. [pmid: 22831831].
1337 Junior RM, Gueiros LA, Silva IH, et al. Labial frenectomy with Nd:YAG laser and conventional surgery: a comparative study. Lasers Med Sci. 2013. Oct. 22. X-1. [pmid: 24146237].
1338 Khade JA, Phadnaik M. Prevalence of gingival recession and its associated etiologic factors: A cross- Sectional study. Indian Journal of Public Health Research and Development. April-June. 2013;4(2):119-23. X-1.
1339 Kittur MA, Padgett J, Drake D. Management of macroglossia in Beckwith-Wiedemann syndrome. Br J Oral Maxillofac Surg. Jan. 2013;51(1):e6-8. X-1. [pmid: 22341741].
1340 Kiviat E. Risks to biodiversity from hydraulic fracturing for natural gas in the Marcellus and Utica shales. Ann N Y Acad Sci. May. 2013;1286:1-14. X-1. [pmid: 23701448].
1341 Kondamudi NP, Ayush G, Kaur R. Magnet balls stuck to the frenulum of the lip. J Emerg Med. Oct. 14. 2013;46(3):345-7. X-1. [pmid: 24135504].
1342 Kummer TR, Nagano HC, Tavares SS, et al. Oral manifestations and challenges in dental treatment of epidermolysis bullosa dystrophica. J Dent Child (Chic). May-Aug. 2013;80(2):97-100. X-1. [pmid: 24011299].
1343 Ma J, Zhao W, Ma RM, et al. Investigation on maternal physiological and psychological factors of cheilopalatognathus. Clin Exp Obstet Gynecol. 2013;40(3):384-8. X-1. [pmid: 24283171].
1344 Macpherson P. Dysgeusia: a matter of taste and quality of life. Dental Nursing. 2013;9(12):702-5. PMID:. X-1.
1345 Maruani A, Brown S, Lorette G, et al. Lack of effect of propranolol in the treatment of lymphangioma in two children. Pediatr Dermatol. May-Jun. 2013;30(3):383-5. X-1. [pmid: 23005572].
1346 McLaren LB, Mactier H, Tolmie J. Situs inversus totalis and congenital hypoglossia associated with atrial ectopic bradycardia and normal neurodevelopmental outcome. Clin Dysmorphol. Jan. 2013;22(1):36-8. X-1. [pmid: 23151441].
1347 Murdoch BE, Barwood CHS, Goozée JV, et al. Determining the optimal current direction of transcranial magnetic stimulation to induce motor responses in the tongue: A preliminary study of neurologically healthy individuals. Speech, Language and Hearing. 2013;16(2):56-67. PMID:. X-1.
1348 Nakashima T, Uematsu N, Shibamori M, et al. Establishment of an X-ray irradiation-induced glossitis model in rats: Biphasic elevation of proinflammatory cytokines and chemokines. The Journal of Pharmacology and Experimental Therapeutics. 2013;347(3):660-8. PMID:. X-1. [pmid: 24060545].
1349 Onisor I, Pecie R, Chaskelis I, et al. Cutting and coagulation during intraoral soft tissue surgery using Er: YAG laser. Eur J Paediatr Dent. Jun. 2013;14(2):140-5. X-1. [pmid: 23758465].
1350 Padula AM, Tager IB, Carmichael SL, et al. The association of ambient air pollution and traffic exposures with selected congenital anomalies in the San Joaquin Valley of California. Am J Epidemiol. May. 15. 2013;177(10):1074-85. X-1. [pmid: 23538941].
1351 Pauws E, Peskett E, Boissin C, et al. X-linked CHARGE-like Abruzzo-Erickson syndrome and classic cleft palate with ankyloglossia result from TBX22 splicing mutations. Clin Genet. Apr. 2013;83(4):352-8. X-1. [pmid: 22784330].
1352 Pereira VJ, Sell D, Tuomainen J. Effect of maxillary osteotomy on speech in cleft lip and palate: Perceptual outcomes of velopharyngeal function. International Journal of Language & Communication Disorders. 2013;48(6):640-50. PMID:. X-1. [pmid: 24165361].
1353 Petroianu GA. Treatment of singultus by traction on the tongue: an eponym revised. J Hist Neurosci. 2013;22(2):183-90. X-1. [pmid: 23586546].
1354 Pickard A, Lobo C, Stoddart PA. The effect of rocuronium and sugammadex on neuromuscular blockade in a child with congenital myotonic dystrophy type 1. Paediatr Anaesth. Sep. 2013;23(9):871-3. X-1. [pmid: 23763618].
1355 Silva CO, Ribeiro-Junior NV, Campos TV, et al. Excessive gingival display: treatment by a modified lip repositioning technique. J Clin Periodontol. Mar. 2013;40(3):260-5. X-1. [pmid: 23278672].
1356 Sitzman TJ, Fisher DM. Presurgical unilateral cleft lip anthropometrics: incidence of vermilion height asymmetry. Plast Reconstr Surg. Jun. 2013;131(6):935e-7e. X-1. [pmid: 23629075].
1357 Sudarshan R, Annigeri RG, Sree Vijayabala G. Bird-headed dwarfism (Seckel syndrome) - A rare case report. TAF Preventive Medicine Bulletin. 2013;12(2):209-12. X-1.
1358 Vogt C, Langer-Jaesrich M, Elsasser O, et al. Effects of inbreeding on mouthpart deformities of Chironomus riparius under sublethal pesticide exposure. Environ Toxicol Chem. Feb. 2013;32(2):423-5. X-1. [pmid: 23161736].
1359 Vyas V, Agha R, Ahmad T. Improving oral function and cosmesis in a case of Freeman-Sheldon syndrome. BMJ Case Rep. 2013;2013. X-1. [pmid: 24225909].
1360 Woo SH. Endoscope-assisted intraoral removal of the thyroid isthmus mass using a frenotomy incision. J Laparoendosc Adv Surg Tech A. Sep. 2013;23(9):787-90. X-1. [pmid: 23781955].
1361 Woo SH, Jeong HS, Kim JP, et al. Endoscope-assisted intraoral removal of ectopic thyroid tissue using a frenotomy incision. Thyroid. May. 2013;23(5):605-8. X-1. [pmid: 23410135].
1362 Yadav S, Upadhyay M, Uribe F, et al. Palatally impacted maxillary canine with congenitally missing lateral incisors and midline diastema. Am J Orthod Dentofacial Orthop. Jul. 2013;144(1):141-6. X-1. [pmid: 23810055].
1363 Yu Q, Gong X, Shen G. CAD presurgical nasoalveolar molding effects on the maxillary morphology in infants with UCLP. Oral Surg Oral Med Oral Pathol Oral Radiol. Oct. 2013;116(4):418-26. X-1. [pmid: 24035109].
1364 Adamec I, Grahovac G, Krbot Skoric M, et al. Tongue somatosensory-evoked potentials in microvascular decompression treated trigeminal neuralgia. Acta Neurologica Belgica. 2014;114(1):55-8. PMID:. X-1. [pmid: 24277571].
1365 da Silva LA, de Siqueira JTT, Teixeira MJ, et al. The role of xerostomia in burning mouth syndrome: A case-control study. Arquivos de Neuro-Psiquiatria. 2014;72(2):91-8. PMID:. X-1. [pmid: 24604360].
1366 Desmurget M, Richard N, Harquel S, et al. Neural representations of ethologically relevant hand/mouth synergies in the human precentral gyrus. PNAS Proceedings of the National Academy of Sciences of the United States of America. 2014;111(15):5718-22. PMID:. X-1.
1367 Finigan V. Tongue-tied. Midwives. 2014;17(2):54. [pmid: 24873077]. X-1.
1368 Gonzalez MG, Castro MP, Nieto DV, et al. Oral-facial-digital syndrome type I: Surgical approach and a case report. J Plast Reconstr Aesthet Surg. Jul. 22. 2014;67(3):396-8. X-1. [pmid: 23886557].
1369 Kantaputra PN, Kayserili H, Guven Y, et al. Oral manifestations of 17 patients affected with mucopolysaccharidosis type VI. J Inherit Metab Dis. Aug. 22. 2014;37(2):263-8. X-1. [pmid: 23974652].
1370 Kothari M, Svensson P, Nielsen JF, et al. Influence of position and stimulation parameters on intracortical inhibition and facilitation in human tongue motor cortex. Brain Research. 2014;1557:83-9. PMID:. X-1. [pmid: 24534367].
1371 Lee J, Mandel L. Rigo-Fede disease: case report. N Y State Dent J. Mar. 2014;80(2):36-7. X-1. [pmid: 24851391].
1372 Llames S, Recuero I, Romance A, et al. Tissue-engineered oral mucosa for mucosal reconstruction in a pediatric patient with hemifacial microsomia and ankyloglossia. Cleft Palate Craniofac J. Jul. 23. 2014;51(2):246-51. X-1. [pmid: 23879858].
1373 McGirr A, Davis L, Vila-Rodriguez F. Idiopathic burning mouth syndrome: A common treatment-refractory somatoform condition responsive to ECT. Psychiatry Research. 2014;216(1):158-9. PMID:. X-1. [pmid: 24560021].
1374 Osborne B, Yao TW, Wang XM, et al. A rare variant in human fibroblast activation protein associated with ER stress, loss of enzymatic function and loss of cell surface localisation. Biochim Biophys Acta. Jul. 2014;1844(7):1248-59. X-1. [pmid: 24717288].
1375 Rubins RP, Tolmie PN, Corsig KT, et al. Subepithelial connective tissue graft with purified rhPDGF-BB for the treatment of mandibular recession defects: a consecutive case series. Int J Periodontics Restorative Dent. May-Jun. 2014;34(3):315-21. X-1. [pmid: 24804282].
1376 Sane VD, Pawar S, Modi S, et al. Is use of LASER really essential for release of tongue-tie?. J Craniofac Surg. May. 2014;25(3):e279-80. X-3. [pmid: 24785748].
1377 Seo YJ, Kim SJ, Munkhshur J, et al. Treatment and retention of relapsed anterior open-bite with low tongue posture and tongue-tie: A 10-year follow-up. Korean J Orthod. Jul. 2014;44(4):203-16. X-2, X-3. [pmid: 25133135].
1378 Sinha J, Kumar V, Tripathi AK, et al. Untangle lip through Z-plasty. BMJ Case Rep. 2014;2014. X-1, X-3. [pmid: 25240003].
1379 Todd DA. Tongue-tie in the newborn: what, when, who and how? Exploring tongue-tie division. Breastfeed Rev. Jul. 2014;22(2):7-10. X-1, X-2. [pmid: 25109095].
1380 Upadhyay P, Verma A, Grover D, et al. A rare case of ankyloglossia and bilateral fusion of mandibular incisors. Gen Dent. Sep-Oct. 2014;62(5):68-70. X-1, X-2. [pmid: 25184721].
1381 Vogel L. Low-risk snip may help tongue-tied infants breastfeed. Cmaj. Jan. 7. 2014;186(1):20. X-1. [pmid: 24324017].
1382 Wolkowicz IR, Herkovits J, Perez Coll CS. Stage-dependent toxicity of bisphenol a on Rhinella arenarum (anura, bufonidae) embryos and larvae. Environ Toxicol. Feb. 2014;29(2):146-54. X-1. [pmid: 22052622].

## Full-Text Review Exclusion Reasons

X-4 | Not original research
X-5 | Does not evaluate effectiveness of treatment for ankyloglossia and/or concomitant lip-tie or is not a case series reporting on harms of treatments for ankyloglossia and/or concomitant lip-tie.
X-6 | Participants are not target age group

1 McEnery ET, Gaines FP. Tongue-tie in infants and children. J Pediatr. 1941;18:252-5. X-4.
2 Rogers JG, Douglas BL. Surgical correction of ankyloglossia. U S Armed Forces Med J. May. 1952;3(5):695-7. X-5, X-6. [pmid: 14931756].
3 Pickrell K, Masters F, Georgiade N, et al. Restoration of lip contour using fascia, tendon, and dermal grafts. Plast Reconstr Surg (1946). Aug. 1954;14(2):126-37. X-5, X-6. [pmid: 13194382].
4 Oldfield MC. Congenitally short frenula of upper lip and tongue. Lancet. Mar. 12. 1955;268(6863):528-30. X-4, X-5. [pmid: 14354917].
5 Tuerk M, Lubit EC. Ankyloglossia. Plast Reconstr Surg Transplant Bull. Sep. 1959;24:271-6. X-4. [pmid: 13839768].
6 Spitzer R. Partial ankyloglossia. Report of a case. Oral Surg Oral Med Oral Pathol. Jul. 1960;13:787-90. X-6. [pmid: 13833411].
7 Wallace AF. Tongue-tie. Lancet. Aug. 24. 1963;2(7304):377-8. X-4. [pmid: 14044288].
8 Gruzdkova E. Plasttic materials in restorative surgery of the lower jaw. Br J Plast Surg. Jan. 1965;18:97-104. X-5, X-6. [pmid: 14256828].
9 Mohnac AM. Surgical correction of maxillomandibular deformities. J Oral Surg. Jul. 1965;23:393-407. X-4, X-5, X-6. [pmid: 14300218].
10 Strader RJ, House RE. Treatment of tongue ankylosis with Z-plasty. Oral Surg Oral Med Oral Pathol. Jul. 1966;22(1):120-4. X-5, X-6. [pmid: 5220018].
11 Graber TM. Team effort: oral surgery and orthodontics. J Oral Surg. May. 1967;25(3):201-24. X-4, X-5, X-6. [pmid: 5227942].
12 Guerrero-Santos J, Altamirano JT. The use of W-plasty for the correction of double lip deformity. Plast Reconstr Surg. May. 1967;39(5):478-81. X-5, X-6. [pmid: 5336915].
13 Hooley JR. The infant's mouth. J Am Dent Assoc. Jul. 1967;75(1):95-103. X-4, X-5, X-6. [pmid: 5338747].
14 Clark DC. Immediate closure of labial diastema by frenectomy and maxillary ostectomy. J Oral Surg. Apr. 1968;26(4):273-6. X-4, X-5, X-6. [pmid: 5237790].
15 Fawcus R. Dental problems in speech pathology. Proc R Soc Med. Jun. 1968;61(6):619-22. X-4, X-5, X-6. [pmid: 5662219].
16 Fletcher SG, Meldrum JR. Lingual function and relative length of the lingual frenulum. J Speech Hear Res. Jun. 1968;11(2):382-90. X-5. [pmid: 5664266].
17 Horton CE, Crawford HH, Adamson JE, et al. Tongue-tie. Cleft Palate J. Jan. 1969;6:8-23. X-4, X-6. [pmid: 5251442].
18 Parker DA, Skalko RG. Congenital asymmetry: report of 10 cases with associated developmental abnormalities. Pediatrics. Oct. 1969;44(4):584-9. X-5. [pmid: 5346637].
19 Berggren RB, Duran RJ. Pitfalls in the treatment of the Pierre Robin Syndrome. J Pediatr Surg. Oct. 1970;5(5):539-40. X-5. [pmid: 5505691].
20 Clifford FO. Minor surgery in the orthodontic office. J Clin Orthod. Oct. 1970;14(10):582-5. X-4, X-5, X-6. [pmid: 5275234].
21 Farina R, Cury E. Labial malocclusion (labrium arcuatum). Br J Plast Surg. Jul. 1970;23(3):254-5. X-5, X-6. [pmid: 5469596].
22 Cohen MM Sr., Cohen MM Jr. The oral manifestations of trisomy G-1 (Down syndrome). Birth Defects Orig Artic Ser. Jun. 1971;7(7):241-51. X-4, X-5, X-6. [pmid: 4281324].
23 Waldrop MF, Goering JD. Hyperactivity and minor physical anomalies in elementary school children. Am J Orthopsychiatry. Jul. 1971;41(4):602-7. X-4, X-5. [pmid: 4997640].
24 Bishara SE. Management of diastemas in orthodontics. Am J Orthod. Jan. 1972;61(1):55-63. X-4, X-5, X-6. [pmid: 4500187].
25 Prowler JR. Anterior Z-plasty ridge extension. Oral Surg Oral Med Oral Pathol. Feb. 1972;33(2):172-8. X-4, X-5, X-6. [pmid: 4500591].
26 Bergstrom K, Jensen R, Martensson B. The effect of superior labial frenectomy in cases with midline diastema. Am J Orthod. Jun. 1973;63(6):633-8. X-5. [pmid: 4513452].
27 Davies D, Morrison G, Miller BH. Reduplication of the mouth and mandible. Br J Plast Surg. Jan. 1973;26(1):84-9. X-5. [pmid: 4685311].
28 Goldberger JM. Tongue thrust: report of cases. J Am Dent Assoc. Mar. 1973;86(3):667-71. X-5. [pmid: 4510005].
29 Hasan N. Tongue tie as a cause of deformity of lower central incisor. J Pediatr Surg. Dec. 1973;8(6):985. X-4, X-5, X-6. [pmid: 4785587].
30 Austermann KH, Machtens E. The influence of tongue asymmetries on the development of jaws and the position of teeth. Int J Oral Surg. 1974;3(5):261-5. X-5, X-6. [pmid: 4214005].
31 Ketty N, Sciullo PA. Ankyloglossia with psychological implications. ASDC J Dent Child. Jan-Feb. 1974;41(1):43-6. X-5. [pmid: 4587849].
32 Quinn PO, Rapoport JL. Minor physical anomalies and neurologic status in hyperactive boys. Pediatrics. May. 1974;53(5):742-7. X-5. [pmid: 4207887].
33 Campbell PM, Moore JW, Matthews JL. Orthodontically corrected midline diastemas. A histologic study and surgical procedure. Am J Orthod. Feb. 1975;67(2):139-58. X-5, X-6. [pmid: 1054215].
34 Miller EL. Sometimes overlooked: preprosthetic surgery. J Prosthet Dent. Nov. 1976;36(5):484-90. X-4, X-5, X-6. [pmid: 789870].
35 Ayers FJ, Hilton LM. Treatment of ankyloglossia: report of case. ASDC J Dent Child. May-Jun. 1977;44(3):237-9. X-5. [pmid: 325044].
36 Kahnberg KE. Frenum surgery. I. A comparison of three surgical methods. Int J Oral Surg. Dec. 1977;6(6):328-33. X-5, X-6. [pmid: 415016].
37 Goldberg MP. The oral mucosa in childhood. Pediatr Clin North Am. May. 1978;25(2):239-62. X-4, X-5, X-6. [pmid: 673500].
38 Young EC, Sacks GK. Examining for tongue tie. Clin Pediatr (Phila). May. 1979;18(5):298. X-5. [pmid: 445932].
39 Monreal FJ. Asymmetric crying facies: an alternative interpretation. Pediatrics. Jan. 1980;65(1):146-9. X-5. [pmid: 7355012].
40 Maisels DO. Reduplication of the mouth and mandible. Br J Plast Surg. Jan. 1981;34(1):23-5. X-5. [pmid: 7459519].
41 Axinn S, Brasher WJ. Frenectomy plus free graft. J Prosthet Dent. Jul. 1983;50(1):16-9. X-4, X-5, X-6. [pmid: 6348274].
42 Lau JT, Ong GB. A grooved table-spoon for tongue-tie release and hernial neck transfixion. Aust N Z J Surg. Feb. 1983;53(1):61-2. X-4, X-5. [pmid: 6572504].
43 Lekkas C, Bruaset I. Ankyloglossia superior. Oral Surg Oral Med Oral Pathol. Jun. 1983;55(6):556-7. X-5. [pmid: 6576285].
44 Sato T, Iida M, Yamaguchi Y. A family with hereditary ankyloglossia complicated by heterochromia irides and a congenital clasped thumb. Int J Oral Surg. Oct. 1983;12(5):359-62. X-5. [pmid: 6420363].
45 Grenier J, Jones D. Giving thanks: turkey takes second place to hard work. Tex Med. Nov. 1984;80(11):61-3. X-4, X-5. [pmid: 6515573].
46 Diagnostic accuracy: effect on treatment planning. Proceedings of the Seventh Annual Symposium of the Society of Craniofacial Genetics. Denver, Colorado, June 17, 1984. Birth Defects Orig Artic Ser. 1985;21(2):1-151. X-4, X-5, X-6. [pmid: 4041571].
47 Casper J. Disorders of speech and voice. Pediatr Ann. Mar. 1985;14(3):220-1. 5. 9. X-4, X-5, X-6. [pmid: 4000737].
48 Williams WN, Waldron CM. Assessment of lingual function when ankyloglossia (tongue-tie) is suspected. J Am Dent Assoc. Mar. 1985;110(3):353-6. X-4, X-5, X-6. [pmid: 3858347].
49 Kronmiller JE. Oral soft tissue abnormalities in children. Pediatr Nurs. May-Jun. 1987;13(3):161-5. 91. X-4, X-5, X-6. [pmid: 3648645].
50 Bjornsson A, Arnason A, Tippet P. X-linked cleft palate and ankyloglossia in an Icelandic family. Cleft Palate J. Jan. 1989;26(1):3-8. X-5. [pmid: 2563678].
51 Pogrel MA. The carbon dioxide laser in soft tissue preprosthetic surgery. J Prosthet Dent. Feb. 1989;61(2):203-8. X-5, X-6. [pmid: 2497242].
52 Ankyloglossia (tongue-tie). J Hum Lact. Sep. 1990;6(3):101-55. X-4, X-5, X-6. [pmid: 2400548].
53 Ewart NP. A lingual mucogingival problem associated with ankyloglossia: a case report. N Z Dent J. Jan. 1990;86(383):16-7. X-5, X-6. [pmid: 2333177].
54 Ishimaru J, Toida M, Handa Y, et al. An infected congenital commissural lip fistula. Report of a case. Int J Oral Maxillofac Surg. Jun. 1990;19(3):160-1. X-5, X-6. [pmid: 2114460].
55 Jerrold L, Lowenstein LJ. The midline: diagnosis and treatment. Am J Orthod Dentofacial Orthop. Jun. 1990;97(6):453-62. X-5. [pmid: 2353675].
56 Marmet C, Shell E, Marmet R. Neonatal frenotomy may be necessary to correct breastfeeding problems. J Hum Lact. Sep. 1990;6(3):117-21. X-5. [pmid: 2205230].
57 Notestine GE. The importance of the identification of ankyloglossia (short lingual frenulum) as a cause of breastfeeding problems. J Hum Lact. Sep. 1990;6(3):113-5. X-5. [pmid: 2400555].
58 Ward N. Ankyloglossia: a case study in which clipping was not necessary. J Hum Lact. Sep. 1990;6(3):126-7. X-5. [pmid: 2400559].
59 Wilton JM. Sore nipples and slow weight gain related to a short frenulum. J Hum Lact. Sep. 1990;6(3):122-3. X-5. [pmid: 2400556].
60 Harris EF, Friend GW, Tolley EA. Enhanced prevalence of ankyloglossia with maternal cocaine use. Cleft Palate Craniofac J. Jan. 1992;29(1):72-6. X-5. [pmid: 1547252].
61 Sullivan MJ, Carroll WR, Kuriloff DB. Lateral arm free flap in head and neck reconstruction. Arch Otolaryngol Head Neck Surg. Oct. 1992;118(10):1095-101. X-5, X-6. [pmid: 1389060].
62 Marres HA, Cremers CW, Huygen PL, et al. The deafness, pre-auricular sinus, external ear anomaly and commissural lip pits syndrome--otological, vestibular and radiological findings. J Laryngol Otol. Jan. 1994;108(1):13-8. X-5. [pmid: 8133157].
63 Velanovich V. The transverse-vertical frenuloplasty for ankyloglossia. Mil Med. Nov. 1994;159(11):714-5. X-4, X-5, X-6. [pmid: 7885603].
64 Bullock N Jr. The use of the CO2 laser for lingual frenectomy and excisional biopsy. Compend Contin Educ Dent. Nov. 20. 22. 1995;16(11):1118-3. X-5, X-6. [pmid: 8598011].
65 Minami K, Sugahara T, Mori Y, et al. Ankyloglossia superior: report of a case. J Oral Maxillofac Surg. May. 1995;53(5):588-9. X-5. [pmid: 7722729].
66 Reed J, Baines D. Difficult intubation following bilateral subtemporal decompression. Anaesth Intensive Care. Feb. 1995;23(1):117-8. X-5. [pmid: 7778728].
67 Wiessinger D, Miller M. Breastfeeding difficulties as a result of tight lingual and labial frena: a case report. J Hum Lact. Dec. 1995;11(4):313-6. X-5. [pmid: 8634108].
68 Chidzonga MM, Lopez Perez VM, Mzezewa S. Treatment of median cleft of the lower lip, mandible, and bifid tongue with ankyloglossia. A case report. Int J Oral Maxillofac Surg. Aug. 1996;25(4):272-3. X-5. [pmid: 8910110].
69 Slavkin HC. Meeting the challenges of craniofacial-oral-dental birth defects. J Am Dent Assoc. May. 1996;127(5):681-2. X-4, X-5, X-6. [pmid: 8642148].
70 Wilder T, Gelesko A. Lingual frenums and frenectomies. Int J Orofacial Myology. 1997;23:47-9. X-5. [pmid: 9487829].
71 Fanibunda K, Adams A. Are the features of ankyloglossia limited to the lingual fraenum?. Dent Update. Sep. 1998;25(7):296-7. X-5. [pmid: 10478024].
72 Kotlow LA. Ankyloglossia (tongue-tie): a diagnostic and treatment quandary. Quintessence Int. Apr. 1999;30(4):259-62. X-4, X-5, X-6. [pmid: 10635253].
73 Morselli P, Vecchiet F, Marini I. Frenuloplasty by means of a triangular flap. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Feb. 1999;87(2):142-4. X-4, X-5, X-6. [pmid: 10052366].
74 Shashua D, Artun J. Relapse after orthodontic correction of maxillary median diastema: a follow-up evaluation of consecutive cases. Angle Orthod. Jun. 1999;69(3):257-63. X-5, X-6. [pmid: 10371432].
75 Al-Qattan MM. Congenital midline sinus of the upper lip. Ann Plast Surg. Jan. 2000;44(1):76-8. X-5, X-6. [pmid: 10651370].
76 Defabianis P. Ankyloglossia and its influence on maxillary and mandibular development. (A seven year follow-up case report). Funct Orthod. Oct-Dec. 2000;17(4):25-33. X-5. [pmid: 11307269].
77 Greenfield MF, Icochea R, Hoffman C, et al. Double lip: an unusual presentation. Cutis. Oct. 2000;66(4):253-6. X-5, X-6. [pmid: 11109146].
78 Livingstone VH, Willis CE, Abdel-Wareth LO, et al. Neonatal hypernatremic dehydration associated with breast-feeding malnutrition: a retrospective survey. Cmaj. Mar. 7. 2000;162(5):647-52. X-5. [pmid: 10738450].
79 Messner AH, Lalakea ML. Ankyloglossia: controversies in management. Int J Pediatr Otorhinolaryngol. Aug. 31. 2000;54(2-3):123-31. X-5, X-6. [pmid: 10967382].
80 Messner AH, Lalakea ML, Aby J, et al. Ankyloglossia: incidence and associated feeding difficulties. Arch Otolaryngol Head Neck Surg. Jan. 2000;126(1):36-9. X-5. [pmid: 10628708].
81 Ankyloglossia and breastfeeding. [French, English]. L'ankyloglossie et i'allaitement. Paediatrics and Child Health. 2002;7(4):269-70. 73. 74. X-4, X-5, X-6. [pmid: 20046302].
82 Garcia Pola MJ, Gonzalez Garcia M, Garcia Martin JM, et al. A study of pathology associated with short lingual frenum. ASDC J Dent Child. Jan-Apr. 2002;69(1):59-62. 12. X-5. [pmid: 12119815].
83 Hagiwara R, Fosnot SM, Alessi DM. Acoustic phonetics in a clinical setting: a case study of /r/-distortion therapy with surgical intervention. Clin Linguist Phon. Sep. 2002;16(6):425-41. X-5. [pmid: 12469449].
84 Mukai S, Nitta M. Correction of the glosso-larynx and resultant positional changes of the hyoid bone and cranium. Acta Otolaryngol. Sep. 2002;122(6):644-50. X-5, X-6. [pmid: 12403128].
85 O'Shea M. Neonatal issues. Licking the problem of tongue-tie. Br J Midwifery. 2002;10(2):90-2. X-4.
86 Fitz-Desorgher R. All tied up. Tongue tie and its implications for breastfeeding. Pract Midwife. Jan. 2003;6(1):20-2. X-4, X-5. [pmid: 12599967].
87 Naimer SA, Biton A, Vardy D, et al. Office treatment of congenital ankyloglossia. Med Sci Monit. Oct. 2003;9(10):Cr432-5. X-5. [pmid: 14523332].
88 Rommel N, De Meyer AM, Feenstra L, et al. The complexity of feeding problems in 700 infants and young children presenting to a tertiary care institution. J Pediatr Gastroenterol Nutr. Jul. 2003;37(1):75-84. X-5. [pmid: 12827010].
89 Tongue-tie: ankyloglossia. Bandolier. 2004;11(6):1-3. X-4.
90 Brinkmann S, Reilly S, Meara JG. Management of tongue-tie in children: a survey of paediatric surgeons in Australia. J Paediatr Child Health. Nov. 2004;40(11):600-5. X-5, X-6. [pmid: 15469527].
91 Queiroz Marchesan I. Lingual frenulum: classification and speech interference. Int J Orofacial Myology. Nov. 2004;30:31-8. X-5. [pmid: 15832860].
92 Cook T. What the tongue tells us. Homoeopathic Heritage. 2005;30(9):12-6. X-4.
93 Kummer AW. Ankyloglossia: to clip or not to clip? That's the question. ASHA Leader. 2005;10(17):6. X-4, X-5, X-6.
94 Kupietzky A, Botzer E. Ankyloglossia in the infant and young child: clinical suggestions for diagnosis and management. Pediatr Dent. Jan-Feb. 2005;27(1):40-6. X-4, X-5, X-6. [pmid: 15839394].
95 Ogino A, Onish K, Maruyama Y. Congenital oral synechia associated with cleft palate: Cleft palate medial synechia syndrome?. European Journal of Plastic Surgery. March. 2005;27(7):338-40. X-4, X-5.
96 Ricke LA, Baker NJ, Madlon-Kay DJ, et al. Newborn tongue-tie: prevalence and effect on breast-feeding. J Am Board Fam Pract. Jan-Feb. 2005;18(1):1-7. X-5. [pmid: 15709057].
97 Yen D. Tongue-tie is an obstacle to breastfeeding… “Tongue-tie in a newborn has minimal effect on breastfeeding success” (A POEM for your practice, May 2005). Contemporary Pediatrics. 2005;22(7):72. X-4, X-5, X-6.
98 Amir LH, James JP, Donath SM. Reliability of the hazelbaker assessment tool for lingual frenulum function. Int Breastfeed J. 2006;1(1):3. X-5. [pmid: 16722609].
99 Ekenze SO, Ikechukwu RN, Oparaocha DC. Surgically correctable congenital anomalies: prospective analysis of management problems and outcome in a developing country. J Trop Pediatr. Apr. 2006;52(2):126-31. X-5. [pmid: 16169860].
100 Haytac MC, Ozcelik O. Evaluation of patient perceptions after frenectomy operations: a comparison of carbon dioxide laser and scalpel techniques. J Periodontol. Nov. 2006;77(11):1815-9. X-5, X-6. [pmid: 17076605].
101 Kluge EH. Hope in the neonatal intensive care nursery: values, ethics, and the injury of continued existence. MedGenMed. 2006;8(3):74. X-4, X-5, X-6. [pmid: 17406195].
102 Magalhaes M, Araujo L, Chiaradia C, et al. Early dental management of patients with Mobius syndrome. Oral Dis. Nov. 2006;12(6):533-6. X-5. [pmid: 17054764].
103 Sheth N, Greenblatt D, Acland K. Minerva. BMJ: British Medical Journal (International Edition). 2006;333(7571):762. X-4, X-5, X-6.
104 Vines G. Readers' forum. Tongue tied. AIMS Journal. 2006;18(2):19. X-4, X-5.
105 Abstracts. Obstetrics & Gynecology. 2007;109(6):1451-4. X-4, X-5, X-6.
106 Oral update. Giving more than lip service to common and uncommon lip and mouth problems. Dermatology Nursing. 2007;19(2):215-6. X-4, X-5, X-6.
107 Bolling RP, Sabeeh V, Stewart JM Jr., et al. Ankyloglossum superius syndrome: diagnosis and surgical management. J Craniofac Surg. Sep. 2007;18(5):1094-7. X-5. [pmid: 17912091].
108 Haytac MCOO. Laser frenectomy… :evaluation of patient perceptions after frenectomy operations: a comparison of carbon dioxide laser and scalpel techniques. J Periodontol. 2006;77:1815-9. Dental Abstracts. 2007;52(3):176-7. X-4. [pmid: 17076605].
109 Karam O, Pfister RE, Extermann P, et al. Congenital lingual cysts. J Pediatr Surg. Apr. 2007;42(4):E25-7. X-4, X-5. [pmid: 17448749].
110 Klockars T. Familial ankyloglossia (tongue-tie). Int J Pediatr Otorhinolaryngol. Aug. 2007;71(8):1321-4. X-5. [pmid: 17588677].
111 Koora K, Muthu MS, Rathna PV. Spontaneous closure of midline diastema following frenectomy. J Indian Soc Pedod Prev Dent. Mar. 2007;25(1):23-6. X-5. [pmid: 17456963].
112 Nopoulos P, Richman L, Andreasen N, et al. Cognitive dysfunction in adults with Van der Woude syndrome. Genet Med. Apr. 2007;9(4):213-8. X-5, X-6. [pmid: 17438385].
113 Parker S. Lasers and soft tissue: ‘loose’ soft tissue surgery. Br Dent J. Feb. 24. 2007;202(4):185-91. X-4, X-5, X-6. [pmid: 17322842].
114 Spolarich AE, Shaklee R. Ask the expert. Dimens Dent Hyg. 2007;5(2):38. X-4, X-5, X-6.
115 Tilluckdharry NV, Blake MA, Sweeney AT. Visual vignette. Endocr Pract. Jan-Feb. 2007;13(1):93. X-4, X-5, X-6. [pmid: 17360312].
116 Todd KL, Weinberg JM, Advisor forum. Slow-healing split lip. Clinical Advisor for Nurse Practitioners. 2007;10(1):69. X-4, X-5, X-6.
117 Verco PJ. Case report and clinical technique: argon beam electrosurgery for tongue ties and maxillary frencectomies in infants and children. Eur Arch Paediatr Dent. 2007;8(Suppl):15-9. X-5.
118 Chapman DJ. Research spotlight. Using ultrasound for a closer look at breastfeeding: pre- and postfrenulotomy. J Human Lact. 2008;24(4):460-1. X-4.
119 Evans AE, Coryllos E, Abel JR, et al. Your voice. Tongue-tied… (January 2008) on ankyloglossia and management. Contemporary Pediatrics. 2008;25(3):11. X-4, X-5, X-6.
120 Genovese MD, Olivi G. Laser in paediatric dentistry: patient acceptance of hard and soft tissue therapy. Eur J Paediatr Dent. Mar. 2008;9(1):13-7. X-5. [pmid: 18380525].
121 Kara C. Evaluation of patient perceptions of frenectomy: a comparison of Nd:YAG laser and conventional techniques. Photomed Laser Surg. Apr. 2008;26(2):147-52. X-5. [pmid: 18341414].
122 Madlon-Kay DJ, Ricke LA, Baker NJ, et al. Case series of 148 tongue-tied newborn babies evaluated with the assessment tool for lingual frenulum function. Midwifery. Sep. 2008;24(3):353-7. X-5. [pmid: 17276561].
123 Martin MS, Schwartz RH. Tackling ankyloglossia in the office. Contemporary Pediatrics. 2008;25(1):59-64. X-4, X-5, X-6.
124 Philipp B. Your voice. More discussion on tongue-tie… tongue-tie (January and March 2008). Contemporary Pediatrics. 2008;25(5):16. X-4, X-5, X-6.
125 Whitman C. Tongue tie is prevalent… ankyloglossia article (January 2008). Contemporary Pediatrics. 2008;25(6):12. X-4, X-5, X-6.
126 Genna CW, Coryllos EV. Breastfeeding and tongue-tie. J Hum Lact. Feb. 2009;25(1):111-2. X-4, X-5, X-6. [pmid: 19196857].
127 Hooda A, Rathee M, Yadav S, et al. Ankyloglossia: A Review of Current Status. Internet Journal of Otorhinolaryngology. 2009;12(2). X-4, X-5, X-6.
128 Klem C. Surgical team partners with Bangladesh Army does in second “Sight, Sound and Smile” mission. Bull Am Coll Surg. Aug. 2009;94(8):19-21. X-4, X-5, X-6. [pmid: 19715001].
129 Louloudiadis AK, Louloudiadis KA. Case report: Dystrophic Epidermolysis Bullosa: dental management and oral health promotion. Eur Arch Paediatr Dent. Jan. 2009;10(1):42-5. X-4, X-5. [pmid: 19254527].
130 Northcutt ME. The lingual frenum. J Clin Orthod. Sep. 2009;43(9):557-65. quiz 81. X-4, X-5, X-6. [pmid: 19904047].
131 Scelfo RS. First person on the last page. Frenectomy for a first kiss. ASHA Leader. 2009;14(5):35. X-4, X-5, X-6.
132 Sharma R. Tongue tie release in an infant with difficult intubation: is it safe?. Internet Journal of Anesthesiology. 2008. 2009;22(1). 3p. X-4, X-5, X-6.
133 ILCA abstracts. J Hum Lact. 2010;26(1):60-71. X-4.
134 Acevedo AC, da Fonseca JA, Grinham J, et al. Autosomal-dominant ankyloglossia and tooth number anomalies. J Dent Res. Feb. 2010;89(2):128-32. X-5, X-6. [pmid: 20042737].
135 Aras MH, Goregen M, Gungormus M, et al. Comparison of diode laser and Er:YAG lasers in the treatment of ankyloglossia. Photomed Laser Surg. Apr. 2010;28(2):173-7. X-6. [pmid: 19743963].
136 Forlenza GP, Paradise Black NM, McNamara EG, et al. Ankyloglossia, exclusive breastfeeding, and failure to thrive. Pediatrics. Jun. 2010;125(6):e1500-4. X-5. [pmid: 20498175].
137 Hamamci N, Ozer T, Hamamci O, et al. Treatment of an adolescent with total ankyloglossia. World J Orthod. Fall. 2010;11(3):278-83. X-5. [pmid: 20877739].
138 Hughes M. Tongue tie. Midwifery Matters. 2010;(127):6-7. X-4, X-5, X-6.
139 Kotlow LA. The influence of the maxillary frenum on the development and pattern of dental caries on anterior teeth in breastfeeding infants: prevention, diagnosis, and treatment. J Hum Lact. Aug. 2010;26(3):304-8. X-4, X-5, X-6. [pmid: 20308621].
140 Manfro AR, Manfro R, Bortoluzzi MC. Surgical treatment of ankyloglossia in babies--case report. Int J Oral Maxillofac Surg. Nov. 2010;39(11):1130-2. X-5. [pmid: 20615663].
141 Melink S, Vagner MV, Hocevar-Boltezar I, et al. Posterior crossbite in the deciduous dentition period, its relation with sucking habits, irregular orofacial functions, and otolaryngological findings. Am J Orthod Dentofacial Orthop. Jul. 2010;138(1):32-40. X-5. [pmid: 20620831].
142 Merdad H, Mascarenhas AK. Ankyloglossia may cause breastfeeding, tongue mobility, and speech difficulties, with inconclusive results on treatment choices. J Evid Based Dent Pract. Sep. 2010;10(3):152-3. X-4, X-5, X-6. [pmid: 20797658].
143 Morowati S, Yasini M, Ranjbar R, et al. Familial ankyloglossia (tongue-tie): a case report. Acta Med Iran. Mar-Apr. 2010;48(2):123-4. X-5, X-6. [pmid: 21133006].
144 Olivi G, Chaumanet G, Genovese MD, et al. Er,Cr:YSGG laser labial frenectomy: a clinical retrospective evaluation of 156 consecutive cases. Gen Dent. May-Jun. 2010;58(3):e126-33. X-5. [pmid: 20478790].
145 van Heerden WFP, van Zyl AW. Diagnosis and management of oral lesions and conditions in the newborn. South African Family Practice. November/December. 2010;52(6):489-91. X-4, X-5, X-6.
146 Boj JR, Poirier C, Hernandez M, et al. Case series: laser treatments for soft tissue problems in children. Eur Arch Paediatr Dent. Apr. 2011;12(2):113-7. X-4. [pmid: 21473844].
147 Burke M. Journal Club. Study affirms efficacy of frenotomy in neonatal akyloglossia. Contemporary Pediatrics. 2011;28(10):26. X-4, X-5, X-6.
148 Cervetto S, Villar C, Ellis E. Laser frenectomy postoperatively less uncomfortable than scalpel frenectomy (UT CAT0769). Tex Dent J. Aug. 2011;128(8):767. X-4, X-6. [pmid: 21957791].
149 Cetinkaya M, Oz FT, Orhan AI, et al. Prevalence of oral abnormalities in a Turkish newborn population. Int Dent J. Apr. 2011;61(2):90-100. X-5. [pmid: 21554278].
150 Gracco A, Tracey S, Lombardo L, et al. Soft tissue laser in orthodontics. Prog Orthod. 2011;12(1):66-72. X-4, X-5, X-6. [pmid: 21515234].
151 Reading R. Efficacy of neonatal release of ankyloglossia: a randomized trial. Child: Care, Health & Development. 2011;37(6):898-9. X-4, X-5, X-6.
152 Rowan-Legg A. Ankyloglossia and breastfeeding. Paediatr Child Health. Apr. 2011;16(4):222. X-4, X-5, X-6. [pmid: 22468126].
153 Voller RJ. Laser technology: real world applications. Dent Today. Mar. 2011;30(3):118. 20. 22 passim. X-4, X-5, X-6. [pmid: 21485889].
154 Block SL. Ankyloglossia: when frenectomy is the right choice. Pediatr Ann. Jan. 2012;41(1):14-6. X-4, X-5, X-6. [pmid: 22224716].
155 Edmunds J, Hazelbaker A, Murphy JG, et al. Tongue-tie. J Hum Lact. Feb. 2012;28(1):14-7. X-4, X-5, X-6. [pmid: 22267314].
156 Glynn RW, Colreavy M, Rowley H, et al. Division of tongue tie: review of practice through a tertiary paediatric otorhinolaryngology service. Int J Pediatr Otorhinolaryngol. Oct. 2012;76(10):1434-6. X-5. [pmid: 22810118].
157 Han SH, Kim MC, Choi YS, et al. A study on the genetic inheritance of ankyloglossia based on pedigree analysis. Arch Plast Surg. Jul. 2012;39(4):329-32. X-5. [pmid: 22872835].
158 Kumar M, Kalke E. Tongue-tie, breastfeeding difficulties and the role of Frenotomy. Acta Paediatr. Jul. 2012;101(7):687-9. X-4, X-5, X-6. [pmid: 22404175].
159 Olivi G, Signore A, Olivi M, et al. Lingual frenectomy: functional evaluation and new therapeutical approach. Eur J Paediatr Dent. Jun. 2012;13(2):101-6. X-4, X-5, X-6. [pmid: 22762170].
160 Pena I, Junquera LM, Llorente S, et al. Clinical outcomes after the use of complete autologous oral mucosa equivalents: preliminary cases. Oral Surg Oral Med Oral Pathol Oral Radiol. May. 2012;113(5):e4-e11. X-4, X-5, X-6. [pmid: 22676990].
161 Pie-Sanchez J, Espana-Tost AJ, Arnabat-Dominguez J, et al. Comparative study of upper lip frenectomy with the CO2 laser versus the Er, Cr:YSGG laser. Med Oral Patol Oral Cir Bucal. Mar. 2012;17(2):e228-32. X-5. [pmid: 22143683].
162 Continuing Education. Journal of Communication Disorders. 2013;46(4):I-iv. X-4, X-5, X-6.
163 Albert J. Breastfeeding: a personal and professional story. Community Pract. Jul. 2013;86(7):36-7. X-4, X-5, X-6. [pmid: 23914477].
164 Burkhart NW. Ankyloglossia: Are you paying attention?. RDH. 2013:48-50. X-4, X-5, X-6.
165 De Santis D, Gerosa R, Graziani PF, et al. Lingual frenectomy: a comparison between the conventional surgical and laser procedure. Minerva Stomatol. 2013. Aug. 1. X-5. [pmid: 23903445].
166 Elanchezhiyan S, Renukadevi R, Vennila K. Comparison of diode laser-assisted surgery and conventional surgery in the management of hereditary ankyloglossia in siblings: a case report with scientific review. Lasers Med Sci. Jan. 2013;28(1):7-12. X-4, X-5, X-6. [pmid: 22252112].
167 Garbin CP, Sakalidis VS, Chadwick LM, et al. Evidence of improved milk intake after frenotomy: a case report. Pediatrics. Nov. 2013;132(5):e1413-7. X-5. [pmid: 24101770].
168 Greenwood G. The benefits to breastfeeding and success rates of a frenulotomy in newborns with ankyloglossia. Br J Midwifery. 2013;21(6):439-42. X-4, X-5.
169 Hayman RL, Henry L. Help Wanted: Champions for Breastfeeding Success in Newborns With Ankyloglossia. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2013;42:S103-4. X-4, X-5, X-6.
170 Ngerncham S, Laohapensang M, Wongvisutdhi T, et al. Lingual frenulum and effect on breastfeeding in Thai newborn infants. Paediatr Int Child Health. May. 2013;33(2):86-90. X-5. [pmid: 23925281].
171 Nguyen AM, Chelius DC, Baker KA, et al. Optimal positioning techniques with fiberoptic laser excision in the treatment of congenital tongue base lesions. Laryngoscope. Jun. 2013;123(6):1552-5. X-4, X-5, X-6. [pmid: 23483518].
172 Sanadi R, Ambulgekar J, Doshi M. Adieu to tongue tie, lingual frenectomy: A case report. International Research Journal of Pharmacy. 2013;4(7):203-4. X-4, X-5, X-6.
173 Stankan T, Sego S, Young AM, et al. Advisor Forum. Clinical Advisor for Nurse Practitioners. 2013;16(3):48-50. X-4, X-5, X-6.
174 Steele CM, Bailey GL, Polacco REC, et al. Outcomes of tongue-pressure strength and accuracy training for dysphagia following acquired brain injury. International Journal of Speech-Language Pathology. 2014-01-09. 2013;15(5):492-502. X-4, X-5, X-6. [pmid: 23336825].
175 Venettacci O, Nettlefold C, Chan L, et al. Sub-labial packing: a novel method of stopping epistaxis from Little's area. Int J Pediatr Otorhinolaryngol. Aug. 2013;77(8):1370-1. X-5. [pmid: 23806741].
176 Bowley DM, Arul GS. Fifteen-minute consultation on the infant with a tongue tie. Arch Dis Child Educ Pract Ed. 2014. Jan. 13. X-4, X-5, X-6. [pmid: 24419208].
177 Haham A, Marom R, Mangel L, et al. Prevalence of breastfeeding difficulties in newborns with a lingual frenulum: a prospective cohort series. Breastfeed Med. Nov. 2014;9:438-41. X-5. [pmid: 25238577].
178 Henry L, Hayman R. Ankyloglossia its impact breastfeeding. Nurs Womens Health. Apr-May. 2014;18(2):122-9. X-4, X-5, X-6. [pmid: 24750651].
179 Hertel M, Matter D, Schmidt-Westhausen AM, et al. Oral syphilis: a series of 5 cases. J Oral Maxillofac Surg. Feb. 2014;72(2):338-45. X-5, X-6. [pmid: 24045192].
180 Ito Y. Does Frenotomy Improve Breastfeeding Difficulties in Infants with Ankyloglossia?. Pediatr Int. 2014. Jun. 30. X-4. [pmid: 24978831].
181 Junqueira MA, Cunha NN, Costa ESLL, et al. Surgical techniques for the treatment of ankyloglossia in children: a case series. J Appl Oral Sci. Jun. 2014;22(3):241-8. X-5. [pmid: 25025566].
182 Krishnamurthy A, George R, Majhi U. Malignant granular cell tumor of the tongue: a clinico-pathological challenge. Indian Journal of Surgical Oncology. March. 2014;5(1):71-4. X-5, X-6. [pmid: 24669168].
183 Ovental A, Marom R, Botzer E, et al. Using topical benzocaine before lingual frenotomy did not reduce crying and should be discouraged. Acta Paediatr. Jul. 2014;103(7):780-2. X-5. [pmid: 24724835].
184 Puapornpong P, Raungrongmorakot K, Mahasitthiwat V, et al. Comparisons of the latching on between newborns with tongue-tie and normal newborns. J Med Assoc Thai. Mar. 2014;97(3):255-9. X-5. [pmid: 25123003].
185 Rampersad S, Rossi MG, Yarnell C, et al. Wrong site frenulectomy in a child: a serious safety event. Anesth Analg. Jul. 2014;119(1):141-4. X-5. [pmid: 24945126].
186 Suter VG, Heinzmann AE, Grossen J, et al. Does the maxillary midline diastema close after frenectomy?. Quintessence Int. 2014;45(1):57-66. X-5. [pmid: 24392496].
187 Wieker H, Sieg P. Ankyloglossia superior syndrome: case report and review of publications. Br J Oral Maxillofac Surg. May. 2014;52(5):464-6. X-4, X-5. [pmid: 24642083].