# Abstract and Full-Text Screening Forms

Table B-1 Abstract screening questions

Ref ID | Reviewer name
1. Does the study address the treatment of ankyloglossia and/or concomitant lip-tie or harms of treatment/no treatment (conservative management)?; If “No” please skip to #4. | Yes | No | Cannot Determine
2 Is the study original research? (excludes reviews, commentary, editorials, letters; includes systematic reviews and meta analyses) | Yes | No | Cannot Determine
3 Does the study population include infants or children up to age 18? | Yes | No | Cannot Determine
4 If excluded, should the study be retained for any of the following reasons:; - Background/discussion; - Review of references; - Study population has congenital craniofacial malformation, Pierre Robin and/or cleft lip/palate; - Other _______________ | Yes | No | Cannot Determine
Comment

Table B-2 Full-text screening questions

Ref ID | Reviewer name
1. Is the study original research? (excludes narrative reviews, commentary, editorials, letters; includes systematic reviews and meta analyses) | Yes | No
2 Does the study evaluate the effectiveness of treatment for ankyloglossia and/or concomitant lip-tie OR is this a study or case report that provides data on harms of treatment? | Yes | No
3 Does the study population include infants or children up to age 18? | Yes | No
4 If excluded, should the study be retained for any of the following reasons:; - Background/discussion; - Review of references; - Study population has congenital craniofacial malformation, Pierre Robin and/or cleft lip/palate; - Other ______________________ | Yes | No
Comment