# Search Strategies

Table A-1 PubMed search strategies

Search terms | | Search results
#1 | (“Mouth Abnormalities”[Mesh:noexp] OR “Tongue Diseases/congenital”[Mesh:noexp] OR “Tongue/abnormalities”[Mesh] OR “Lingual Frenum”[Mesh] OR “Lip Diseases/congenital”[Mesh:noexp] OR “Lip/abnormalities”[Mesh] OR “Labial Frenum”[Mesh] OR “Ankyloglossia”[Supplementary Concept] OR “ankyloglossia”[tiab] OR ((“tongue”[tiab] OR “lip”[tiab] OR “lingual”[tiab] OR “linguae”[tiab] OR “labial”[tiab] OR “maxillary”[tiab]) AND (“frenum”[tiab] OR “fraenum”[tiab] OR “frenulum”[tiab] OR “frena”[tiab] OR “frenula”[tiab])) OR ((“tongue”[tiab] OR “lip”[tiab] OR “maxillary”[tiab]) AND (“tie”[tiab] OR “tied”[tiab]))) | 3501
#2 | (“Therapeutics”[Mesh] OR “therapy”[Subheading] OR “Treatment Outcome”[Mesh] OR “therapy”[tiab] OR “therapies”[tiab] OR “therapeutic”[tiab] OR “therapeutics”[tiab] OR “outcome”[tiab] OR “outcomes”[tiab] OR “Oral Surgical Procedures”[Mesh] OR “surgical”[tiab] OR “surgery”[Subheading] OR “surgery”[tiab] OR “frenulotomy”[tiab] OR “frenulectomy”[tiab] OR “frenotomy”[tiab] OR “frenectomy”[tiab] OR “frenuloplasty”[tiab] OR “z-plasty”[tiab] OR “h-plasty”[tiab] OR “laser”[tiab] OR “Rehabilitation of Speech and Language Disorders”[Mesh] OR “Speech Disorders “[Mesh] OR “Language Development Disorders “[Mesh] OR “speech therapy”[tiab] OR “speech therapies”[tiab] OR “language therapy”[tiab] OR “language therapies”[tiab] OR “oral motor therapy”[tiab] OR “oral motor therapies”[tiab] OR “Complementary Therapies”[Mesh] OR cam[sb] OR “complementary medicine”[tiab] OR “complementary therapy”[tiab] OR “complementary therapies”[tiab] OR “alternative medicine”[tiab] OR “alternative therapy”[tiab] OR “alternative therapies”[tiab] OR “cam”[tiab] OR “craniosacral therapy”[tiab] OR “cranial sacral therapy”[tiab] OR “myofascial release”[tiab] OR “myofascial therapy”[tiab] OR “rolfing”[tiab]) OR (“unsafe”[tiab] OR “safety”[tiab] OR “harm”[tiab] OR “harms”[tiab] OR “harmful”[tiab] OR “complication”[tiab] OR “complications”[tiab] OR “risk”[tiab] OR “risks”[tiab] OR “side-effect”[tiab] OR “side-effects” [tiab]OR ((undesirable OR adverse) AND (effect OR effects OR reaction OR reactions OR event OR events OR outcome OR outcomes))OR” sequelae” [tiab] OR “sequela” [tiab] OR ((postoperative OR surgical OR “post operative” OR “post surgical”) AND (complication OR complications)) OR “adverse effects”[Subheading] OR “complications”[Subheading] OR “contraindications”[Subheading]) | 10219702
#3 | #1 AND #2 | 2065
#4 | #3 AND eng[la] | 1496
#5 | #4 NOT (editorial[pt] OR letter[pt] OR comment[pt] OR review[pt] OR news[pt] OR historical article[pt] OR practice guideline[pt] OR meta-analysis[pt]) | 1252

Key: [Mesh: noexp] exact medical subject heading, not including the terms nested beneath it; [MeSH] medical subject heading; [Supplmentary Concept] indexing terms for chemicals, substances and rare diseases; [tiab] keyword in title or abstract; [sh] subheading; [la] language; [pt] publication type.

Table A-2 CINAHL search strategies

Search terms | | Search results
S1 | ((MH “Mouth Abnormalities”) OR (MH “Tongue Diseases”) OR (MH “Tongue/AB”) OR (MH “Lip Diseases”) OR (MH “Lip/AB”) OR (MH “Frenum (Oral)”) OR (MH “Ankyloglossia”) OR “ankyloglossia” OR ((“tongue” OR “lip” OR “lingual” OR “linguae” OR “labial” OR “maxillary”) AND (“frenum” OR “fraenum” OR “frenulum” OR “frena” OR “frenula”)) OR ((“tongue” OR “lip” OR “maxillary”) AND (“tie” OR “tied”))) | 864
S2 | ((MH “Therapeutics+”) OR (MH “Treatment Outcomes+”) OR “therapy” OR “therapies” OR “therapeutic” OR “therapeutics” OR “outcome” OR “outcomes” OR (MH “Surgery, Oral+”) OR “frenulotomy” OR “frenulectomy” OR “frenotomy” OR “frenectomy” OR “frenuloplasty” OR “z-plasty” OR “h-plasty” OR “laser” OR “surgery” OR “surgical” OR (MW “su”) OR (MH “Speech Disorders+”) OR (MH “Communicative Disorders+”) OR (MH “Language Disorders+”) OR (MH “Rehabilitation, Speech and Language+”) OR “speech therapy” OR “speech therapies” OR “language therapy” OR “language therapies” OR “oral motor therapy” OR “oral motor therapies” OR (MH “Alternative Therapies+”) OR “complementary medicine” OR “complementary therapy” OR “complementary therapies” OR “alternative medicine” OR “alternative therapy” OR “alternative therapies” OR “cam” OR “craniosacral therapy” OR “cranial sacral therapy” OR “myofascial release” OR “myofascial therapy” OR “rolfing”) | 1269326
S3 | S1 AND S2 | 497
S4 | S3 AND limiters: English language | 495
S5 | S4 AND limiters: Exclude MEDLINE records | 96

Key: MH CINAHL medical subject heading; MW CINAHL subheading

Table A-3 PsycINFO search strategies

Search terms | | Search results
#1 | (SU.EXACT.EXPLODE(“Mouth (Anatomy)”) OR SU.EXACT.EXPLODE(“Tongue”) OR SU.EXACT.EXPLODE(“Lips (Face)”) OR IF(“ankyloglossia” OR ((“tongue” OR “lip” OR “lingual” OR “linguae” OR “labial” OR “maxillary”) AND (“frenum” OR “frenum” OR “fraenum” OR “frenulum” OR “frena” OR “frenula”)) OR ((“tongue” OR “lip” OR “maxillary”) AND (“tie” OR “tied”)))) | 2022
#2 | (SU.EXACT.EXPLODE(“Treatment”) OR (IF(“therapy” OR “therapies” OR “therapeutic” OR “therapeutics” OR “outcome” OR “outcomes” OR “frenulotomy” OR “frenulectomy” OR “frenotomy” OR “frenectomy” OR “frenuloplasty” OR “z-plasty” OR “h-plasty” OR “laser” OR “surgery” OR “surgical” OR “speech therapy” OR “speech therapies” OR “language therapy” OR “language therapies” OR “oral motor therapy” OR “oral motor therapies” OR “complementary medicine” OR “complementary therapy” OR “complementary therapies” OR “alternative medicine” OR “alternative therapy” OR “alternative therapies” OR “cam” OR “craniosacral therapy” OR “cranial sacral therapy” OR “myofascial release” OR “myofascial therapy” OR “rolfing”))) | 684785
#3 | #1 AND #2 | 235
#4 | #3 AND LA(English) | 220
#5 | #4 with peer reviewed and scholarly journals selected | 207

Key: SU.EXACT.EXPLODE subject term

Table A-4 EMBASE search strategies

Search terms | | Search results
#1 | tongue disease/cn or tongue disease*.tw. or tongue abnormalit*.tw. or ankyloglossia/ or ankyloglossia.tw. or lip malformation/cn or lip malformation*.tw. or lip disease/cn or lip disease*.tw. or ((tongue/ or tongue.tw. or lip/ or lip*.tw. or labial.tw. or lingual.tw.) and (frenum.tw. or fraenum.tw. or frena.tw. or frenulum.tw. or frenula.tw.)) or ((tongue.tw. or lip/ or maxillary.tw.) and (tie.tw. or tied.tw. or ties.tw.)) | 1229
#2 | th.fs. or therapy/ or therapy.tw. or therapies.tw. or therapeutic*.tw. or treatment outcome/ or treatment outcome*.tw. or outcome*.tw. or oral surgery/ or oral surger*.tw. or surgical.tw. or su.fs. or surgery.tw. or frenulotom*.tw. or frenulectom*.tw. or frenotom*.tw. or frenectom*.tw. or frenuloplast*.tw. or z plasty/ or z plasty.tw. or h plasty.tw. or laser surgery/ or speech rehabilitation/ or speech rehabilitation.tw. or speech disorder/ or speech disorder*.tw. or developmental language disorder/ or language development disorder*.tw. or speech therapy/ or speech therap*.tw. or language therap*.tw. or oral motor therap*.tw. or complementary therap*.tw. or cam.tw. or complementary medicine*.tw. or alternative medicine/ or alternative medicine*.tw. or alternative therap*.tw. or craniosacral therapy/ or craniosacral therap*.tw. or myofascial therap*.tw. or myofascial release.tw. or manipulative medicine/ or rolfing/ or rolfing.tw. or (Unsafe.tw. or safety/ or safety.tw. or harm.tw. or harms.tw. or harmful.tw. or complication/ or complication*.tw. or risk/ or risk*.tw. or side effect/ or side effect*.tw. or contraindication*.tw. or ((undesirable.tw. or adverse.tw.) and (effect.tw. or effects.tw. or reaction.tw. or reactions.tw. or event.tw. or events.tw. or outcome.tw. or outcomes.tw.)) or sequelae.tw. or sequela.tw. or ((postoperative.tw. or surgical.tw. or post operative.tw. or post surgical.tw.) and (event.tw. or events.tw. or outcome.tw. or outcomes.tw.)) or si.fs. or co.fs.) | 8617400
#3 | 1 AND 2 | 730
#4 | Limit 3 to English | 585
#5 | Limit 4 to human | 541
#6 | 5 not (review.pt. or editorial.pt. or letter.pt. or note.pt. or short survey.pt. or conference paper.pt. or meta analysis/ or practice guideline/ or systematic review/) | 431
#7 | 5 Exclude MEDLINE journals | 25

Key: / Emtree heading; .tw. abstract, title and drug trade name; /cn congenital; .fs. subheading; si.fs. side effects subheading; th.fs. therapy subheading; su.fs. surgery subheading; co.fs. complications subheading; p.t. publication type