# Abbreviations and Acronyms

AAP: American Academy of Pediatrics
AAPD: American Academy of Pediatric Dentistry
AAO: American Association of Orthodontists
AAO-HNS: American Academy of Otolaryngology – Head and Neck Surgery
ABM: Academy of Breastfeeding Medicine
AF: Analytic framework
AHRQ: Agency for Healthcare Research and Quality
AOS: American Orthodontic Society
ASHA: American Speech-Language-Hearing Association
BSES: Breastfeeding Self-Efficacy Scale
BSES-SF: Breastfeeding Self-Efficacy Scale Short Form
CAM: Complementary and alternative medicine
CER: Comparative Effectiveness Review
CINAHL: Cumulative Index of Nursing and Allied Health Literature
CLCWA: College of Lactation Consultants of Western Australia
CPS: Canadian Paediatric Society
ENT: Ear, Nose & Throat
EMBASE: Excerpta Medica Database
EPC: Evidence-based Practice Center
HATLFF: Hazelbaker Assessment Tool of Lingual Frenulum Function
IBFAT: Infant Breastfeeding Assessment Tool
ILCA: International Lactation Consultant Association
IQR: Interquartile range
KI: Key Informant
KQ: Key Question
LATCH: Latch, Audible swallowing, Type of nipple, Comfort, Hold
LCANZ: Lactation Consultants of Australia and New Zealand
MPQ-SF: Montreal Pain Questionnaire
NHS: National Health Service
MeSH: Medical Subject Headings
NICU: Neonatal intensive care unit
PAS: Pediatric Academic Societies
PICOTS: Population, Intervention, Comparator, Outcomes, Timing, Setting
PQDT: ProQuest Dissertations & Theses
RCT: Randomized controlled trial
SF-MQP: Short Form McGill Pain Questionnaire
SRDR: Systematic Review Data Repository
TEP: Technical Expert Panel
VAS: Visual Analog Scale for Pain