# Results

## Organization of Results

The Results are broadly organized by the Key Questions. The Key Questions are further subdivided by class of treatment (pharmacologic, physical, psychological, or mixed) and within that, by subgroups. We first examine the effects of drugs on various subgroups and then address the effects of other treatments. Within each class of treatment, subgroup/intervention/outcome comparisons with at least low strength of evidence are provided first. Brief details for the subgroups with insufficient evidence are provided second.

A complete list of abbreviations and acronyms can be found at the end of this report.

## Type and Labeling of Included Studies

We included several types of studies. RCTs with mixed patient samples refer to studies that identified a patient subgroup after randomization (such as adults with fibromyalgia, a proportion of whom had depression). RCTs that selected within particular subgroups (such as postmenopausal women) comprised another group of included studies; we refer to these as pure subgroup RCTs. A third type of study was a pooled analysis of individual patient data from several RCTs to report subgroup outcomes. We refer to these as pooled analyses of individual patient data (IPD) from RCTs, or pooled IPD RCT analyses, which were pooled within-study comparisons. All such studies investigated drug interventions. Finally, observational studies with comparator groups were included.

## Results of Literature Searches

We identified 6401 citations from all databases combined. We examined the full text of 516 articles (391 RCTs, 24 pooled analyses of patient-level RCT data, and 101 observational studies) to assess for subgroup reporting. Of those, 34 studies were included in the analysis (Table 4 and Figure 2): 22 RCTs, eight analyses that pooled IPD from RCTs,25,26,29,76-80 and four observational studies.81-84 The two types of RCTs included ten studies with mixed patient samples3,4,27,28,30,85-89 and 12 RCTs of pure subgroup samples.52,53,90-99 Of the 22 RCTs, ten were placebo-controlled trials (eight mixed samples and two pure subgroup RCTs). Twenty studies were drug trials (59 percent). All included studies were published in 2001 or later, with the eight pooled IPD RCT analyses all published since 2009. Appendix D contains a list of studies that were excluded after the initial full text screen for subgroup reporting, with rationale for exclusion.

Figure 2 Disposition of fibromyalgia studies identified for this review

Abbreviations: AMED = Allied and Complementary Medicine Database; KQ1 = Key Question 1; KQ2 = Key Question 2; RCT = randomized controlled trial

Figure 2: QUORUM Figure 2 is a flow chart that outlines the citation retrieval and study selection process. It begins with the total number of citations retrieved from the literature searches and ends with the number of studies that satisfied the inclusion criteria for this report. This figure is further described in the report section entitled, “Results of Literature Searches.” We identified 6401 citations from all databases combined; 875 duplicates were excluded, leaving 5526 citations to review. Of those, 5010 references were excluded for not meeting selection criteria on screening of titles and abstracts, leaving 516 references that underwent full-text screening to assess for subgroup reporting (391 randomized clinical trial (RCTs), 24 pooled analyses of patient-level RCT data, and 101 observational studies). Of those, the majority (421) were excluded for lack of subgroup reporting, leaving 95 articles that underwent full-text review: 71 randomized clinical trials (RCTs), 11 pooled analyses of individual-patient data from RCTs, and 13 observational studies. We excluded an additional 61 studies during full-text review (20 for no subgroup outcomes reporting, 21 with less than 3 months of followup and 20 for other reasons). Our final count of studies included 34 total articles, of which 29 were unique patient samples: 22 RCTs, 8 pooled analyses of patient-level RCT data and 4 observational studies.

Table 4 Included fibromyalgia subgroup studies, by study design

Study Design | Count
Randomized controlled trials | 10
Randomized controlled trials of pure subgroups | 12
Pooled analyses of individual patient data from randomized controlled trials | 8
Observational studies | 4
Total of included studies for report | 34

Figure 2 shows the QUORUM diagram for the study selection process beginning with the total number of citations retrieved from the literature searches and ending with the number of studies that satisfied the inclusion criteria for this report. Of the 516 references that underwent initial full-text screening, the majority were excluded for lack of subgroup outcomes reporting.

## Key Question 1 Treatment Effectiveness in Fibromyalgia Subgroups

### Overview

Table 5 provides a basic map of the included studies to assess treatment effectiveness in fibromyalgia subgroups. It is readily apparent that little evidence is available for any given treatment-subgroup-outcome combination regarding potential differential treatment effects in subgroups of adults with fibromyalgia. With the exception of studies on duloxetine, there are few areas where more than one study has examined a treatment-outcome combination for a given subgroup. Persons with depression have been most commonly studied. Pain was the most frequently studied outcome, followed by the measure of Patient Global Impression Improvement (PGI-I).

Table 5 Number of studies by subgroup-treatment-outcome combinations in adults with fibromyalgia

Subgroup-by Treatment | Brief Pain Inventory Average Pain Score | Patient Global Impression of Improvement (PGI-I) | Fibromyalgia Impact Questionnaire (FIQ) Total Score | FIQ Subscale | Visual Analog Scale (VAS) for Pain | Patient Global Impression of Change (PGI-C) | HAMD | Other Pain Measure | Other Nonpain Measures
Drugs
Duloxetine
Depression/MDD | 6 Arnold, 2012^28^ Russell, 2008^3^ Chappell, 2008^89^ Arnold, 2005^27^ Arnold, 2004^4^ Arnold, 2009^25,*^ | 3 Arnold, 2010^30^ Russell, 2008^3^ Arnold, 2009^25,*^ | 2 Arnold, 2004^4^ Arnold, 2009^25,*^ | 1 (pain) Arnold, 2004^4^ | | | 2 Russell, 2008^3^ (within strata) Arnold, 2009^25^ | | 1 each outcome: SF-36 Arnold, 2009^25^ SDS, CGI-S, MFI; Arnold, 2009^25^
Anxiety/GAD | 2 Arnold, 2012^28^ Chappell, 2008^89^ | 1 Arnold, 2010^30^
Age | 3 Arnold, 2012^28^ Russell, 2008^3^ Chappell, 2008^89^ | 2 Arnold, 2010^30^ Russell, 2008^3^ | | 1 (stiffness) Bennett, 2012^76^
Sex | 4 Arnold, 2012^28^ Russell, 2008^3^ Arnold, 2004^4^ Chappell, 2008^89^ | 2 Arnold, 2010^30^ Russell, 2008^3^ | 1 Arnold, 2004^4^ | 1 (pain) Arnold, 2004^4^ | | | | | 1:SDS Arnold, 2004^4^
Race | 3 Arnold, 2012^28^ Russell, 2008^3^ Chappell, 2008^89^ | 2 Arnold, 2010^30^ Russell, 2008}3
Obesity/BMI | | | | 1 (stiffness) Bennett, 2012^76^
Fatigue/Tiredness | 1 Bradley, 2010^26^ | 1 Bradley, 2010^26^ | 1 Bradley, 2010^26^ | 1 (multiple) Bradley, 2010^26^ | | | | | 1 (SF-36) Bradley, 2010^26^
Prior antidepressant use | 1 Chappell, 2008^89^
Milnacipran
Depression | | | | | 2 Gendreau, 2005^85^ Arnold, 2012^81^ | 1 Arnold, 2012^81^ | | 1 (3 different pain scores) Gendreau, 2005^85^ | 1 (Beck Depression) Arnold, 2012^81^
Obesity/BMI | | | | | | | | | 1 (weight loss) Arnold, 2012^77^
Baseline VAS pain | | | | | 1 Geisser, 2011^78^ | 1 Geisser, 2011^78^ | | | 1 (SF-36 PCS) Geisser, 2011^78^
Pregabalin
Age | | | | | | 1 (NR) Byon, 2010^80^ | | 1 (NR) Byon, 2010^80^
Sex | | | | | | 1 (NR) Byon, 2010^80^ | | 1 (NR) Byon, 2010^80^
Depression | | | | | | 1 (within stratum) Bhadra, 2010^79^ | | 1 (within stratum) Bhadra, 2010^79^ | 1 (HADS-D) Arnold, 2010^29^
Anxiety | | | | | | 1 (within stratum) Bhadra, 2010^79^ | | 1 (within stratum) Bhadra, 2010^79^ | 1 (HADS-A) Arnold, 2010^29^
Immune/allergies | | | | | | 1 (within stratum) Bhadra, 2010^79^ | | 1 (within stratum) Bhadra, 2010^79^
GI reflux | | | | | | 1 (within stratum) Bhadra, 2010^79^ | | 1 (within stratum) Bhadra, 2010^79^
Insomnia | | | | | | 1 (within stratum) Bhadra, 2010^79^ | | 1 (within stratum) Bhadra, 2010^79^
IBS | | | | | | 1 (within stratum) Bhadra, 2010^79^ | | 1 (within stratum) Bhadra, 2010^79^
Neurological | | | | | | 1 (within stratum) Bhadra, 2010^79^ | | 1 (within stratum) Bhadra, 2010^79^
Asthma | | | | | | 1 (within stratum) Bhadra, 2010^79^ | | 1 (within stratum) Bhadra, 2010^79^
Restless legs/RLS | | | | | | 1 (within stratum) Bhadra, 2010^79^ | | 1 (within stratum) Bhadra, 2010^79^
Off-label
Depression (Fluoxetine) | | | 1 Arnold, 2002^86^ | 1 (pain) Arnold, 2002^86^
Postmenopausal women (17B-estradiol) | | | | | | | | 1 Stening, 2011^90^
Postmenopausal women (Raloxifen) | | | | | | | | 1 Sadreddini, 2008^91^ | 1 (4 other measures) Sadreddini, 2008^91^
ESR level at baseline (Naltrexone) | | | | | | | | | 1 (FM symptom severity) Younger, 2009^82^
Physical
Sedentary women (deep water vs. land based exercise) | | | 1 Assis, 2006^92^ | | 1 Assis, 2006^92^ | | | | 1 (BDI, SF-36, PGART) Assis, 2006^92^
Sedentary women (strengthening vs. flexibility exercise) | | | 1 Gavi, 2014^98^ | | 1 Gavi, 2014^98^ | | | | 1 (HRV, fitness, IDATE, SF-36) Gavi, 2014^98^
Body weight (whole body vibration) | | | | | | | | | 1 (dynamic balance) Gusi, 2010^52^
Premenopausal women(strength training) | | | | | | | | | 1 (knee strength, hormones) Hakkinen, 2001^100^
Obese adults (weight reduction) | | | 1 Senna, 2012^53^ | | | | | | 1 (BDI, Sleep quality index, TPs) Senna, 2012^53^
Postmenopausal (strength and aerobic training) | | | | | | | | | 1 (5 measures) Valkeinen, 2008^94^
Psychological
Baseline MMPI (EMG-biofeedback) | | | | | | | | 1 Drexler, 2002^83^ | 1 (SF-36 and 3 other measures) Drexler, 2002^83^
Insomnia (CBT) | | | | | | | | | 1 (polysomnography) Edinger, 2005^95^
Women–all with psychological comorbidity (psychotherapy) | | | 1 Scheidt, 2013^96^ | | | | | 1 Scheidt, 2013^96^ | 1 (2 other measures) Scheidt, 2013^96^
Coping style (Written emotional disclosure) | | | | | | | | 1 Junghaenel, 2008^87^ | 1 (fatigue, psychological well-being) Junghaenel, 2008^87^
Educational status (Written emotional disclosure) | | | | | | | | 1 Junghaenel, 2008^87^ | 1 (fatigue, psychological well-being) Junghaenel, 2008^87^
Mixed
Fatigue (Multidisciplinary plus CBT or medications) | | | 1 Lera, 2009^88^ | | | | | | 1 (SF-36, SCL-90-R) Lera, 2009^88^
Females with insomnia (CBT for insomnia vs education) | | | 1 Martinez, 2014^99^ | | | | | 1 Martinez, 2014^99^ | 1 (PSQI, MFI, SCL-90-R) Martinez, 2014^99^
Sedentary adults (cognitive-behavioral physical activity promotion program vs. information) | | | 1 Fontaine, 2010^97^ | 1 Fontaine, 2010^97^ | 1 Fontaine, 2010^97^ | | | | 1 (4 other measures) Fontaine, 2010^97^
Severe fibromyalgia (exercise and relaxation vs. drug) | | | 1 Joshi, 2009^84^
Socioeconomic status (exercise and relaxation vs. drug) | | | 1 Joshi, 2009^84^

Abbreviations: BDI = Beck Depression Inventory; BMI = Body Mass Index; BPI = Brief Pain Inventory; CBT = Cognitive Behavioral Therapy; CGI-S = Clinical Global Impression of Severity Scale; EMG = Electromyography; EQ-5D = EuroQol health outcomes assessment; FIQ = Fibromyalgia Impact Questionnaire; FM = fibromyalgia; GAD = Generalized Anxiety Disorder; GI = gastrointestinal; HADS-A = Hospital Anxiety and Depression Scale, anxiety subscale score; HADS-D = Hospital Anxiety and Depression Scale, depression subscale score; HAMD = Hamilton Rating Scale for Depression; HRV = Heart Rate Variability; IBS = Irritable Bowel Syndrome; MDD = Major Depressive Disorder; MFI = Multidimensional Fatigue Inventory; NR = not reported; PGART = Patient Global Assessment of Response to Therapy; PGI-C = Patient Global Impression of Change Scale; PGI-I = Patient Global Impression of Improvement Scale; PSQI = Pittsburg Sleep Quality Index; RLS = Restless legs syndrome; SDS = Sheehan Disability Scale; SCL-90-R = Symptom Checklist-90-Revised; SF-36 = MOS Short-Form 36-item Health Survey; SF-36 PCS = SF-36 Physical component score; TPs = Tender Points; VAS = Visual Analog Scale.

* Arnold 2009^25^ pooled analysis of patient-level data from 4 RCTs is partially redundant with included RCTs (3 of 4 RCTs included in this report. Rationale for inclusion is provided in the report text

Sample selection criteria were highly selective, particularly in drug trials. Study specific selection criteria are shown in Appendix Tables E1-E3. Thirty-three of 34 included studies (97 percent) used the 1990 ACR preliminary diagnostic criteria for fibromyalgia; one study did not specify the fibromyalgia diagnostic criteria used.

Basic study information for all included studies is provided in Appendix Tables E4-E7.

Given the sparse evidence for specific treatment-subgroup-outcome combinations, we were unable to conduct meta-analyses (Appendix Tables E8 and E9). Instead, we present subgroup results in tables in the few instances where data for subgroup outcomes were reported (two RCTs3,89 and five pooled IPD analyses25,26,76,79,81), provide summary tables of results from articles with text-only reporting of interaction effects, and add qualitative summary information on other comparisons in the text below.

### Key Points

- Evidence is largely insufficient to determine subgroup effects for interventions other than duloxetine in adults with fibromyalgia.
- For duloxetine, patient subgroups do not experience significantly different fibromyalgia treatment effects relative to other adults with fibromyalgia (low strength evidence).
- The most commonly addressed subgroup was adults with fibromyalgia and major depressive disorder, especially for the effects of duloxetine on pain. Less information is available on treatment effects for other subgroups (such as age, sex, race, anxiety), other outcomes or for other (nondrug) interventions.
- All but two individual RCTs had high risk of bias; all RCTs used in pooled IPD analyses had high risk of bias.
- Evidence is overwhelmingly short-term (3 months)

### Pharmacologic Therapies

The strength of evidence was low or insufficient for the effectiveness of all pharmacologic interventions in alleviating symptoms of fibromyalgia in subgroups. Individual clinical trials all had high risk of bias (Appendix Tables E10-E12).

The majority of included studies reported the effects of pharmacologic therapies on pain and other outcomes in subgroups of adults with fibromyalgia. All eight pooled analyses of patient-level RCT data were drug studies. Duloxetine effects were studied most often (six mixed-sample RCTs3,4,27,28,30,89 and three pooled IPD RCT analyses25,26,76). Subgroups that we determined a priori that were found in drug studies included depression (12 studies), age (seven studies), sex (six studies), anxiety (four studies), obesity/Body Mass Index (BMI) (two studies), and medical comorbidities (one study). Additional subgroups found in drug studies were race (four studies), baseline fatigue level (one study), prior antidepressant use (one study), postmenopausal women (two studies), and one study that used baseline Visual Analog Scale (VAS) pain ratings for subgroup definition.

The literature set for drug treatment consists exclusively of high risk of bias studies due to very high attrition, lack of attrition reporting for subgroups or treatment groups, and small subgroup sample sizes in nonpooled analyses (Appendix C). Overall attrition in drug trials ranged from 4 percent in one off-label international trial91 to at least 47 percent,3 with most studies having 30 to 40 percent attrition. Only two off-label international drug trials reported overall attrition of less than 25 percent.90,91

Industry funded 85 percent of the 17 drug trials that reported the source of study funding (Appendix Tables E4-E7). Industry involvement in studies included data management, statistical support, manuscript drafting, construction of figures and tables, and study management. Corresponding authors in pharmaceutical trials were often industry employees.

### Subgroup Outcomes

In this section, we first examine the effect of drugs on various subgroups and then address the effects of other treatments. Those subgroup-intervention-outcome comparisons with at least low strength of evidence are provided first. Brief details for the subgroups with insufficient evidence are provided second.

#### Comorbid Mental Health Conditions

##### Depression

Adults with fibromyalgia and major depressive disorder (MDD) or history thereof were the most frequently assessed subgroup for potential differential treatment effects in patients with MDD (treatment interactions) in pharmaceutical studies, and across all other types of treatments. Eleven drug studies (eight RCTs, seven FDA approved, one off-label), two pooled IPD RCT analyses, and one observational study) assessed treatment-by-MDD interactions on the outcomes of pain, global improvement, fibromyalgia impact, and depression. One additional pooled IPD RCT analysis reported stratum-specific (differences in outcomes in treated vs. controls, but only among patients with depression) changes from baseline in a weekly average pain diary rating rather than an interaction effect (Table 6).79

Table 6 Pregabalin results from pooled patient-level RCT study: mean change from baseline in Weekly Mean Pain Diary Score (11-point scale) by comorbid condition

Author, Year | Followup Duration | Comorbid Condition at Baseline^*^ | Placebo | Pregabalin 300 mg/Day | Pregabalin 450 mg/Day | Pregabalin 600 mg/Day
Bhadra, 2010^79^ | 8-12 weeks | Headache | -1.0 | -1.7 | -1.7 | -1.5
Bhadra, 2010^79^ | 8-12 weeks | Immune/allergies | -1.1 | -1.8 | -1.9 | -2.0
Bhadra, 2010^79^ | 8-12 weeks | GI reflux | -1.1 | -1.9 | -1.9 | -1.8
Bhadra, 2010^79^ | 8-12 weeks | Insomnia | -1.3 | -2.0 | -2.0 | -2.0
Bhadra, 2010^79^ | 8-12 weeks | Depression | -1.0 | -1.6 | -1.9 | -2.1
Bhadra, 2010^79^ | 8-12 weeks | IBS | -1.1 | -1.6 | -2.1 | -1.7
Bhadra, 2010^79^ | 8-12 weeks | Neurological | -1.1 | -2.0 | -1.9 | -1.9
Bhadra, 2010^79^ | 8-12 weeks | Asthma | -1.0 | -2.1 | -1.9 | -2.1
Bhadra, 2010^79^ | 8-12 weeks | Anxiety | -1.1 | -1.8 | -1.4 | -2.0
Bhadra, 2010^79^ | 8-12 weeks | RLS | -1.6 | -1.6 | -1.7 | -2.0

Abbreviations: GI = gastrointestinal; IBS = irritable bowel syndrome; RLS = restless legs syndrome

* Comorbid conditions not mutually exclusive

Drug treatments did not appear to have differential effects in adults with fibromyalgia and depression. Low-strength evidence from six RCTs of duloxetine and one pooled IPD analysis25 suggest that pain outcomes for adults with fibromyalgia and depression do not differ.3,4,25,27,28,30,89 Pain was the most common outcome assessed in adults with fibromyalgia and comorbid depression, including six RCTs (five of duloxetine3,4,27,28,89 and one of milnacipran,85) and two pooled RCT analyses,25,26 both of duloxetine. All treatment-by-MDD interactions on pain as an outcome in the pharmacologic studies we examined were either not significant or not reported. Five different measures were used to assess pain in the MDD subgroup; the Beck Depression Inventory (BPI) average pain severity score was used most often (Appendix Tables E8 and E9). Two high risk of bias RCTs3,89 and one pooled IPD RCT analysis of four high risk of bias RCTs25 of duloxetine trials presented data on MDD subgroup BPI average pain severity scores (Tables 7 and 8). Two MDD subgroup interactions were not significant;25,89 one was not explicitly reported but the text implies that it was not significant.3 Irrespective of MDD status, when placebo group improvements are examined alongside treatment effects (Table 7), differences in improvements from baseline between treated and control group patients in BPI average pain severity were small.(0.45-1.23 points).

Table 7 Duloxetine randomized controlled trials with subgroup data showing 6-month outcomes in adults with fibromyalgia, with or without major depressive disorder

Author, Year Time | Outcome Measure | Subgroup | N-tx^*^ | Dose, Mean BPI Change in Treated (SE) | N-c^*^ | Mean BPI Change in Placebo (SE) | Interaction p Value | Difference in Mean Effect (tx-c)
Chappell, 2008^89^ | Brief Pain Inventory (BPI) average pain severity | Previous antidepressant use | 162 | 60mg/d, titrated to 120mg/d at week 8 | 168 | | 0.028
Chappell, 2008^89^ | | Yes (43% of patients) | 71 | -1.85 (0.29) | 72 | -0.65 (0.27) | | -1.20
Chappell, 2008^89^ | | No | 91 | -1.56 (0.29) | 96 | -1.51 (0.29) | | -0.05
Russell, 2008^3^ 6 months | Brief Pain Inventory (BPI) average pain severity^**^ | Major depressive disorder (MDD) (24% of patients) | 79^†^ | 20 mg/day^‡^ | 144 | | NR
Russell, 2008^3^ 6 months | | With MDD | 22 | -2.58 (0.53) | 35 | -1.35 (0.45) | | -1.23
Russell, 2008^3^ 6 months | | Without MDD | 57^§^ | -2.16 (0.34) | 109^§^ | -1.48 (0.25) | | -0.68
Russell, 2008^3^ 6 months | | | 150^†^ | 60 mg/day
Russell, 2008^3^ 6 months | | With MDD | 35 | -2.35 (0.46) | 35 | -1.35 (0.45) | | -1.00
Russell, 2008^3^ 6 months | | Without MDD | 115^§^ | -1.93 (0.25) | 109^§^ | -1.48 (0.25) | | -0.45
Russell, 2008^3^ 6 months | | | 147^†^ | 120 mg/day
Russell, 2008^3^ 6 months | | With MDD | 34 | -2.56 (0.48) | 35 | -1.35 (0.45) | | -1.21
Russell, 2008^3^ 6 months | | Without MDD | 113^§^ | -2.20 (0.25) | 109^§^ | -1.48 (0.25) | | -0.72
Russell, 2008^3^ 6 months | | | | Dose, PGI-I
Russell, 2008^3^ 6 months | Patient Global Impression of Improvement (PGI-I)^††^ | | 79^†^ | 20 mg/day^‡^ | | | NR
Russell, 2008^3^ 6 months | | With MDD | 22 | 2.85 (0.33) | | 3.28 (0.28) | | -0.43
Russell, 2008^3^ 6 months | | Without MDD | 57^§^ | 2.76 (0.22) | | 3.37 (0.16) | | -0.61
Russell, 2008^3^ 6 months | | | 150^†^ | 60 mg/day
Russell, 2008^3^ 6 months | | With MDD | 35 | 2.96 (0.29) | | 3.28 (0.28) | | -0.32
Russell, 2008^3^ 6 months | | Without MDD | 115^§^ | 3.07 (0.16) | | 3.37 (0.16) | | -0.30
Russell, 2008^3^ 6 months | | | 147^†^ | 120 mg/d
Russell, 2008^3^ 6 months | | With MDD | 34 | 2.41 (0.30) | | 3.28 (0.28) | | -0.87
Russell, 2008^3^ 6 months | | Without MDD | 113^§^ | 3.04 (0.16) | | 3.37 (0.16) | | -0.33

Abbreviations: BPI = Brief Pain inventory; MDD = major depressive disorder; N-tx = number randomized to treatment group; N-c = number randomized ton control group; PGI-I= patient global impression of improvement scale; SE = standard error; tx-c = difference in mean outcome between treated and control groups (treated minus control)

BPI: Treatment by subgroup interactions not significant for age, sex and race at 3 or 6 months (p-values reported but no data).

* Number of patients randomized to each group-does not account for attrition

† Denominators for both 3 and 6 month followup in Table 2 of the article report baseline enrollment totals by treatment group that do not reflect dropouts. Of the 520 randomized patients, 325 (62.5%*) completed the study for 3 months, and 278 for 6 months. Denominators for the number of patients per dose at 3 and 6 month followups were not reported in tables or text.

‡ Duloxetine patients on the 20mg dose during the first 3 months had their dose blindly increased to 60 mg/day for months 4 through 6 (n=49^†^).

§ Calculated by the MN EPC, not article authors

** Minimum clinically important difference (MCID) for the BPI average pain severity score in fibromyalgia patients is 2.1 points101

†† PGI-I: 7 point scale ranging from 1 (very much better) to 7 (very much worse). Dropouts were assigned a PGI-I score of 4 (corresponding to no change); the analyses assume no treatment benefit or decrement for patients who did not complete the 3- or 6-month treatment phases.3

Table 8 Results from pooled patient-level RCT data: primary outcome with subgroup changes from baseline in pooled studies that reported subgroup data

Drug Author, Year | Time | Outcome | Subgroup | | N-tx Baseline | Treatment, Dose | N-c Baseline | Control | Difference in Effect (tx-c)^*^ | Interaction p Value | MCID for Fibromyalgia
Duloxetine
Bennett, 2012^76^ | 3 months | FIQ stiffness change (0-10 scale) | Age (years) | | | Duloxetine 60 and 120 mg/day | | Placebo | | 0.246 | 13% change in FIQ stiffness42
Bennett, 2012^76^ | 3 months | FIQ stiffness change (0-10 scale) | <55 | | 485 | -2.43(0.12) | 345 | -1.50 (0.12) | -0.93
Bennett, 2012^76^ | 3 months | FIQ stiffness change (0-10 scale) | ≥55 | | 275 | -2.14(0.17) | 172 | -1.50 (0.12) | -0.67
Bennett, 2012^76^ | 3 months | FIQ stiffness change (0-10 scale) | BMI | | | | | | | 0.102
Bennett, 2012^76^ | 3 months | FIQ stiffness change (0-10 scale) | Normal | | 208 | -2.40(0.18) | 157 | -1.36 (0.21) | -1.04
Bennett, 2012^76^ | 3 months | FIQ stiffness change (0-10 scale) | Overweight | | 230 | -2.08(0.17) | 149 | -1.31 (0.21) | -0.77
Bennett, 2012^76^ | 3 months | FIQ stiffness change (0-10 scale) | Obese | | 253 | -2.51(0.17) | 164 | -1.80 (0.20) | -0.71
Bennett, 2012^76^ | 3 months | FIQ stiffness change (0-10 scale) | Extreme obesity | | 62 | -2.01(0.34) | 41 | -1.53 (0.41) | -0.48
Bradley, 2010^26^ | 3 months | BPI average pain score | FIQ Tiredness | | | Duloxetine 60 and 120 mg/day | | | | >0.1 | 2.1 points for BPI average pain severity101
Bradley, 2010^26^ | 3 months | BPI average pain score | mild | | 9^**^ | -1.3(0.5) | 20 | -1.8 (0.5) | 0.5
Bradley, 2010^26^ | 3 months | BPI average pain score | moderate | | 50^**^ | -1.6(0.2) | 83 | -1.1 (0.2) | -0.5
Bradley, 2010^26^ | 3 months | BPI average pain score | severe | | 204^**^ | -2.0(0.1) | 430 | -1.1 (0.1) | -0.9
Arnold, 2009^25^ | 3 months | BPI average pain score | Major Depressive Disorder (MDD) | | | Duloxetine 60 and 120 mg/day | | | | 0.48 | 2.1 points for BPI average pain severity101
Arnold, 2009^25^ | 3 months | BPI average pain score | Without MDD | | 594 | -1.9(0.1) | 388 | -1.2 (0.1) | -0.07
Arnold, 2009^25^ | 3 months | BPI average pain score | With MDD | | 203 | -2.0(0.2) | 147 | -1.2 (0.2) | -0.08
Milnacipran
Arnold, 2012^77^ 2 doses | 3 months | Mean weight change (kg) | BMI | n/group | | Milnacipran 100 mg/day | | | | NR | NA
Arnold, 2012^77^ 2 doses | 3 months | Mean weight change (kg) | <25 | 711 | NR | -0.33(0.21) | NR | 0.06 (0.20) | -0.39
Arnold, 2012^77^ 2 doses | 3 months | Mean weight change (kg) | 25-30 | 886 | NR | -1.39(0.23) | NR | 0.03 (0.24) | -1.42
Arnold, 2012^77^ 2 doses | 3 months | Mean weight change (kg) | ≥30 | 1507 | NR | -1.48(0.21) | NR | -0.17 (0.19) | -1.31
Arnold, 2012^77^ 2 doses | 3 months | Mean weight change (kg) | BMI | | | Milnacipran 200 mg/day | | | | NR
Arnold, 2012^77^ 2 doses | 3 months | Mean weight change (kg) | <25 | 711 | NR | -0.44(0.25) | NR | 0.06 (0.20) | -0.50
Arnold, 2012^77^ 2 doses | 3 months | Mean weight change (kg) | 25-30 | 886 | NR | -0.91(0.28) | NR | 0.03 (0.24) | -0.94
Arnold, 2012^77^ 2 doses | 3 months | Mean weight change (kg) | ≥30 | 1507 | NR | -1.13(0.26) | NR | -0.17 (0.19) | -0.96

Abbreviations: 1 kg = 1 kilogram = 2.2 pounds; BMI = Body Mass Index; BPI = Brief Pain Inventory; c = controls; d = day; FIQ = stiffness-Fibromyalgia Impact Questionnaire stiffness subscale; MCID = minimum clinically important difference; MDD = Major depressive disorder; mg = milligrams; mo = month; NA = not assessed; N-c = number in control group; NR = not reported; N-tx = number in treatment group; tx=treated.

* difference = change in outcome of (treated – control) per row Calculated by the MN EPC, not article authors. Positive difference indicates that placebo improved more than treated.

** calculated by the MN EPC from article text. Not directly reported by authors.

For the MDD subgroup, two studies (one RCT4 and one pooled IPD25) showed no difference on the Fibromyalgia Impact Questionnaire (FIQ) total score with duloxetine.4,86 Two RCTs (one of duloxetine72 and one of fluoxetine86) examined the FIQ and FIQ pain subscales as primary outcomes; both treatment-by-MDD interactions on the FIQ pain subscales4,86 and FIQ total scores4 were not significant.

Low-strength evidence from three studies of duloxetine (two RCTs3,30 and one pooled analysis25) showed no difference among subgroups on the Patient Global Impression of Improvement (PGI-I), a 7 point scale ranging from 1 (very much better) to 7 (very much worse).61 For the PGI-I, the duloxetine-by-MDD interaction in was not statistically significant,25,30 or not reported.3 The RCT by Russell et al. 2008^3^ displayed MDD subgroup data for the PGI-I. Study authors noted similar improvements in PGI-I in treated versus controls regardless of MDD status but did not report the interaction result. However, dropouts were assigned a PGI-I score of 4 (corresponding to no change) for the analysis, which assumed no treatment benefit or decrement for patients who did not complete the 3- or 6-month treatment phases3 (Table 7).

Treatment-by-MDD interaction results for all other outcomes were found in article text only, with or without p-values; these were either not significant or results were not specifically reported (Tables 9 and 10).

Table 9 Fibromyalgia mixed-sample RCT treatment-by-subgroup interaction outcomes reported in the text,^*^ by outcome measure

Treatment | Author, Year | FIQ Total | FIQ Subscale | BPI Average Pain Severity | VAS Pain | PGI-I | HAMD | Other
Mixed sample RCTs (not pure subgroups)
Pharmacologic
Duloxetine | Arnold, 2012^28^ | | | a: NS s: NS r: Nonwhite +,> White p=0.017 d: NS g: NS
| Arnold, 2010^30^ | | | | | a: NS s: NS r: NS d: NS g: NS
| Chappell, 2008^89^ | | | a: NS s: NS r: NS d: NS g: NS
| Russell, 2008^3,**^ | | | a: NS s: NS r: NS d: NR | | a: NS s: NS r: NS d: NR | d:NS within MDD strata
| Arnold, 2005^27^ | | | d: NS
| Arnold, 2004^4^ Primary: FIQ pain subscale | s: NS, p=0.101 d: NS, p=0.862 | pain s: NS, p=0.121 d: NS, p=0.677 | s: F +,> M, p=0.046 d: NR | | | | s: F +,> M in Sheehan disability (p=0.007)
Milnacipran | Gendreau, 2005^85^ | | | | d: NR | | | d: Mean pain scores on e-diary, Gracely or McGill pain questionnaires, NR
Fluoxetine | Arnold, 2002^86^ | d: NS | d: NS
Psychological
Written emotional disclosure | Junghaenel, 2008^87^ | | | | | | | 3 composite measures for: c: pain, NS; c: fatigue, NS; c:psychological well-being: interpersonally distressed +,> adaptive coping, p=0.08. e: psychological well-being: graduate educated +,> college or less educated
Mixed
Multidisciplinary (MT) with/without CBT | Lera, 2009^88^ | f:MTCBT+,>MT in fatigued p=0.21 NS | | | | | | f: MTCBT+,> MT on SF-36 emotional well-being in fatigued p=0.21 NS

Abbreviations: a = age; s = sex; r = race; d = depression, major depressive disorder (MDD) or history of MDD; e = education87; f = fatigue; g = generalized anxiety disorder (GAD); c = coping style87; w = SF-36 emotional well-being88 o = other subgroup

CBT = cognitive behavioral therapy; MTCBT = multidisciplinary (MT) with CBT; NR = interaction significance was not reported; NS = Treatment by subgroup interaction not statistically significant; SF-36 = Medical Outcomes Study short form 36 item health survey

+ the study reported statistically positive treatment effect in the subgroup for the outcome

> improved more than

* no additional subgroup data provided in any articles except in Russell 2008

** Russell 2008 included text and table reporting of subgroup data

Table 10 Summary of pooled RCT outcomes in fibromyalgia subgroups: significance of overall treatment-by-subgroup interaction terms where interaction results were reported (in text with/without p-values but without supporting data)

Treatment and Subgroup | Author, Year | Followup | FIQ | FIQ Subscales | BPI | VAS Pain | PGI-I | PGI-C | SF-36 | Other
Pharmacologic
Duloxetine
Age (<55, ≥55) | Bennett, 2012^76^ | 3 months | | NS p=0.246
BMI (normal, overweight, obese, extreme obesity) | Bennett, 2012^76^ | 3 months | | NS p=0.102
FIQ Tiredness (mild, moderate, severe) | Bradley, 2010^26^ | 3 months | NS p=0.74 | NS p>0.1 | NS p>0.1 | | NS p=0.908 | | NS p>0.1
MDD: Major depressive disorder | Arnold, 2009^25^ | 3 months | NS p=0.46 | | NS p=0.48 primary outcome | | NS p=0.45 | | NS p=NR | NS (all) HAMD p=0.14 CGI-S p=0.98 SDS p=0.18 MFI p= NR
Milnacipran
BMI (<25, 25-30, ≥30) | Arnold, 2012^77^ | 3 months | | | | | | | | Weight loss NR
Baseline VAS Pain (≤64.7, >64.7) | Geisser, 2011^78^ | 3 months and 6 months | | | | Reported % (n) with ≥30% improvement only NR | | Reported % (n) with PGI-C ≤2 only NR | 6 pt better in SF-36 PCS NR | ≥30% better on PGI-C and VAS pain NR
Pregabalin
Anxiety | Arnold, 2010^29^ | Pooled 8, 13, and 14 weeks | | | | I | | | | HADS-A (≥2 pts, <2 pts) I
Depression | Arnold, 2010^29^ | *Pooled 8, 13, and 14 weeks | | | | I | | | | HADS-D I
10 Comorbid Conditions | Bhadra, 2010^79^ | *8-12 weeks | | | | | | NR | | Weekly pain rating of 0-10 NR all subgroups
Age (<40, 40-60, >60) | Byon, 2010^80^ | * 8-14 weeks | | | | | | NR | | Weekly mean pain rating: greater pain reduction in older vs. younger patients NR
Sex | Byon, 2010^80^ | * 8-14 weeks | | | | | | NR | | Weekly mean pain rating: greater pain reduction in females vs. males NR

Abbreviations: BPI = Brief Pain Inventory; CGI-S = Clinical Global Impression of Severity Scale; FIQ = Fibromyalgia Impact Questionnaire; HADS-A = Hospital Anxiety and Depression Scale, anxiety subscale score; HADS-D = Hospital Anxiety and Depression Scale, depression subscale score; HAMD = Hamilton Rating Scale for Depression; I = indeterminable as reported (figures, lack n’s, etc.); MFI = Multidimensional Fatigue Inventory; N = not significant; NR = significance of interaction not reported; NA = not assessed; PGI-C = Patient Global Impression of Change Scale; PGI-I = Patient Global Impression of Improvement Scale; SDS = Sheehan Disability Scale; SF-36 = MOS Short-Form 36-item Health Survey; VAS = Visual Analog Scale

* At least 1 of the pooled studies reported longest followup outcomes at less than 12 weeks.

Insufficient information on duloxetine effects on the Hamilton Rating Scale for Depression3,25 (Table 11) and the Beck Depression Inventory28 was available for analysis for the MDD subgroup.

Table 11 Change in depression as measured by the Hamilton Depression Scale (HAMD) in one randomized controlled trial of duloxetine among fibromyalgia patients with MDD at baseline^*^

Author, Year | Group | Baseline HAMD With MDD | 6-Month Change in HAMD With MDD
Russell, 2008^3^ | Placebo | 15.3 (4.58) | -4.8 (n=30)
Russell, 2008^3^ | 20 mg/day^‡^ | 15.1 (4.9) | -5.2 (n=22) 20→60 mg
Russell, 2008^3^ | 60 mg/day | 15.4 (5.8) | -6.9 (n=30)
Russell, 2008^3^ | 120 mg/day | 16.3 (4.4) | -7.2 (n=29)

* Authors reported baseline HAMD in patients without MDD, but did not report 6 month followup for those without MDD

† Denominators for both 3 and 6 month followup in Table 2 of the article report baseline enrollment totals by treatment group that do not reflect dropouts. Of the 520 randomized patients, 325 (62.5%*) completed the study for 3 months, and 278 for 6 months. Denominators for the number of patients per dose at 3 and 6 month followups were not reported in tables or text.

‡ Duloxetine patients on the 20 mg dose during the first 3 months had their dose blindly increased to 60 mg/day for months 4 through 6 (n=49^†^)

One observational study of milnacipran was a post-hoc analysis of RCT data that stratified by baseline Beck Depression Inventory score to assess improvement in VAS pain scores. No formal statistical analysis was conducted for subgroup effects.81

These reported results should be considered along with issues common to this set of studies. At baseline, MDD subgroup sample sizes were small in all RCTs, and difficult to determine in pooled analyses that reported only the number of patients randomized to the input RCTs, excluding attrition information. The number of patients with MDD at final followup in both treatment and control groups was usually not determinable due to incomplete reporting of denominator values and dropouts per subgroup or by treatment groups after baseline. The lack of denominator values after baseline was common in both RCT and pooled analyses.

##### Anxiety

Three RCTs provided insufficient evidence for duloxetine effects in patients with generalized anxiety disorder (GAD) on the BPI average pain severity score28,89 and PGI-I28,30 (Table 9). One pooled IPD RCT analysis provided insufficient evidence for pregabalin in stratum-specific changes from baseline in a weekly average pain diary rating, rather than an interaction79 (Table 6).

#### Other Subgroups

##### Age

Six drug studies examined potential age-related differences in treatment effectiveness in adults with fibromyalgia.21,24,25, 76,80,89 Five of the six studies tested duloxetine effects (four RCTs3,28,30,89 and one pooled IPD RCT analysis76) and one pooled IPD analysis examined pregabalin.80 Five studies reported 3-month outcomes; two RCTs reported 6 month outcomes.3,89

Of these, three RCTs with low-strength evidence found no differences by age for duloxetine effects on the BPI average pain severity score at 3 or 6 months21,24,89 (Tables 7 and 9).

Two low-strength evidence RCTs found no differences by age in duloxetine effects on the PGI-I24,25 (Tables 7 and 9).

One pooled IPD analysis by Bennett et al.76 provided pooled data for nonsignificant differences in the effect of duloxetine on FIQ stiffness by age, dichotomized at age 55 (Table 8). One pregabalin study was a statistical modeling paper that provided insufficient evidence for the effect of pregabalin on weekly pain by age80 (Table 10).

##### Sex

For the BPI average pain severity score, four RCTs that assessed duloxetine effects by sex offered insufficient evidence of a mixed pattern; in three there was no difference by sex3,28,89 at 3^3,28^ or 6 months,24, 89 but in one study, females improved more than males at 3 months (p=0.046)72 (Tables 9 and 10).

When PGI-I was the outcome, low-strength evidence from two duloxetine studies showed no differences by sex in 3 and 6 month treatment effects.3,30

Three studies reported outcomes for other pain measures; all evidence was insufficient. One pooled analysis/statistical modeling paper of four RCTs with 8-14 weeks of followup reported greater weekly pain reduction in females versus males in text but did not provide useable interaction results80 (Table 10). Two high risk of bias pure subgroup RCTs provided insufficient evidence for off-label drug treatment effects in postmenopausal women with fibromyalgia. One underpowered study examined the effects of transdermal estrogen versus placebo on pain and found no difference between groups.90 The second study of 100 women found that women treated with raloxifen had greater mean reduction in pain, sleep disturbance, and tender points but no effect on anxiety and depression relative to women treated with placebo.91

One RCT offered insufficient interaction evidence that women improved more than men in the Sheehan Disability Scale (p=0.007).4

##### Race

Although not listed as an a priori subgroup due to the expected small number of nonwhite race patients in fibromyalgia trials, treatment-by-race interactions were assessed in four RCTs, all of duloxetine3,28,30,89 (Table 9). The outcomes included BPI average pain severity3,28,89 and global improvement (PGI-I).3,30

There was insufficient evidence of mixed effects by race for duloxetine on the BPI average pain severity from three RCTs; two RCTs found no difference in BPI average pain severity by race3,89 but in one underpowered RCT, nonwhites improved more than whites.28 The sample size for the nonwhite subgroup was small at baseline (22 treated, 17 placebo) and was not reported for the 3-month followup.28

Two RCTs with low-strength evidence reported no difference by race when PGI-I was the outcome.3,30

##### Obesity

Two pooled IPD analyses, one of duloxetine76 and one of milnacipran77 provided insufficient evidence for the outcomes of stiffness76 (FIQ subscale) and weight loss77 for subgroups determined by BMI at baseline. All input RCTs for these pooled IPD analyses were high risk of bias studies. The duloxetine pooled IPD analysis76 assessed whether treatment effects on stiffness associated with fibromyalgia, measured by the FIQ stiffness subscale (one item), varied by BMI. The 3-month outcomes data were reported, stratified by BMI (normal, overweight, obese, and morbidly obese) (Table 8). The treatment-by-BMI interaction was not significant. However, the small differences between treated and placebo-controlled patients in changes in FIQ stiffness from baseline decreased with increasing levels of BMI. No interaction result was reported in a pooled milnacipran study that reported that overweight and obese patients had greater mean weight loss than normal or underweight patients at 3 months.77

##### Other Subgroup Outcomes

One high risk of bias duloxetine RCT reported 6-month changes in BPI average pain severity for patients stratified by prior antidepressant use at baseline (Table 7).89 The interaction was significant, whereby treated patients with previous antidepressant use had greater improvements in BPI average pain then those without prior antidepressant use (p=0.028).

Bradley et al.26 conducted a pooled analysis of IPD RCT data to determine if duloxetine effects on the BPI average pain score varied by baseline level of fatigue using the FIQ tiredness subscale. The interaction term was not significant; data are shown in Table 8.

Within-subgroup changes from baseline in pain in fibromyalgia patients with any of ten different concomitant conditions (such as headache, irritable bowel syndrome, or gastrointestinal reflux) were reported by Bhadra et al.79 in a study of varying doses of pregabalin. No interaction effects were assessed (Table 6).

No other subgroups were separately reported in included studies.

### Physical Treatments

Due to the sparse literature on physical treatment effects in subgroups of adults with fibromyalgia, this section is organized by the type of study design, and subsequently, by specific type of intervention. All physical interventions were assessed in pure subgroup RCTs. Study duration ranged from 3 months to 6 months (Appendix Table E5).

Five pure subgroup RCTs examined the effects of exercise interventions92-94,98 and one assessed the impact of dietary changes53 on outcomes in subgroups of adults with fibromyalgia. Two studies of physical interventions had moderate risk of bias;52,92 all others were high risk of bias. Sample sizes ranged from 21 to 83 adults at enrollment, for a total of 311 subjects across all five studies.

One moderate risk of bias RCT exclusively of sedentary women with fibromyalgia92 compared the aerobic exercise interventions of deep water running versus land-based exercise (control) on the outcomes of fibromyalgia impact (FIQ), pain (VAS), depression (BDI), health status (SF-36), and Patients Global Assessment of response to treatment (PGART). Both groups improved significantly with 15 weeks of three times per week exercise, with greater improvements in the FIQ in the deep water running group. There were no differences in improvement from baseline between groups in all other measures.

Gusi et al.52 assessed the effects of whole body vibration on dynamic balance in a post hoc analysis of RCT data by baseline body weight. This moderate risk of bias studies found that participants with the heaviest weight and worst balance at baseline improved more than others (p<0.001).

Two exercise interventions were evaluated in females with fibromyalgia based on their menopausal status;93,94 both studies had a high risk of bias. Hakkinen et al.93 evaluated the isometric knee strength and serum hormone effects of 21 weeks of supervised strength training in premenopausal women. Only isometric knee strength increased significantly in the strength-trained versus normal activities group. The high risk of bias Valkeinen study94 of strength and aerobic training versus no training in postmenopausal women age 50 and older reported a 2 percent improvement in strength and significant improvements in pain, walking, and stair climbing ability in the trained versus no strength or aerobic training group, with no differences in fatigue, well-being, or sleep quality reported.

The strength of evidence was insufficient to compare treatment outcomes by physical interventions in these pure subgroup RCTs. All studies tested unique treatments in unique subgroups and had small sample sizes; four of six were high risk of bias studies (Appendix Table E10).

### Psychological Therapies

Four studies examined the effects of psychological therapies in subgroups of adults with fibromyalgia: one mixed-sample RCT,87 two pure subgroup RCTs,95,96 and one observational study.83 Study duration ranged from 3 months to 1 year, which was the longest followup of any studies included in this report. Sample sizes were small; the total number of adults included across these psychological studies was 210. All assessed unique outcomes in disparate subgroups and all were high risk of bias studies.

Junghaenel et al.87 compared outcomes in fibromyalgia patients by their level of education and dominant pain coping strategy at baseline to assess the effects of a written emotional disclosure intervention on pain, fatigue, and psychological wellbeing in a mixed-sample RCT. Outcomes from the writing intervention did not differ by level of education or baseline pain coping strategy for pain or fatigue, but adults with the pain coping strategy called “interpersonally-distressed” improved more in the psychological wellbeing outcome than did the “adaptive” pain coping group. Also, only graduate-educated adults had significant improvements in psychological well-being with the intervention compared to less educated individuals.

The longest of all included studies was a year-long study of the effects of psychotherapy versus four primary care consultations with advice on medication and exercise on multiple outcomes. This high risk of bias pure subgroup RCT included women with fibromyalgia, all of whom had concomitant psychological comorbidity, including MDD, dysthymia, anxiety, and double depression.96 Both interventions were deemed to be equally effective; there were no significant outcomes differences from psychotherapy versus primary care interventions by type of baseline psychological comorbidity. This was the only study that included patients with mental health conditions other than major depressive disorder or anxiety.

One high risk of bias pure subgroup RCT compared CBT versus other behavioral therapy versus usual care on sleep patterns in adults with fibromyalgia and insomnia. Both treatment groups improved, with the CBT group showing the greatest improvements in polysomnography assessed wake times.

One high risk of bias observational biofeedback study examined the benefits of using EMG-reduction training of visual and auditory feedback to teach two groups of subjects the same muscle relaxation techniques.83 Subjects were stratified by baseline Minnesota Multiphasic Personality Inventory (MMPI) scores to assess outcomes of pain perception, tender point scores, and the SF-36. Although the group with “psychologically abnormal” MMPI scores was worse off than “psychologically normal” women in all measures at baseline, the psychologically abnormal group had improvements in all outcomes measures, including pain and fibromyalgia symptoms, which were not experienced in the comparator group of women.

The strength of evidence was insufficient to compare subgroup treatment effects for psychological interventions in these four studies due to their high risk of bias and small sample sizes (Appendix Table E10 and E11).

### Mixed Types of Treatments

Four studies assessed combination therapies, and each study had a high risk of bias; one RCT, two pure subgroup RCTs and one observational study.84,88,97,99

A mixed sample RCT included a subgroup of 16 patients with fatigue.88 Multidisciplinary treatment with CBT showed greater improvements in the FIQ total score and SF-36 emotional well-being in fatigue patients than with multidisciplinary treatment alone. The study was not powered to assess subgroup effects.

In a pure subgroup RCT, Fontaine et al.97 assessed the effects of a cognitive behavioral physical activity promotion program on multiple outcomes in adults with fibromyalgia who had suboptimal physical activity in the prior 6 months per U.S. Surgeon General’s recommendations. The treated group increased daily walking (count of steps) by 54 percent, and had a significant reduction in mean total FIQ (-16 percent; MCID (minimum clinically important difference) is 14 percent42) and reduction in the FIQ pain subscore. No differences were noted in the 6 minute walk test, BMI, fatigue, depression, or number of tender points between groups. Martinez et al.99 found that adults treated with CBT for insomnia improved total FIQ and sleep measures after 6 weeks of treatment compared with sleep education in a pure subgroup study. Most adults also took medication; the effect of CBT was not sustained at 3 or 6 months.

One observational study evaluated the effects of supervised multifaceted exercise and relaxation (exercise plus relaxation) versus amitriptyline for subgroups determined by socioeconomic status and FIQ pain score.84 Both strategies equally reduced disability.

The strength of evidence was insufficient to compare treatment outcomes for mixed types of fibromyalgia treatments. All four studies assessed unique treatment-subgroup-outcomes combinations, and all had a high risk of bias (Appendix Tables E10 and E11).

## Key Question 2 Adverse Treatment Effects in Fibromyalgia Subgroups

The clinical trial literature on adults with fibromyalgia that reported on subgroup treatment effects was nearly devoid of adverse effect (harms) reporting for subgroups. Therefore, this section is organized by the type of study design, under which we report summary information on harms only.

### Key Points

- Adverse effects (AEs) were rarely reported by subgroup
- Evidence was insufficient to determine whether or not AEs of treatments for adults with fibromyalgia vary in adult subgroups or whether subgroups experience atypical AEs for a given treatment
- When reported, AEs did not markedly differ in subgroups

### RCTs

None of the ten mixed sample RCTs with adverse effect reporting and subgroup treatment outcomes separately reported AEs by subgroups.3,4,27,28,30,85-89

### Pure Subgroup RCTs

Of the 12 RCTs that sampled within at least one subgroup, only three reported any information on adverse treatment effects: two off-label pharmacologic studies90,91 and one test of an exercise intervention.92 The most common side effect in the deep water running versus land-based exercise intervention was muscle pain, which was more common in the land-based exercise control group.92 The raloxifen versus placebo study91 reported one serious AE (deep vein thrombosis) affecting 2 percent of the treated group with less severe issues of leg cramps, anxiety, and flushing affecting 10-15 percent of the treated group. The second small RCT tested transdermal 17B-estradiol on pain in 29 women.90 The study was halted at half the planned sample size due to new information that emerged with concerns for the health effects of hormone replacement therapy.

### Pooled IPD RCT Analyses

Adverse effects were reported for subgroups in one pooled analysis of duloxetine clinical trials.25 In a pooled analysis of patients with fibromyalgia and major depressive disorder, the treatment-by-MDD interaction for serious adverse events was not significant (p>0.1).25 However, the treatment-by-MDD stratum interaction was significant for “treatment-emergent adverse events,” with higher rates of 10 adverse effects in treated patients with MDD relative to treated adults without MDD. The three most common of the “treatment-emergent adverse effects” in treated patients were nausea (31.6 percent), headache (19.6 percent), and dry mouth (19.1 percent) in the duloxetine-MDD group, which was 0.4-3.3 percent higher than the rates in the group treated without MDD. The lower proportion of placebo-treated patients with MDD that experienced these adverse effects was similar to those experienced by placebo-treated adults without MDD.

AEs were reported only by treatment group, not by subgroup, in two pooled milnacipran studies77,78 and in one duloxetine study.76 AEs were not reported in the three pooled pregabalin studies.29,79,80

### Observational Studies

Only one of four observational studies reported adverse treatment effects in a crossover study of 10 patients treated with naltrexone (off-label) versus placebo that were grouped by baseline erythrocyte sedimentation rate (ESR).82 The most common AEs were vivid dreams, nausea, and insomnia.