# References

1 Goldenberg DL, Burckhardt C, Crofford L. Management of fibromyalgia syndrome. JAMA. Nov. 17. 2004;292(19):2388-95. [pmid: 15547167].
2 Okifuji A, Hare BD. Management of fibromyalgia syndrome: review of evidence. Pain Ther. Dec. 2013;2(2):87-104. [pmid: 25135147].
3 Russell IJ, Mease PJ, Smith TR, et al. Efficacy and safety of duloxetine for treatment of fibromyalgia in patients with or without major depressive disorder: results from a 6-month, randomized, double-blind, placebo-controlled, fixed-dose trial. Pain. Jun. 2008;136(3):432-44. [pmid: 18395345].
4 Arnold LM, Lu Y, Crofford LJ, et al. A double-blind, multicenter trial comparing duloxetine with placebo in the treatment of fibromyalgia patients with or without major depressive disorder. Arthritis Rheum. Sep. 2004;50(9):2974-84. [pmid: 15457467].
5 Centers for Disease Control and Prevention. Fibromyalgia. Centers for Disease Control and Prevention. 2012. http://www.cdc.gov/arthritis/basics/fibromyalgia.htm. July 17, 2013.
6 Goldenberg D, Schur P, Romain P. Clinical manifestations and diagnosis of fibromyalgia in adults. UpToDate. Wolters Kluwer. 2013.
7 Howard KJ, Mayer TG, Neblett R, et al. Fibromyalgia syndrome in chronic disabling occupational musculoskeletal disorders: prevalence, risk factors, and posttreatment outcomes. J Occup Environ Med. Dec. 2010;52(12):1186-91. [pmid: 21124244].
8 Kleinman N, Harnett J, Melkonian A, et al. Burden of fibromyalgia and comparisons with osteoarthritis in the workforce. J Occup Environ Med. Dec. 2009;51(12):1384-93. [pmid: 19952796].
9 McDonald M, DiBonaventura M, Ullman S. Musculoskeletal pain in the workforce: the effects of back, arthritis, and fibromyalgia pain on quality of life and work productivity. J Occup Environ Med. Jul. 2011;53(7):765-70. [pmid: 21685799].
10 Lawrence RC, Felson DT, Helmick CG, et al. Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Part II. Arthritis Rheum. Jan. 2008;58(1):26-35. [pmid: 18163497].
11 Vincent A, Lahr BD, Wolfe F, et al. Prevalence of fibromyalgia: a population-based study in Olmsted County, Minnesota, utilizing the Rochester Epidemiology Project. Arthritis Care Res. May. 2013;65(5):786-92. [pmid: 23203795].
12 Haviland MG, Banta JE, Przekop P. Fibromyalgia: prevalence, course, and co-morbidities in hospitalized patients in the United States, 1999-2007. Clin Exp Rheumatol. Nov-Dec. 2011;29(6 Suppl 69):S79-87. [pmid: 22243553].
13 Wolfe F, Clauw DJ, Fitzcharles MA, et al. The American College of Rheumatology preliminary diagnostic criteria for fibromyalgia and measurement of symptom severity. Arthritis Care Res. May. 2010;62(5):600-10. [pmid: 20461783].
14 Wolfe F, Clauw DJ, Fitzcharles MA, et al. Fibromyalgia criteria and severity scales for clinical and epidemiological studies: a modification of the ACR Preliminary Diagnostic Criteria for Fibromyalgia. J Rheumatol. Jun. 2011;38(6):1113-22. [pmid: 21285161].
15 Wolfe F, Smythe HA, Yunus MB, et al. The American College of Rheumatology 1990 criteria for the classification of fibromyalgia. Report of the Multicenter Criteria Committee. Arthritis Rheum. 1990;33(2):160-72. [pmid: 2306288].
16 Hauser W, Wolfe F. Diagnosis and diagnostic tests for fibromyalgia (syndrome). Reumatismo. 2012;64(4):194-205. [pmid: 23024964].
17 Hauser W, Jung E, Erbsloh-Moller B, et al. Validation of the Fibromyalgia Survey Questionnaire within a cross-sectional survey. PLoS ONE. 2012;7(5):e37504. [pmid: 22662163].
18 Kim SM, Lee SH, Kim HR. Applying the ACR preliminary diagnostic criteria in the diagnosis and assessment of fibromyalgia. Korean J Pain. Jul. 2012;25(3):173-82. [pmid: 22787548].
19 Bennett RM, Friend R, Marcus D, et al. Criteria for the diagnosis of fibromyalgia: validation of the modified 2010 preliminary American College of Rheumatology criteria and the development of alternative criteria. Arthritis Care Res (Hoboken). Sep. 2014;66(9):1364-73. [pmid: 24497443].
20 Goldenberg D, Schur P, Romain P. Initial treatment of fibromyalgia in adults. UpToDate. Wolters Kluwer. 2013.
21 Terhorst L, Schneider MJ, Kim KH, et al. Complementary and alternative medicine in the treatment of pain in fibromyalgia: a systematic review of randomized controlled trials. J Manipulative Physiol Ther. Sep. 2011;34(7):483-96. [pmid: 21875523].
22 Staud R. Pharmacological treatment of fibromyalgia syndrome: new developments. Drugs. 2010;70(1):1-14. [pmid: 20030422].
23 Kasper S, Pail G. Milnacipran: a unique antidepressant?. Neuropsychiatr Dis Treat. 2010;6:23-31. [pmid: 20856597].
24 Gartlehner G, Hansen RA, Morgan LC, et al. Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: An Update of the 2007 Comparative Effectiveness Review. Rockville (MD). 2011.
25 Arnold LM, Hudson JI, Wang F, et al. Comparisons of the efficacy and safety of duloxetine for the treatment of fibromyalgia in patients with versus without major depressive disorder. Clin J Pain. Jul-Aug. 2009;25(6):461-8. [pmid: 19542792].
26 Bradley LA, Bennett R, Russell IJ, et al. Effect of duloxetine in patients with fibromyalgia: tiredness subgroups. Arthritis Res Ther. 2010;12(4):R141. [pmid: 20630058].
27 Arnold LM, Rosen A, Pritchett YL, et al. A randomized, double-blind, placebo-controlled trial of duloxetine in the treatment of women with fibromyalgia with or without major depressive disorder. Pain. Dec. 15. 2005;119(1-3):5-15. [pmid: 16298061].
28 Arnold LM, Zhang S, Pangallo BA. Efficacy and safety of duloxetine 30 mg/d in patients with fibromyalgia: a randomized, double-blind, placebo-controlled study. Clin J Pain. Nov-Dec. 2012;28(9):775-81. [pmid: 22971669].
29 Arnold LM, Leon T, Whalen E, et al. Relationships among pain and depressive and anxiety symptoms in clinical trials of pregabalin in fibromyalgia. Psychosomatics. Nov-Dec. 2010;51(6):489-97. [pmid: 21051680].
30 Arnold LM, Clauw D, Wang F, et al. Flexible dosed duloxetine in the treatment of fibromyalgia: a randomized, double-blind, placebo-controlled trial. J Rheumatol. Dec. 2010;37(12):2578-86. [pmid: 20843911].
31 Fitzcharles MA, Ste-Marie PA, Gamsa A, et al. Opioid use, misuse, and abuse in patients labeled as fibromyalgia. Am J Med. Oct. 2011;124(10):955-60. [pmid: 21962316].
32 Hauser W, Kuhn-Becker H, von Wilmoswky H, et al. Demographic and clinical features of patients with fibromyalgia syndrome of different settings: a gender comparison. Gend Med. Apr. 2011;8(2):116-25. [pmid: 21536230].
33 Wolfe F, Anderson J, Harkness D, et al. A prospective, longitudinal, multicenter study of service utilization and costs in fibromyalgia. Arthritis Rheum. Sep. 1997;40(9):1560-70. [pmid: 9324009].
34 Weimer MB, Macey TA, Nicolaidis C, et al. Sex differences in the medical care of VA patients with chronic non-cancer pain. Pain Med. Dec. 2013;14(12):1839-47. [pmid: 23802846].
35 Castro-Sanchez AM, Mataran-Penarrocha GA, Lopez-Rodriguez MM, et al. Gender differences in pain severity, disability, depression, and widespread pressure pain sensitivity in patients with fibromyalgia syndrome without comorbid conditions. Pain Med. Dec. 2012;13(12):1639-47. [pmid: 23171037].
36 Aparicio VA, Ortega FB, Carbonell-Baeza A, et al. Are there gender differences in quality of life and symptomatology between fibromyalgia patients?. Am J Mens Health. Jul. 2012;6(4):314-9. [pmid: 22494975].
37 Campos RP, Vazquez MI. The impact of fibromyalgia on health-related quality of life in patients according to age. Rheumatol Int. Jun. 2013;33(6):1419-24. [pmid: 23152088].
38 Shillam CR, Dupree Jones K, Miller L. Fibromyalgia symptoms, physical function, and comorbidity in middle-aged and older adults. Nurs Res. Sep-Oct. 2011;60(5):309-17. [pmid: 21873914].
39 Kim CH, Luedtke CA, Vincent A, et al. Association of body mass index with symptom severity and quality of life in patients with fibromyalgia. Arthritis Care Res. Feb. 2012;64(2):222-8. [pmid: 21972124].
40 Epstein SA, Kay G, Clauw D, et al. Psychiatric disorders in patients with fibromyalgia. A multicenter investigation. Psychosomatics. Jan-Feb. 1999;40(1):57-63. [pmid: 9989122].
41 Hauser W, Burgmer M, Kollner V, et al. Fibromyalgia syndrome as a psychosomatic disorder - diagnosis and therapy according to current evidence-based guidelines. Z Psychosom Med Psychother. 2013;59(2):132-52. [pmid: 23775553].
42 Bennett RM, Bushmakin AG, Cappelleri JC, et al. Minimal clinically important difference in the fibromyalgia impact questionnaire. J Rheumatol. Jun. 2009;36(6):1304-11. [pmid: 19369473].
43 Wasserman RA, Brummett CM, Goesling J, et al. Characteristics of chronic pain patients who take opioids and persistently report high pain intensity. Reg Anesth Pain Med. Jan-Feb. 2014;39(1):13-7. [pmid: 24310048].
44 Nijs J, Roussel N, Van Oosterwijck J, et al. Fear of movement and avoidance behaviour toward physical activity in chronic-fatigue syndrome and fibromyalgia: state of the art and implications for clinical practice. Clin Rheumatol. Aug. 2013;32(8):1121-9. [pmid: 23639990].
45 Wolfe F, Anderson J, Harkness D, et al. Health status and disease severity in fibromyalgia: results of a six-center longitudinal study. Arthritis Rheum. Sep. 1997;40(9):1571-9. [pmid: 9324010].
46 Zammurrad S, Munir W, Farooqi A. Disease activity score in rheumatoid arthritis with or without secondary fibromyalgia. J Coll Physicians Surg--Pak. Jun. 2013;23(6):413-7. [pmid: 23763802].
47 Mourao AF, Blyth FM, Branco JC. Generalised musculoskeletal pain syndromes. Best Prac Research. Clin Rheumatol. Dec. 2010;24(6):829-40. [pmid: 21665129].
48 Wolfe F, Ross K, Anderson J, et al. The prevalence and characteristics of fibromyalgia in the general population. Arthritis and Rheumatism. 1995;38(1):19-28. [pmid: 7818567].
49 Gore M, Tai KS, Chandran A, et al. Clinical characteristics, pharmacotherapy, and healthcare resource use among patients with fibromyalgia newly prescribed pregabalin or tricyclic antidepressants. Journal of Medical Economics. 2012;15(1):32-44. [pmid: 21970698].
50 Wolfe F, Ross K, Anderson J, et al. Aspects of fibromyalgia in the general population: Sex, pain threshold, and fibromyalgia symptoms. J Rheumatol. 1995;22(1):151-6. [pmid: 7699662].
51 Smith HS, Harris R, Clauw D. Fibromyalgia: an afferent processing disorder leading to a complex pain generalized syndrome. Pain Physician. Mar-Apr. 2011;14(2):E217-45. [pmid: 21412381].
52 Gusi N, Parraca JA, Olivares PR, et al. Tilt vibratory exercise and the dynamic balance in fibromyalgia: A randomized controlled trial. Arthritis Care Res. Aug. 2010;62(8):1072-8. [pmid: 20235191].
53 Senna MK, Sallam RA, Ashour HS, et al. Effect of weight reduction on the quality of life in obese patients with fibromyalgia syndrome: a randomized controlled trial. Clin Rheumatol. Nov. 2012;31(11):1591-7. [pmid: 22948223].
54 Busse JW, Ebrahim S, Connell G, et al. Systematic review and network meta-analysis of interventions for fibromyalgia: a protocol. Syst Rev. 2013;2:18. [pmid: 23497523].
55 Yunus M, Masi AT, Calabro JJ, et al. Primary fibromyalgia (fibrositis): clinical study of 50 patients with matched normal controls. Semin Arthritis Rheum. Aug. 1981;11(1):151-71. [pmid: 6944796].
56 McCormack HM, Horne DJ, Sheather S. Clinical applications of visual analogue scales: a critical review. Psychol Med. Nov. 1988;18(4):1007-19. [pmid: 3078045].
57 Cleeland CS, Ryan KM. Pain assessment: global use of the Brief Pain Inventory. Ann Acad Med Singapore. Mar. 1994;23(2):129-38. [pmid: 8080219].
58 Melzack R. The McGill Pain Questionnaire: major properties and scoring methods. Pain. Sep. 1975;1(3):277-99. [pmid: 1235985].
59 Burckhardt CS, Clark SR, Bennett RM. The Fibromyalgia Impact Questionnaire: development and validation. J Rheumatol. May. 1991;18(5):728-33. [pmid: 1865419].
60 Bennett RM, Friend R, Jones KD, et al. The Revised Fibromyalgia Impact Questionnaire (FIQR): validation and psychometric properties. Arthritis Res Ther. 2009;11(4):R120. [pmid: 19664287].
61 Guy W. ECDEU assessment manual for psychopharmacology, revised. Rockville, MD. US Department of Health, Education and Welfare publication (ADM). National Institute of Mental Health. 1976.
62 Bennett R. The Fibromyalgia Impact Questionnaire (FIQ): a review of its development, current version, operating characteristics and uses. Clin Exp Rheumatol. Sep-Oct. 2005;23(5 Suppl 39):S154-62. [pmid: 16273800].
63 Ware JE Jr, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. Jun. 1992;30(6):473-83. [pmid: 1593914].
64 Belza BL. Comparison of self-reported fatigue in rheumatoid arthritis and controls. J Rheumatol. Apr. 1995;22(4):639-43. [pmid: 7791155].
65 Hays RD, Martin SA, Sesti AM, et al. Psychometric properties of the Medical Outcomes Study Sleep measure. Sleep Med. Jan. 2005;6(1):41-4. [pmid: 15680294].
66 Beckles Z, Glover S, Ashe J, et al. Searching CINAHL did not add value to clinical questions posed in NICE guidelines. J Clin Epidemiol. Sep. 2013;66(9):1051-7. [pmid: 23835312].
67 Moseley AM, Sherrington C, Elkins MR, et al. Indexing of randomised controlled trials of physiotherapy interventions: a comparison of AMED, CENTRAL, CINAHL, EMBASE, hooked on evidence, PEDro, PsycINFO and PubMed. Physiotherapy. Sep. 2009;95(3):151-6. [pmid: 19635333].
68 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. Sep. 2000;53(9):964-72. [pmid: 11004423].
69 Morrison A, Polisena J, Husereau D, et al. The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. International journal of technology assessment in health care. Apr. 2012;28(2):138-44. [pmid: 22559755].
70 Pham B, Klassen TP, Lawson ML, et al. Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. Aug. 2005;58(8):769-76. [pmid: 16086467].
71 Higgins JPT, Altman D, Sterne J. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions: Version 5.1.0: The Cochrane Collaboration. 2011.
72 Sun X, Briel M, Walter SD, et al. Is a subgroup effect believable? Updating criteria to evaluate the credibility of subgroup analyses. BMJ. 2010;340:c117. [pmid: 20354011].
73 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. Feb. 2012;65(2):163-78. [pmid: 21959223].
74 Fisher DJ, Copas AJ, Tierney JF, et al. A critical review of methods for the assessment of patient-level interactions in individual participant data meta-analysis of randomized trials, and guidance for practitioners. J Clin Epidemiol. Sep. 2011;64(9):949-67. [pmid: 21411280].
75 Berkman ND, Lohr KN, Ansari M, et al. Grading the strength of a body of evidence when assessing health care interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Rockville, MD. November. 2013. www.effectivehealthcare.ahrq.gov.
76 Bennett R, Russell IJ, Choy E, et al. Evaluation of patient-rated stiffness associated with fibromyalgia: a post-hoc analysis of 4 pooled, randomized clinical trials of duloxetine. Clin Ther. Apr. 2012;34(4):824-37. [pmid: 22421576].
77 Arnold LM, Palmer RH, Hufford MR, et al. Effect of milnacipran on body weight in patients with fibromyalgia. Int J Gen Med. 2012;5:879-87. [pmid: 23109813].
78 Geisser ME, Palmer RH, Gendreau RM, et al. A pooled analysis of two randomized, double-blind, placebo-controlled trials of milnacipran monotherapy in the treatment of fibromyalgia. Pain Pract. Mar-Apr. 2011;11(2):120-31. [pmid: 20642487].
79 Bhadra P, Petersel D. Medical conditions in fibromyalgia patients and their relationship to pregabalin efficacy: pooled analysis of Phase III clinical trials. Expert Opin Pharmacother. Dec. 2010;11(17):2805-12. [pmid: 21039311].
80 Byon W, Ouellet D, Chew M, et al. Exposure-response analyses of the effects of pregabalin in patients with fibromyalgia using daily pain scores and patient global impression of change. J Clin Pharmacol. Jul. 2010;50(7):803-15. [pmid: 20357295].
81 Arnold LM, Palmer RH, Gendreau RM, et al. Relationships among pain, depressed mood, and global status in fibromyalgia patients: post hoc analyses of a randomized, placebo-controlled trial of milnacipran. Psychosomatics. Jul-Aug. 2012;53(4):371-9. [pmid: 22677218].
82 Younger J, Mackey S. Fibromyalgia symptoms are reduced by low-dose naltrexone: a pilot study. Pain Med. May-Jun. 2009;10(4):663-72. [pmid: 19453963].
83 Drexler AR, Mur EJ, Gunther VC. Efficacy of an EMG-biofeedback therapy in fibromyalgia patients. A comparative study of patients with and without abnormality in (MMPI) psychological scales. Clin Exp Rheumatol. Sep/Oct. 2002;20(5):677-82. [pmid: 12412199].
84 Joshi MN, Joshi R, Jain AP. Effect of amitriptyline vs. physiotherapy in management of fibromyalgia syndrome: what predicts a clinical benefit?. J Postgrad Med. Jul-Sep. 2009;55(3):185-9. [pmid: 19884743].
85 Gendreau RM, Thorn MD, Gendreau JF, et al. Efficacy of milnacipran in patients with fibromyalgia. J Rheumatol. Oct. 2005;32(10):1975-85. [pmid: 16206355].
86 Arnold LM, Hess EV, Hudson JI, et al. A randomized, placebo-controlled, double-blind, flexible-dose study of fluoxetine in the treatment of women with fibromyalgia. Am J Med. Feb. 15. 2002;112(3):191-7. [pmid: 11893345].
87 Junghaenel DU, Schwartz JE, Broderick JE. Differential efficacy of written emotional disclosure for subgroups of fibromyalgia patients. Br J Health Psychol. Feb. 2008;13(Pt 1):57-60. [pmid: 18230233].
88 Lera S, Gelman SM, Lopez MJ, et al. Multidisciplinary treatment of fibromyalgia: does cognitive behavior therapy increase the response to treatment?. J Psychosom Res. Nov. 2009;67(5):433-41. [pmid: 19837206].
89 Chappell AS, Bradley LA, Wiltse C, et al. A six-month double-blind, placebo-controlled, randomized clinical trial of duloxetine for the treatment of fibromyalgia. Int J Gen Med. 2008;1:91-102. [pmid: 20428412].
90 Stening KD, Eriksson O, Henriksson KG, et al. Hormonal replacement therapy does not affect self-estimated pain or experimental pain responses in post-menopausal women suffering from fibromyalgia: a double-blind, randomized, placebo-controlled trial. Rheumatology (Oxford). Mar. 2011;50(3):544-51. [pmid: 21078629].
91 Sadreddini S, Molaeefard M, Noshad H, et al. Efficacy of Raloxifen in treatment of fibromyalgia in menopausal women. Eur J Intern Med. Jul. 2008;19(5):350-5. [pmid: 18549938].
92 Assis MR, Silva LE, Alves AM, et al. A randomized controlled trial of deep water running: clinical effectiveness of aquatic exercise to treat fibromyalgia. Arthritis Rheum. Feb. 15. 2006;55(1):57-65. [pmid: 16463414].
93 Hakkinen K, Pakarinen A, Hannonen P, et al. Effects of strength training on muscle strength, cross-sectional area, maximal electromyographic activity, and serum hormones in premenopausal women with fibromyalgia. J Rheumatol. Jun. 2002;29(6):1287-95. [pmid: 12064848].
94 Valkeinen H, Alen M, Hakkinen A, et al. Effects of concurrent strength and endurance training on physical fitness and symptoms in postmenopausal women with fibromyalgia: a randomized controlled trial. Arch Phys Med Rehabil. Sep. 2008;89(9):1660-6. [pmid: 18675392].
95 Edinger JD, Wohlgemuth WK, Krystal AD, et al. Behavioral insomnia therapy for fibromyalgia patients: a randomized clinical trial. Arch Intern Med. Nov. 28. 2005;165(21):2527-35. [pmid: 16314551].
96 Scheidt CE, Waller E, Endorf K, et al. Is brief psychodynamic psychotherapy in primary fibromyalgia syndrome with concurrent depression an effective treatment? A randomized controlled trial. Gen Hosp Psychiatry. Mar-Apr. 2013;35(2):160-7. [pmid: 23218844].
97 Fontaine KR, Conn L, Clauw DJ. Effects of lifestyle physical activity on perceived symptoms and physical function in adults with fibromyalgia: results of a randomized trial. Arthritis Res Ther. 2010;12(2):R55. [pmid: 20353551].
98 Gavi MBRO, Vassalo DV, Amaral FT, et al. Strengthening exercises improve symptoms and quality of life but do not change autonomic modulation in fibromyalgia: a randomized clinical trial. PLoS ONE. 20. Mar. 2014;9(3). [pmid: 24651512].
99 Martinez M, Miro E, Sanchez AI, et al. Cognitive-behavioral therapy for insomnia and sleep hygiene in fibromyalgia: A randomized controlled trial. J Behav Med. Aug. 2014;37(4):683-97. [pmid: 23744045].
100 Hakkinen A, Hakkinen K, Hannonen P, et al. Strength training induced adaptations in neuromuscular function of premenopausal women with fibromyalgia: comparison with healthy women. Ann Rheum Dis. Jan. 2001;60(1):21-6. [pmid: 11114277].
101 Mease PJ, Spaeth M, Clauw DJ, et al. Estimation of minimum clinically important difference for pain in fibromyalgia. Arthritis Care Res. Jun. 2011;63(6):821-6. [pmid: 21312349].
102 Gore M, Tai KS, Chandran A, et al. Clinical comorbidities, treatment patterns, and healthcare costs among patients with fibromyalgia newly prescribed pregabalin or duloxetine in usual care. J Med Econ. 2012;15(1):19-31. [pmid: 21970699].
103 Koroschetz J, Rehm SE, Gockel U, et al. Fibromyalgia and neuropathic pain--differences and similarities. A comparison of 3057 patients with diabetic painful neuropathy and fibromyalgia. BMC Neurol. 2011;11:55. [pmid: 21612589].
104 Berger A, Dukes E, Martin S, et al. Characteristics and healthcare costs of patients with fibromyalgia syndrome. International Journal of Clinical Practice. Sep. 2007;61(9):1498-508. [pmid: 17655684].
105 Boulanger L, Wu N, Chen SY, et al. Predictors of pain medication selection among patients diagnosed with fibromyalgia. Pain pract. Apr. 2012;12(4):266-75. [pmid: 21899718].
106 Kasenda B, Schandelmaier S, Sun X, et al. Subgroup analyses in randomised controlled trials: cohort study on trial protocols and journal publications. BMJ. 2014;349:g4539. [pmid: 25030633].
107 Lachaine J, Beauchemin C, Landry PA. Clinical and economic characteristics of patients with fibromyalgia syndrome. Clin J Pain. May. 2010;26(4):284-90. [pmid: 20393262].