# Introduction

## Background

Fibromyalgia is a chronic, diffuse musculoskeletal pain syndrome that has no clearly identified etiology.1-4 It affects mostly adults5 and is characterized by chronic widespread pain, abnormal processing of and heightened sensitivity to pain, chronic fatigue, sleep disorders, and emotional distress or depression.5,6 Fibromyalgia reduces quality of life and productivity and is associated with functional disability, lost work time, and increased use of health care services.5,7-9 Based on diagnostic criteria developed in 1990 by the American College of Rheumatology (ACR), fibromyalgia affects more than 5 million Americans,10 most of whom are middle-aged women; men are less likely to be diagnosed with fibromyalgia even if they meet diagnostic criteria (3.4% women vs. 0.5% men).1,10,11

Although fibromyalgia can occur in children, diagnosis is typically made in middle age, and prevalence increases with age until age 65, then declines in women.5,12

## Diagnosis

The diagnostic criteria for fibromyalgia have evolved13,14 since the first publication by the ACR in 1990. The original criteria included palpation of myofascial “tender points” during physical examination and the presence of widespread pain for at least 3 months.15 In 2010 the ACR eliminated the tender point examination and added (1) physician-rated severity in two scales, the Widespread Pain Index and the Symptom Severity Scale, and (2) a requirement of symptoms for at least 3 months and the absence of another disorder that would account for the symptoms.13,16 A survey version of the 2010 ACR criteria was also released for research purposes in 2011; it replaced physician estimates of somatic symptom severity with a patient-generated summary score derived from three self-reported symptom domains.14 Compared with the 1990 criteria, the 2010 ACR preliminary diagnostic criteria capture a broader population of fibromyalgia patients, which affects prevalence estimates and patient heterogeneity in more recent studies.16-18 Alternative diagnostic criteria are under consideration.19

## Treatment Strategies

Treatments for fibromyalgia syndrome include drugs and nonpharmacologic therapies to help mitigate symptoms and improve function.5 Treatment goals are to mitigate diffuse musculoskeletal pain, maximize physical and cognitive function, optimize patient self-management and self-efficacy, and manage comorbid medical and psychiatric disorders. Treatment components may include pharmaceutical therapy, exercise programs, cognitive behavioral therapy, patient education (self-management, sleep hygiene, importance of exercise, etc.), and the treatment of comorbid medical and mental health conditions.5,20 Complementary and alternative medicine (CAM) approaches such as acupuncture and massage are also common.20,21 Large-scale fibromyalgia clinics typically use multimodal treatment approaches, although many patients still receive uncoordinated care by seeking treatment from individual health care providers across multiple clinical settings.

### Pharmacologic Treatments

Pharmacologic interventions include both Food and Drug Administration (FDA) approved medications specifically for the treatment of fibromyalgia and other FDA approved drugs not specifically approved for the management of fibromyalgia symptoms in the United States.

#### FDA-Approved Drugs for Fibromyalgia

Three oral medications have been FDA approved for fibromyalgia since 2007: duloxetine and milnacipran (serotonin-norepinephrine reuptake inhibitors [SNRIs]) and pregabalin (a gamma-aminobutyric acid agonist).

Pregabalin was the first FDA approved medication for fibromyalgia. Antiepileptic drugs, such as pregabalin, are commonly used to treat neuropathic pain.22 Although its exact mechanism of action is unknown, pregabalin acts on neurons and results in analgesic, anxiolytic, and antiepileptic effects in animal studies.22

Newer SNRIs, such as duloxetine and milnacipran, differ from selective serotonin reuptake inhibitors (SSRIs) because of their reuptake inhibition of both norepinephrine and serotonin neurotransmitters.23 SNRIs were designed to have superior efficacy in treating depression than SSRIs, and with fewer side effects than tricyclic antidepressants,22 but evidence for this claim is not persuasive.24 Duloxetine was the first SNRI that demonstrated efficacy for reducing pain in patients with fibromyalgia, although the exact mechanism of action on the perception of pain is unknown. Milnacipran was approved after demonstrating efficacy in concurrent improvements in pain, physical function, and global impression of disease. Additional information about these medications is listed in Table 1.

Table 1 FDA-approved drugs for the treatment of fibromyalgia

Trade Name | Generic Name | Manufacturer | Therapeutic Drug Class | Drug Subclass | Year FDA Approved
Lyrica | Pregabalin | Pfizer Inc. | Antiepileptics | Gamma-aminobutyric acid agonist | 2007
Cymbalta | Duloxetine HCL | Eli Lilly and Co. | Antidepressants | SNRI | 2008
Savella | Milnacipran | Forest Labs/Cypress Bioscience, Inc. | Antidepressants | SNRI | 2009

Abbreviation: SNRI = serotonin and norepinephrine reuptake inhibitors.

#### Off-Label Use of FDA-Approved Drugs

Numerous drugs that are approved for other conditions are currently used off-label in patients with fibromyalgia, such as antidepressants, analgesics, opioid analgesics, anti-inflammatories, and skeletal muscle relaxants. A table of pharmacologic agents that are used off-label for the treatment of fibromyalgia in the United States is in Appendix A.

### Nonpharmacologic Treatments for Fibromyalgia

A wide array of nondrug treatments is used to manage pain and other symptoms associated with fibromyalgia, often in combination. Treatment goals are to reduce pain, improve physical function and endurance, and foster self-efficacy in fibromyalgia management, both short and long-term. Common therapies are listed in Table 2.

Table 2 Nonpharmacologic treatments for fibromyalgia

Type | Category | Examples
Psychological | Cognitive behavioral therapy | Cognitive behavioral therapy sessions
Psychological | Other cognitive | Mindfulness training
Physical | Passive | Massage therapy, acupuncture, chiropractic; modalities (such as ultrasound, heat, electrical muscle stimulation, etc.); other (such as magnets)
Physical | Active | Supervised or independent exercise (such as aerobic, strength training, stretching, water/pool-based, yoga)
Physical | Multimodal physical | Combinations of active and/or passive physical interventions
Multicomponent | Various | Combinations of multiple intervention categories (such as pharmacologic + psychological + physical interventions simultaneously or in coordination)
Lifestyle modifications | Independent or with education, advice or support | Weight loss, dietary changes (such as vegetarian or gluten-free), smoking cessation, sleep habit improvement, etc.
Other therapies | Mind-body therapies | Meditation, hypnosis, tai chi, visualization
Other therapies | Nutraceuticals | S-adenosyl-methionine (SAMe), coenzyme Q10, omega-3 fatty acids, algae
Other therapies | Other | Transcranial direct current stimulation

Abbreviation: SAMe = S-adenosyl-methionine

### Rationale for Review

Many clinical trials suggest a modest benefit from treatments for a general population of fibromyalgia patients.1,20 Although clinicians believe that treatment effectiveness may vary in subgroups,25-27 less is known about the efficacy and comparative effectiveness of these treatments for subgroups of adults (defined by number and type of coexisting syndromes or conditions, severity of pain or impairment at baseline,13 presence of a mood or other mental health disorder, primary complaint at baseline, or demographic or other related factors). Understanding subgroup treatment effects might help to inform clinical decisions. For example, moderate to severe depression affects 20 to 40 percent of fibromyalgia patients in clinical trials,3,27-29 and approximately 10 percent have anxiety disorders.30

This systematic review provides information for both patients and providers on treatment outcomes in fibromyalgia subgroups; such patients typically present with multiple, chronic symptoms and/or conditions and pose significant treatment dilemmas for providers.

### Selection of Patient Subgroups

Certain subgroups of patients have a higher prevalence of fibromyalgia, are more clinically complex or challenging to treat, and/or have historically unsatisfactory treatment outcomes.10,31 The patient subgroups were chosen a priori from the literature and with input from experts and other stakeholders, including: women,32-36 older37,38 or obese39 adults, individuals with coexisting mental health conditions,5,10,29,40,41 those with high severity41-44 or longer fibromyalgia duration,45 multiple medical comorbidities,5,45,46 or other chronic pain conditions.5,10,20,29,47

- Women: Population-based prevalence estimates of fibromyalgia in women are two to seven times higher than those of males.11,48 Women comprise the majority of fibromyalgia patients seen in clinical practice49 and many studies were conducted exclusively in women. Women with fibromyalgia tend to have higher tender point counts, lower pain thresholds (per dolorimeter), and report more fibromyalgia symptoms (such as all-over pain, sleep disturbance, fatigue, and irritable bowel syndrome) than men.50 Recent studies also identified differences by sex in depression, somatic symptoms, modes of treatment used, and patterns of health care service use.32-36 More information is needed about how outcomes differ between men and women for the same modes and intensities of treatment and which treatment modes best benefit men or women.
- Individuals with coexisting mental health conditions: Coexisting mental health disorders are particularly common in fibromyalgia patients, especially depression and/or anxiety (which occurs in more than one-third of fibromyalgia patients) and substance abuse.5,10,29,40 Traumatic or stressful events and post-traumatic stress disorder may trigger or exacerbate fibromyalgia.5,51 Simultaneous treatment of co-occurring mental health disorders has been advised, especially in severe cases.41
- Individuals with high fibromyalgia symptom severity (Fibromyalgia Impact Questionnaire (FIQ) 59-100):42 Patients with high FIQ scores report greater functional limitations, higher overall impairment, and more severe symptoms; typical treatments may be less effective43 or not feasible and may require adaptation to severity.41,44 These highly-affected individuals present special treatment and management challenges for providers.
- Older adults: Older adults may have higher comorbidity burden, functional limitations, or altered renal clearance that require treatment modifications compared with middle-aged adults. More frequent and more severe medical comorbidities in older adults may increase the likelihood of adverse effects, drug interactions, and altered drug tolerance from pharmaceutical therapies for fibromyalgia, increasing the risk for falls, fractures, and other injuries from standard treatments. Recent information shows less impact of fibromyalgia on health-related quality of life (HRQoL) in older women37 and less fibromyalgia symptomatology in older adults compared with middle-age adults.38 However, feasible modes of treatment and outcomes may vary in this subgroup.
- Obese adults: Obese adults with fibromyalgia report greater fibromyalgia symptoms (pain, stiffness, depression) and poorer physical function39 and may have differential treatment responses compared with nonobese adults with fibromyalgia.52,53 High rates of obesity (45 percent) and overweight (27 percent) are reported in patients with fibromyalgia, and severe obesity is particularly associated with greater fibromyalgia symptoms and lower quality of life.39
- Individuals with multiple medical comorbidities:45
  ○ Concurrent rheumatic disease: rheumatoid arthritis (RA), lupus (SLE), ankylosing spondylitis (AS), etc., including osteoarthritis (OA). At least one-third of patients with rheumatic conditions also have fibromyalgia.5,46
  ○ Other comorbidities
- Persons with other significant chronic pain conditions: The presence of other somatic syndromes with fibromyalgia complicates treatment and compromises outcomes.47
  ○ Migraine or tension headaches affect up to than half of patients.5,10,29
  ○ Somatic syndromes (e.g., irritable bowel syndrome, chronic fatigue syndrome, temporomandibular joint dysfunction, low back pain, and others) are associated with fibromyalgia.5,20
- Individuals with longer duration of fibromyalgia symptoms: Longer duration of symptoms is associated with poorer outcomes. Initial assessment values are predictive of longer-term outcomes in fibromyalgia patients seen in rheumatology centers.45

## Scope and Key Questions

### Scope of the Review

This systematic review examined whether specific subgroups would benefit from being treated differently from the general fibromyalgia patient population.

Unlike most systematic reviews that compare average treatment effects for average patients with a specific condition, the goal of this report is to provide summary information on the evidence to date to support patient and provider treatment choices when comorbid or complex clinical situations are present in adults with fibromyalgia. The subgroups, chosen a priori, reflect medically and/or psychologically complex patients or those who reported greater impairment or less responsiveness to treatments. Additional subgroups were included as found in the literature.

We limited this systematic review to subgroup treatment effects because McMaster University in Canada is currently conducting a comprehensive systematic review of randomized controlled trials (RCTs) on interventions for fibromyalgia in adults.54 Our systematic review complements the McMaster work by examining outcomes in fibromyalgia patient subgroups and by including observational literature.

Because fibromyalgia is largely a chronic condition in adults, we limited our analysis to studies of individuals age 18 or older that compared treatments for fibromyalgia in subgroups of adults and reported outcomes at least 3 months after treatment initiation.

### Key Questions

The following two Key Questions were the focus of this systematic review:

#### Key Question 1 (KQ 1) What are the efficacy and comparative effectiveness of treatments for fibromyalgia in specific adult subpopulations?

- Women
- Individuals with coexisting mental health conditions
- Individuals with high fibromyalgia symptom severity (FIQ 59-100)
- Older adults
- Obese adults
- Persons with multiple medical comorbidities
  ○ Concurrent rheumatic disease: rheumatoid arthritis (RA), lupus (SLE), ankylosing spondylitis (AS) etc., including osteoarthritis (OA)
  ○ Other comorbidities
- Individuals with other significant chronic pain conditions (low back pain, headache, irritable bowel syndrome (IBS), etc.)
- Individuals with longer duration of fibromyalgia symptoms

#### Key Question 2 (KQ 2) What are the harms of treatments for fibromyalgia in specific adult subpopulations?

- Women
- Individuals with coexisting mental health conditions
- Individuals with high fibromyalgia symptom severity (FIQ 59-100)
- Older adults
- Obese adults
- Individuals with multiple medical comorbidities
  ○ Concurrent rheumatic disease: rheumatoid arthritis (RA), lupus (SLE), ankylosing spondylitis (AS) etc., including osteoarthritis (OA)
  ○ Other comorbidities
- Individuals with other significant chronic pain conditions (low back pain, headache, irritable bowel syndrome (IBS), etc.)
- Individuals with longer duration of fibromyalgia symptoms

Components of the PICOTS framework to answer the Key Questions on fibromyalgia for this review are described in Table 3.

Table 3 PICOTS framework

PICOTS Element | Inclusion Criteria
Population | Adults (age 18 and older) with fibromyalgia in studies that tested the effectiveness of treatments for fibromyalgia and reported outcomes in at least one of the adult subgroups of interest: sex differences, patients with high symptom severity (e.g., Fibromyalgia Impact Questionnaire (FIQ) scores ≥59 (severe) or severe on a related scale); patients with coexisting mental health disorders; older adults (age 65 or older), obese adults (body mass index [BMI] of 30 or higher or similar classification), patients with multiple medical comorbidities (rheumatic diseases/osteoarthritis, other), with other chronic pain conditions, or patients with longer duration of fibromyalgia symptoms (such as 1 year or more). Patients met either the 1990^15^ or 2010^13^ revised fibromyalgia diagnostic criteria from the American College of Rheumatology (ACR), or the Yunus criteria for fibrositis55 for studies published from 1985-1990. Additional subgroups were included as found in the literature.
Interventions | Pharmacologic treatments that are or were FDA approved for use in the U.S. for fibromyalgia or other conditions (off-label use for fibromyalgia) were included. Nonpharmacologic interventions that are or were available for use in the U.S. were included.
Comparators | Placebo, sham, alternate dose or dosing regimen, or any active pharmacologic or nonpharmacologic treatment available for use in the U.S.
Outcomes | KQ 1: Change from baseline in any measures used to assess the status in fibromyalgia patients regarding:; - Overall pain (such as a Visual Analog Scale [VAS],56 Brief Pain Inventory,57 or the McGill Pain Questionnaire58); - Symptom improvement (such as the Fibromyalgia Impact Questionnaire [FIQ],59 Revised FIQ [FIQR],60 Patient Global Impression of Change [PGI-C],61 or Patient Global Impression of Improvement [PGI-I]61); - Physical and/or emotional function (such as the FIQ, FIQR subscales); - Participation in work or social activities (such as the FIQ, FIQR subscales42,62); - Health-related quality of life [HRQoL] (such as the SF-36^63^); - Fatigue (such as the Multidimensional Assessment of Fatigue [MAF]64); - Sleep quality (such as the Medical Outcomes Study [MOS] Sleep Scale65); KQ 2: Adverse effects or harms of intervention(s); - Drug-related side effects (such as dizziness, nausea, fatigue, dry mouth, weight gain, difficulty concentrating, hypertension, thoughts of suicide, peripheral edema, anxiety, tachycardia, constipation, etc.); - Adverse effects from nonpharmaceutical treatments (such as muscle aches, minor injuries or falls during or after exercise; soreness or aches from passive physical treatments such as massage, etc.)
Timing | A minimum of 3 months followup on interventions of any length. Since fibromyalgia is a chronic condition, outcomes improvements over time are more salient to patients and providers than temporary treatment effects.
Setting | Any outpatient setting

Abbreviations: ACR=American College of Rheumatology; BMI=body mass index; FIQ=Fibromyalgia Impact Questionnaire; FIQR=Revised Fibromyalgia Impact Questionnaire; HRQoL=health-related quality of life; MAF=Multidimensional Assessment of Fatigue; MOS=Medical Outcomes Study; PGI-C=Patient Global Impression of Change; PGI-I=Patient Global Impression of Improvement; VAS=Visual Analog Scale.

## Analytic Framework

Figure 1 depicts the two Key Questions within the context of the PICOTS described in Table 3. The figure illustrates how the use of pharmacologic, nonpharmacologic, or multimodal treatments for fibromyalgia may improve outcomes for adults with fibromyalgia. The patients for this study are subgroups of individuals with fibromyalgia who are identified by at least one of the following characteristics: sex, coexisting mental health disorders, high symptom severity, older age, obesity, multiple medical comorbidities, other chronic pain conditions, or longer duration of fibromyalgia symptoms. The Key Question 1 outcome categories include overall pain, symptom improvement, function, participation (work or social), health-related quality of life (HRQoL), fatigue, and sleep quality. Adverse effects of drugs or interventions may also occur at any point after the treatment is initiated; these will be examined in Key Question 2.

Figure 1 Analytic framework for treatments for fibromyalgia in adult subgroups

Note: KQ = Key Question

Figure 1: Analytic Framework Figure 1 depicts the two key questions within the context of the PICOTS described in Table 3. The figure illustrates how the use of pharmacologic, nonpharmacologic, or multimodal treatments for fibromyalgia may improve outcomes for adults with fibromyalgia. The patients for this study are subgroups of individuals with fibromyalgia who are identified by at least one of the following characteristics: sex, coexisting mental health disorders, high symptom severity, older age, obesity, multiple medical comorbidities, other chronic pain conditions, or longer duration of fibromyalgia symptoms. The Key Question 1 outcome categories include overall pain, symptom improvement, function, participation (work or social), health-related quality of life (HRQoL), fatigue, and sleep quality. Adverse effects of drugs or interventions may also occur at any point after the treatment is initiated; these will be examined in Key Question 2.