# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Jason Busse, D.C., Ph.D.
  McMaster University
  Hamilton, ON, Canada
- Roger Chou, M.D.
  Oregon Health & Science University
  Portland, OR
- Edward C. Covington, M.D.
  Cleveland Clinic
  Cleveland, OH
- Don L. Goldenberg, M.D.
  Tufts University School of Medicine
  Newton, MA
- Kim Dupree Jones, R.N.C., Ph.D., FNP
  Oregon Health & Science University
  Portland, OR
- Robert D. Kerns, Ph.D.
  VA Connecticut Healthcare System
  Yale University
  West Haven, CT
- Akiko Okifuji, Ph.D.
  University of Utah
  Salt Lake City, UT
- Linda M. Torma, Ph.D., A.P.R.N.,
  G.C.N.S.-B.C.
  Montana State University
  Bozeman, MT