# Acknowledgments

The authors wish to thank Uzoma Abakporo and Nathan Carter, who served as research assistants on this project, and Marilyn Eells and Jeannine Ouellette for their assistance in editing the report.