# Discussion

## Key Findings and Strength of Evidence

Despite the clinical belief that the treatment effects for fibromyalgia may vary in adult subgroups,25-27 there is little information to support this hypothesis. Evidence is largely insufficient to determine subgroup effects, with the exception of the drug duloxetine. We were unable to conduct a meta-analysis because relatively few studies examined subgroups as well as the variety of subgroup-treatment-outcome combinations we encountered.

Table 12 summarizes the major findings and associated strength of evidence for subgroup analyses with at least two studies. All but one comparison for which we could assign strength of evidence involved duloxetine.

Table 12 Key Question 1: Benefits of treatment—summary and strength of evidence of effectiveness and comparative effectiveness of treatments for fibromyalgia in adult subgroups^*^

Population (FM subgroup) | Intervention vs. Placebo | Outcome: Change from Baseline | Conclusion | Number of Studies | Strength of Evidence
With major depressive disorder (MDD)/depression | Duloxetine | Brief Pain Inventory (BPI) average pain severity score | No evidence that treatment effects differ in subgroup | 6: 5 RCTs; 1 pooled analysis^**^ | Low (high risk of bias/many study limitations; consistent direction of effect)
With major depressive disorder (MDD)/depression | Duloxetine | Patient Global Impression of Improvement (PGI-I) | No evidence that treatment effects differ in subgroup | 3: 2 RCTs; 1 pooled analysis^**^ | Low (high risk of bias/many study limitations; consistent direction of effect)
With major depressive disorder (MDD)/depression | Duloxetine | Fibromyalgia Impact Questionnaire (FIQ) total score | No evidence that treatment effects differ in subgroup | 2: 1 RCT; 1 pooled analysis^**^ | Low (high risk of bias/many study limitations)
With major depressive disorder (MDD)/depression | Duloxetine | Hamilton Rating Scale for Depression (HAMD) | Unable to determine (impact of duloxetine on HAMD in adults with MDD and FM) | 2: 1 RCT; 1 pooled analysis^**^ | Insufficient (pooled interaction NS; RCT within stratum only)
With major depressive disorder (MDD)/depression | Milnacipran | Visual Analog Scale (VAS) for pain | Unable to determine (whether milnacipran effects on VAS pain differ in adults with MDD and FM) | 2: 1 RCT (NR), 1 post hoc RCT analysis | Insufficient (outcomes reporting issues: 1 indirect, 1 incomplete)
Age | Duloxetine | BPI average pain severity score | No evidence that treatment effects differ in subgroup | 3 RCTs | Low (high risk of bias/many study limitations)
Age | Duloxetine | PGI-I | No evidence that treatment effects differ in subgroup | 2 RCTs | Low (high risk of bias/many study limitations)
Sex | Duloxetine | BPI average pain severity score | Weak evidence that treatment effects may differ in subgroup (3 NS; in 1 study females improved more than males) | 4 RCTs | Insufficient (high risk of bias/many study limitations, inconsistent)
Sex | Duloxetine | PGI-I | No evidence that treatment effects differ in subgroup | 2 RCTs | Low (high risk of bias/many study limitations)
Race | Duloxetine | BPI average pain severity score | Weak evidence that treatment effects may differ in subgroup (2 NS; in 1 study nonwhites improved more than whites) | 3 RCTs | Insufficient (high risk of bias/many study limitations, inconsistent)
Race | Duloxetine | PGI-I | No evidence that treatment effects differ in subgroup | 2 RCTs | Low (high risk of bias/many study limitations)

Abbreviations: F = female; FM = fibromyalgia; HAMD = Hamilton Rating Scale for Depression; M = male; MDD = major depressive disorder; NR = not reported; NS = not significant; NW = nonwhite; RCT = randomized controlled trial; W = white

* Table shows strength of evidence for subgroup-treatment-outcomes combinations with at least two relevant studies. Other comparisons that had insufficient evidence (addressed by single studies that had high risk of bias and small sample sizes) are not shown.

** Arnold 2009^25^ is a pooled analysis of patient-level data from four RCTs that are also included in this report. Rationale for the inclusion of non-overlapping information from these studies is provided in the Discussion and Appendix Table E17.

Limited, low-strength evidence, mostly for duloxetine effects on pain in adults with fibromyalgia and major depressive disorder, suggests that treatment effects do not differ in this subgroup. Sparse, low-strength evidence suggests that duloxetine effects on global improvement (PGI-I) and fibromyalgia impact (FIQ) do not differ in the MDD patient subgroup. Evidence was insufficient regarding duloxetine effects on depression (HAMD) and milnacipran effects on VAS pain scores for adults with MDD and fibromyalgia.

Low-strength, limited RCT evidence for duloxetine effects by age (on BPI average pain and PGI-I), sex (on PGI-I) and race (on PGI-I) suggest that treatment effects do not differ in these subgroups.

For all other subgroup-treatment-outcome comparisons, evidence was insufficient to draw conclusions about subgroup treatment effects.

Few studies have examined subgroup treatment outcomes in fibromyalgia. We found little evidence to inform treatment decisions for adults with fibromyalgia and nondepression psychological or medical comorbidities, as these individuals were often excluded from clinical trials. Uniformly excluded were those with rheumatologic conditions, serious medical conditions, and psychological disorders other than depression or anxiety. Little information was reported on individuals over age 55, and extensive medical exclusion criteria likely impacted the participation of older individuals in clinical trials.

Clinicians and patients are thus left with little to guide their treatment decisions. Multimorbid fibromyalgia patients are the clinical reality.40,76,79,102-105 Yet, clinical trial results from restricted patient samples offer little information to assist in clinical decisionmaking when multiple comorbid conditions are present. Although the prevalence of single subgroup membership is estimated for some individual conditions (such as depression), the prevalence of subgroups with simultaneous (multiple) comorbid conditions within this population is incompletely identified.

In general, overall treatment effects were small and even less when substantial placebo-group improvements were considered relative to treatment effects. Subgroup effects paralleled the magnitude and direction of overall treatment and placebo effects in mixed-sample studies. Reporting of overall interaction results, or assessment for differential treatment effects based on subgroup membership, was inconsistent across and within studies, and most interaction results were reported in text only.

The fibromyalgia subgroup outcomes evidence is overwhelmingly pharmaceutical and all but one comparison for which we could assign strength of evidence involved duloxetine. Drug trials were based on the most highly selective sampling criteria of all the studies we reviewed. The pharmaceutical industry was heavily involved in all study aspects, including funding, study management, data analysis, and results reporting. It was common to find the corresponding and other authors located in industry (Appendix Tables E13-E17). Nonsignificant subgroup effects in drug studies were often difficult to find and sometimes indeterminable within selective article text. When subgroup interactions were assessed, data tables often presented p-values for individual comparisons within strata, rather than overall negative subgroup interaction results.

In general, sample selection criteria were restrictive, and the extent to which such select patient samples reflect average patients in subgroups of adults with fibromyalgia is unknown. Despite this careful patient selection, attrition by 3-month followup was high (25 to 40 percent in most studies; range 4 percent to 47 percent). Dropouts were typically reported only in aggregate; the effects of attrition on initially small subgroup or treatment group sample sizes were usually indeterminable. All but one study used the 1990 ACR preliminary diagnostic criteria for fibromyalgia.

Adverse effects were rarely reported for subgroups and appear not to differ within them.

Subgroup samples were small except in pooled drug RCT analyses. However, drug studies, including pooled analyses, routinely reported only baseline enrollment sample sizes; the tables and text did not account for attrition. Other common methodological limitations were insufficient power to detect subgroup effects and lack of correction for multiple outcomes testing. Also, it was often not possible to determine whether or not subgroups were decided a priori or post hoc (Appendix tables E4-E7).

## Applicability and Limitations of the Evidence Base

Several important characteristics limit the generalizability and applicability of these review results.

Study patients were largely middle-aged white females with moderate to severe fibromyalgia symptoms at baseline as measured by the FIQ, which is generally representative of the fibromyalgia patient population seen in clinical practice in the United States.11,102 Few men were included in clinical trials. Sample selection criteria were most restrictive for pharmaceutical studies so that adults with mental health conditions other than depression or anxiety, or those with higher medical comorbidity burden, were excluded.

Subgroup outcomes evidence is mostly pharmaceutical, especially for duloxetine. Fewer studies assessed the effects of physical interventions (such as exercise or weight loss), psychological interventions (such as CBT, psychotherapy, or biofeedback), and very few assessed combination treatments.

Most drug trials were placebo-controlled RCTs. Other comparators included standard care, standard care plus adjunctive therapy, normal activities or education and information sessions.

We included four RCTs of duloxetine that are contained in three pooled IPD RCT analyses that are also included in this review. Appendix Table E17 shows differentiating study features that allowed inclusion of this literature set in our review. On careful examination, differences in outcomes timing, drug dosages (single dose vs. aggregated doses for pooled analysis), outcome measures, and an omitted treatment group in the pooled analyses were sufficient to include the four RCTs and three pooled analyses in the review.

Several issues affect the subgroup outcomes reported in this review. Outcomes are overwhelmingly reported for short-term outcomes despite that long term outcomes are of greatest interest in the management of chronic fibromyalgia syndrome. Reporting issues were particularly prominent in drug studies. The effect of attrition within subgroups was missing so the extent to which studies could detect a difference even if one existed was not determinable, particularly since power calculations, when reported, were conducted to detect main not subgroup effects. Pooled analyses failed to acknowledge that unacceptably high attrition during input RCTs greatly diminished the reported amount of pooled patient data available for short-term analysis (more than 40 percent in some cases, see Appendix table E17). The text on the magnitude of drug treatment effects for specific outcomes rarely acknowledged placebo group improvements that would have better contextualized the magnitude of treatment benefits had the difference been directly reported. We noted inconsistencies within and across studies in which subgroup interaction effects were reported, even when methods sections identified that subgroup-treatment interactions were assessed. Selective reporting of subgroup outcomes was most often noted in results tables where individual within-stratum comparisons were identified, but the overall interaction term was either not reported or reported only in text that was distant from the table.

Additionally, statistical corrections for multiple comparisons were either not conducted or not reported in most studies, raising the chance that significant differences in outcomes across groups, if present, may have been detected by chance alone. Although numerous outcomes measures were utilized, which impeded our ability to aggregate across studies, the range of outcomes assessed was not particularly broad. Multiple measures for pain were used. Pain, perceptions of global improvement, and changes in the overall impact of fibromyalgia were most commonly reported; physical and social functioning were infrequently reported. Finally, industry funding and study involvement were considerable across all aspects of pharmaceutical trials, including manuscript construction. Careful consideration for potential reporting biases cannot be overlooked in the context of outcomes interpretation from the included drug trials.

Given this contextual information, the extent to which the fibromyalgia subgroup literature from clinical studies to date reflects the breadth and severity of the broader population of adult subgroups with fibromyalgia is unknown. Patients with both fibromyalgia and multiple physical and/or mental health comorbidities were most often excluded, which limits the applicability of these findings.

## Limitations of the Comparative Effectiveness Review Process

This review’s focus on subgroups required us to modify the systematic review processes used to assess overall benefits and harms of treatments in average adults. In assessing risk of bias, we assessed typical risk of bias domains for RCTs and added subgroup questions that were supported by the literature, which reflected common sense statistical practices for subgroup evaluation. We created a quality assessment form for observational studies and added similar subgroup items. We created quality assessment forms for pooled RCT IPD analyses that included quality assessments of the methods and reporting used for the summary analysis, and risk of bias assessments of the individual input RCTs. Although risk of bias/study quality assessment is inherently subjective, we tried to evaluate quality as objectively as possible using pre-specified forms that were uniformly used and rated by two reviewers.

In assessing subgroup pre-specification for included studies, we relied on information in each article, which may overstate the actual number of subgroups that were determined a priori in randomized controlled trials.106

This review was limited to English-language publications. The possibility of missing clinical trials with subgroup reporting with this restriction for treatments that were FDA approved and/or available in the United States is remote, especially for conventional medical therapies.68-70

We did not find evidence on all a priori subgroups, such as individuals with higher severity or longer duration of fibromyalgia, or rheumatologic conditions. Fibromyalgia duration and especially baseline severity as assessed with the FIQ were often part of the sample selection criteria for clinical trials, thereby excluding individuals with mild symptoms or impairment and/or shorter syndrome duration. Adults with rheumatologic conditions were routinely excluded.

## Research Gaps

Many of the subgroups identified by experts as clinically important were never investigated or were studied for only a few therapies. For the few studies that have examined subgroups, the strength of evidence was low or insufficient, suggesting that future studies with higher quality could change the conclusions of this review.

There is a clear need for more evidence for interventions other than duloxetine, and for adults with fibromyalgia and multiple comorbid conditions. Information on patients with concurrent pain conditions is particularly lacking. For example, fibromyalgia patients with conditions such as headache, gastroesophageal reflux disease, irritable bowel syndrome, back pain, and/or osteoarthritis,4,28,102,105,107 may require treatment modifications or mixed treatment approaches, which could not be determined from the literature to date. Also, individuals with comorbid mental health conditions, other than depression or anxiety, and/or those with higher medical comorbidity burden, have been excluded from most clinical trials, especially drug trials. The extent to which such multimorbidity affects treatment needs, feasible treatment options and adverse effects requires further investigation to provide useful treatment information on multimorbid adults. Individuals with comorbid rheumatologic and other autoimmune disorders are virtually missing from the general fibromyalgia treatment outcomes literature, and may require varied treatment approaches to successfully manage and accommodate both conditions. The use of observational methods to examine existing electronic health data (e.g., health plan, integrated health care systems) could supplement clinical trial data for individuals with fibromyalgia and other conditions.

Despite purportedly high utilization of multicomponent treatments for adults with fibromyalgia, few such studies reported on subgroup effects. Drug studies dominated the studies that assessed subgroup effects; far fewer studies assessed the effects of nondrug interventions that showed potential benefits.

The vast majority of studies are short term (3 months), leaving many questions about the durability of treatment effects in the management of this chronic condition. Only one study reported that short term overall improvements were not sustained when duloxetine was taken for 6 months.89 For clinicians, short-term studies provide very little information about how best to treat adults with fibromyalgia.

Little is reported on functional outcomes in subgroups of patients with fibromyalgia, including physical, cognitive, and social functioning. Changes in work attendance, work performance, and participation in avocational activities were rarely reported but could benefit the evidence base.

Potential differences in adverse effects in adult subgroups warrant more attention. Although most treatment harms were not serious, potentially differential effects in subgroups were reported in only one pooled IPD RCT analysis.

Study reporting needs improvement to make research information useable for clinicians, particularly in drug studies. Transparently reported, sufficiently powered clinical studies with a priori subgroup and hypothesis specifications were lacking, making subgroup treatment effect conclusions tenuous and limited. Efforts to reduce knowledge gaps from research involving fibromyalgia adult subgroups should aim to present findings that are clear and concise for clinicians to interpret. Reporting of the impact of very high attrition on the strength of study conclusions is critical but is currently inadequate. Placebo effects, which are prominent in this patient population, should be openly reported to enable clinicians and readers to better assess the magnitude of treatment effects.

## Conclusions

The fibromyalgia evidence is largely insufficient to determine subgroup effects for interventions other than duloxetine. The limitations of the primary literature preclude any change of policy or practice based on these findings.