# Evidence Tables

Appendix Table E1 Sample selection criteria and allowed co-interventions for included fibromyalgia randomized clinical trials

Appendix Table E2 Sample selection criteria and allowed co-interventions for included pooled studies of patient-level randomized clinical trial data

Appendix Table E3 Sample selection criteria and allowed co-interventions for included fibromyalgia observational studies

Appendix Table E4 Fibromyalgia randomized clinical trials with subgroups and mixed samples, by class of treatment

Appendix Table E5 Fibromyalgia randomized clinical trials with pure subgroup samples, by class of treatment

Appendix Table E6 Fibromyalgia pooled studies of patient-level RCT data with subgroup reporting, by pharmacologic treatment

Appendix Table E7 Fibromyalgia observational studies with subgroups, by class of treatment

Appendix Table E8 Subgroup outcomes reported in the fibromyalgia randomized clinical trial literature

Appendix Table E9 Subgroup outcomes reported in pooled randomized clinical trial analyses and observational studies

Appendix Table E10 Fibromyalgia risk of bias summary for RCTs: mixed samples and pure subgroups

Appendix Table E11 Fibromyalgia risk of bias summary for observational studies

Appendix Table E12 Quality issues and risk of bias summary for pooled analyses of patient-level randomized clinical trial data on fibromyalgia subgroups

Appendix Table E13 Funding source and corresponding author information in fibromyalgia randomized clinical trials, mixed samples

Appendix Table E14 Funding source and corresponding author information in fibromyalgia randomized clinical trials with pure subgroup samples

Appendix Table E15 Funding source and corresponding author information in fibromyalgia pooled studies of individual patient data from randomized clinical trials

Appendix Table E16 Funding source and corresponding author information in fibromyalgia observational studies

Appendix Table E17 Justification for retaining potentially overlapping individual RCTs and associated pooled patient-level data duloxetine studies that differed in outcome or timing of outcome assessment

## References for Appendix E Evidence Tables

1 Arnold LM, Zhang S, Pangallo BA. Efficacy and safety of duloxetine 30 mg/d in patients with fibromyalgia: a randomized, double-blind, placebo-controlled study. Clin J Pain. Nov-Dec. 2012;28(9):775-81. [pmid: 22971669].
2 Arnold LM, Clauw D, Wang F, et al. Flexible dosed duloxetine in the treatment of fibromyalgia: a randomized, double-blind, placebo-controlled trial. J Rheumatol. Dec. 2010;37(12):2578-86. [pmid: 20843911].
3 Chappell AS, Bradley LA, Wiltse C, et al. A six-month double-blind, placebo-controlled, randomized clinical trial of duloxetine for the treatment of fibromyalgia. Int J Gen Med. 2008;1:91-102. [pmid: 20428412].
4 Russell IJ, Mease PJ, Smith TR, et al. Efficacy and safety of duloxetine for treatment of fibromyalgia in patients with or without major depressive disorder: Results from a 6-month, randomized, double-blind, placebo-controlled, fixed-dose trial. Pain. Jun. 2008;136(3):432-44. [pmid: 18395345].
5 Arnold LM, Rosen A, Pritchett YL, et al. A randomized, double-blind, placebo-controlled trial of duloxetine in the treatment of women with fibromyalgia with or without major depressive disorder. Pain. Dec. 15. 2005;119(1-3):5-15. [pmid: 16298061].
6 Arnold LM, Lu Y, Crofford LJ, et al. A double-blind, multicenter trial comparing duloxetine with placebo in the treatment of fibromyalgia patients with or without major depressive disorder. Arthritis Rheum. Sep. 2004;50(9):2974-84. [pmid: 15457467].
7 Gendreau RM, Thorn MD, Gendreau JF, et al. Efficacy of milnacipran in patients with fibromyalgia. J Rheumatol. Oct. 2005;32(10):1975-85. [pmid: 16206355].
8 Stening KD, Eriksson O, Henriksson KG, et al. Hormonal replacement therapy does not affect self-estimated pain or experimental pain responses in post-menopausal women suffering from fibromyalgia: a double-blind, randomized, placebo-controlled trial. Rheumatology (Oxford). Mar. 2011;50(3):544-51. [pmid: 21078629].
9 Sadreddini S, Molaeefard M, Noshad H, et al. Efficacy of Raloxifen in treatment of fibromyalgia in menopausal women. Eur. Jul. 2008;19(5):350-5. [pmid: 18549938].
10 Arnold LM, Hess EV, Hudson JI, et al. A randomized, placebo-controlled, double-blind, flexible-dose study of fluoxetine in the treatment of women with fibromyalgia. Am J Med. Feb. 15. 2002;112(3):191-7. [pmid: 11893345].
11 Gavi MBRO, Vassalo DV, Amaral FT, et al. Strengthening exercises improve symptoms and quality of life but do not change autonomic modulation in fibromyalgia: A randomized clinical trial. PLoS ONE. 20. Mar. 2014;9(3). [pmid: 24651512].
12 Senna MK, Sallam RA, Ashour HS, et al. Effect of weight reduction on the quality of life in obese patients with fibromyalgia syndrome: a randomized controlled trial. Clin Rheumatol. Nov. 2012;31(11):1591-7. [pmid: 22948223].
13 Gusi N, Parraca JA, Olivares PR, et al. Tilt vibratory exercise and the dynamic balance in fibromyalgia: A randomized controlled trial. Arthritis Care Res. Aug. 2010;62(8):1072-8. [pmid: 20235191].
14 Valkeinen H, Alen M, Hakkinen A, et al. Effects of concurrent strength and endurance training on physical fitness and symptoms in postmenopausal women with fibromyalgia: a randomized controlled trial. Arch Phys Med Rehabil. Sep. 2008;89(9):1660-6. [pmid: 18675392].
15 Assis MR, Silva LE, Alves AM, et al. A randomized controlled trial of deep water running: clinical effectiveness of aquatic exercise to treat fibromyalgia. Arthritis Rheum. Feb. 15. 2006;55(1):57-65. [pmid: 16463414].
16 Hakkinen K, Pakarinen A, Hannonen P, et al. Effects of strength training on muscle strength, cross-sectional area, maximal electromyographic activity, and serum hormones in premenopausal women with fibromyalgia. J Rheumatol. Jun. 2002;29(6):1287-95. [pmid: 12064848].
17 Scheidt CE, Waller E, Endorf K, et al. Is brief psychodynamic psychotherapy in primary fibromyalgia syndrome with concurrent depression an effective treatment? A randomized controlled trial. General Hospital Psychiatry. Mar-Apr. 2013;35(2):160-7. [pmid: 23218844].
18 Castel A, Cascon R, Padrol A, et al. Multicomponent cognitive-behavioral group therapy with hypnosis for the treatment of fibromyalgia: long-term outcome. J Pain. Mar. 2012;13(3):255-65. [pmid: 22285609].
19 Junghaenel DU, Schwartz JE, Broderick JE. Differential efficacy of written emotional disclosure for subgroups of fibromyalgia patients. Br J Health Psychol. Feb. 2008;13(Pt 1):57-60. [pmid: 18230233].
20 Edinger JD, Wohlgemuth WK, Krystal AD, et al. Behavioral insomnia therapy for fibromyalgia patients: a randomized clinical trial. Arch Intern Med. Nov. 28. 2005;165(21):2527-35. [pmid: 16314551].
21 Martinez M, Miro E, Sanchez AI, et al. Cognitive-behavioral therapy for insomnia and sleep hygiene in fibromyalgia: A randomized controlled trial. Journal of Behavioral Medicine. Aug. 2014;37(4):683-97. [pmid: 23744045].
22 Fontaine KR, Conn L, Clauw DJ. Effects of lifestyle physical activity on perceived symptoms and physical function in adults with fibromyalgia: results of a randomized trial. Arthritis Res Ther. 2010;12(2):R55. [pmid: 20353551].
23 Lera S, Gelman SM, Lopez MJ, et al. Multidisciplinary treatment of fibromyalgia: does cognitive behavior therapy increase the response to treatment?. J Psychosom Res. Nov. 2009;67(5):433-41. [pmid: 19837206].
24 Bennett R, Russell IJ, Choy E, et al. Evaluation of patient-rated stiffness associated with fibromyalgia: a post-hoc analysis of 4 pooled, randomized clinical trials of duloxetine. Clin Ther. Apr. 2012;34(4):824-37. [pmid: 22421576].
25 Bradley LA, Bennett R, Russell IJ, et al. Effect of duloxetine in patients with fibromyalgia: tiredness subgroups. Arthritis Res Ther. 2010;12(4):R141. [pmid: 20630058].
26 Arnold LM, Hudson JI, Wang F, et al. Comparisons of the efficacy and safety of duloxetine for the treatment of fibromyalgia in patients with versus without major depressive disorder. Clin J Pain. Jul-Aug. 2009;25(6):461-8. [pmid: 19542792].
27 Arnold LM, Palmer RH, Hufford MR, et al. Effect of milnacipran on body weight in patients with fibromyalgia. International Journal of General Medicine. 2012;5:879-87. [pmid: 23109813].
28 Arnold LM, Gendreau RM, Palmer RH, et al. Efficacy and safety of milnacipran 100 mg/day in patients with fibromyalgia: results of a randomized, double-blind, placebo-controlled trial. Arthritis Rheum. Sep. 2010;62(9):2745-56. [pmid: 20496365].
29 Mease PJ, Clauw DJ, Gendreau RM, et al. The efficacy and safety of milnacipran for treatment of fibromyalgia. a randomized, double-blind, placebo-controlled trial. [Erratum appears in J Rheumatol. 2009 Mar;36(3):661]. J Rheumatol. Feb. 2009;36(2):398-409. [pmid: 19132781].
30 Clauw DJ, Mease P, Palmer RH, et al. Milnacipran for the treatment of fibromyalgia in adults: a 15-week, multicenter, randomized, double-blind, placebo-controlled, multiple-dose clinical trial. [Erratum appears in Clin Ther. 2009 Feb;31(2):446], [Erratum appears in Clin Ther. 2009 Jul; 31(7): 1617]. Clin Ther. Nov. 2008;30(11):1988-2004. [pmid: 19108787].
31 Geisser ME, Palmer RH, Gendreau RM, et al. A pooled analysis of two randomized, double-blind, placebo-controlled trials of milnacipran monotherapy in the treatment of fibromyalgia. Pain pract. Mar-Apr. 2011;11(2):120-31. [pmid: 20642487].
32 Arnold LM, Leon T, Whalen E, et al. Relationships among pain and depressive and anxiety symptoms in clinical trials of pregabalin in fibromyalgia. Psychosomatics. Nov-Dec. 2010;51(6):489-97. [pmid: 21051680].
33 Arnold LM, Russell IJ, Diri EW, et al. A 14-week, randomized, double-blinded, placebo-controlled monotherapy trial of pregabalin in patients with fibromyalgia. J Pain. Sep. 2008;9(9):792-805. [pmid: 18524684].
34 Mease PJ, Russell IJ, Arnold LM, et al. A randomized, double-blind, placebo-controlled, phase III trial of pregabalin in the treatment of patients with fibromyalgia. J Rheumatol. Mar. 2008;35(3):502-14. [pmid: 18278830].
35 Crofford LJ, Rowbotham MC, Mease PJ, et al. Pregabalin for the treatment of fibromyalgia syndrome: results of a randomized, double-blind, placebo-controlled trial. Arthritis Rheum. Apr. 2005;52(4):1264-73. [pmid: 15818684].
36 Bhadra P, Petersel D. Medical conditions in fibromyalgia patients and their relationship to pregabalin efficacy: pooled analysis of Phase III clinical trials. Expert Opinion on Pharmacotherapy. Dec. 2010;11(17):2805-12. [pmid: 21039311].
37 Pauer L, Danneskiold-Samsoe B, Jespersen A, et al. Pregabalin for management of fibromyalgia (FM): A 14-week randomized, double-blind, placebo-controlled, monotherapy trial (Study A0081100). Ann Rheum Dis. 2008;87(Suppl II):256.
38 Byon W, Ouellet D, Chew M, et al. Exposure-response analyses of the effects of pregabalin in patients with fibromyalgia using daily pain scores and patient global impression of change. J Clin Pharmacol. Jul. 2010;50(7):803-15. [pmid: 20357295].
39 Arnold LM, Palmer RH, Gendreau RM, et al. Relationships among pain, depressed mood, and global status in fibromyalgia patients: post hoc analyses of a randomized, placebo-controlled trial of milnacipran. Psychosomatics. Jul-Aug. 2012;53(4):371-9. [pmid: 22677218].
40 Younger J, Mackey S. Fibromyalgia symptoms are reduced by low-dose naltrexone: a pilot study. Pain Med. May-Jun. 2009;10(4):663-72. [pmid: 19453963].
41 Drexler AR, Mur EJ, Gunther VC. Efficacy of an EMG-biofeedback therapy in fibromyalgia patients. A comparative study of patients with and without abnormality in (MMPI) psychological scales. Clinical and Experimental Rheumatology. Sep/Oct. 2002;20(5):677-82. [pmid: 12412199].
42 Joshi MN, Joshi R, Jain AP. Effect of amitriptyline vs. physiotherapy in management of fibromyalgia syndrome: What predicts a clinical benefit?. Journal of Postgraduate Medicine. Jul-Sep. 2009;55(3):185-9. [pmid: 19884743].
43 Hakkinen A, Hakkinen K, Hannonen P, et al. Strength training induced adaptations in neuromuscular function of premenopausal women with fibromyalgia: comparison with healthy women. Ann Rheum Dis. Jan. 2001;60(1):21-6. [pmid: 11114277].
44 Fisher DJ, Copas AJ, Tierney JF, et al. A critical review of methods for the assessment of patient-level interactions in individual participant data meta-analysis of randomized trials, and guidance for practitioners. J Clin Epidemiol. Sep. 2011;64(9):949-67. [pmid: 21411280].