# Excluded Studies

## No Subgroup (n=20)

1 Huuhka MJ, Haanpaa ML, Leinonen EV. Electroconvulsive therapy in patients with depression and fibromyalgia. European Journal of Pain. Aug. 2004;8(4):371-6. [pmid: 15207518].
2 Jones KD, Sherman CA, Mist SD, et al. A randomized controlled trial of 8-form Tai chi improves symptoms and functional mobility in fibromyalgia patients. Clinical Rheumatology. Aug. 2012;31(8):1205-14. [pmid: 22581278].
3 Toussaint LL, Whipple MO, Abboud LL, et al. A mind-body technique for symptoms related to fibromyalgia and chronic fatigue. Explore: The Journal of Science & Healing. Mar-Apr. 2012;8(2):92-8. [pmid: 22385563].
4 Castel A, Cascon R, Padrol A, et al. Multicomponent cognitive-behavioral group therapy with hypnosis for the treatment of fibromyalgia: long-term outcome. Journal of Pain. Mar. 2012;13(3):255-65. [pmid: 22285609].
5 Ang DC, Kaleth AS, Bigatti S, et al. Research to encourage exercise for fibromyalgia (REEF): use of motivational interviewing, outcomes from a randomized-controlled trial. Clinical Journal of Pain. Apr. 2013;29(4):296-304. [pmid: 23042474].
6 Fontaine KR, Conn L, Clauw DJ. Effects of lifestyle physical activity in adults with fibromyalgia: results at follow-up. JCR: Journal of Clinical Rheumatology. Mar. 2011;17(2):64-8. [pmid: 21325963].
7 Alfano AP, Taylor AG, Foresman PA, et al. Static magnetic fields for treatment of fibromyalgia: a randomized controlled trial. Journal of Alternative & Complementary Medicine. Feb. 2001;7(1):53-64. [pmid: 11246937].
8 van Koulil S, van Lankveld W, Kraaimaat FW, et al. Tailored cognitive-behavioral therapy and exercise training for high-risk patients with fibromyalgia. Arthritis care & research. Oct. 2010;62(10):1377-85. [pmid: 20521308].
9 McCain GA. Role of physical fitness training in the fibrositis/fibromyalgia syndrome. American Journal of Medicine. Sep. 29. 1986;81(3A):73-7. [pmid: 3532784].
10 Vitton O, Gendreau M, Gendreau J, et al. A double-blind placebo-controlled trial of milnacipran in the treatment of fibromyalgia. Human Psychopharmacology. Oct. Suppl 1. 2004;19:S27-35. [pmid: 15378666].
11 Goldenberg DL, Clauw DJ, Palmer RH, et al. Durability of therapeutic response to milnacipran treatment for fibromyalgia. Results of a randomized, double-blind, monotherapy 6-month extension study. Pain Medicine. Feb. 2010;11(2):180-94. [pmid: 20002596].
12 Castro-Sanchez AM, Mataran-Penarrocha GA, Arroyo-Morales M, et al. Effects of myofascial release techniques on pain, physical function, and postural stability in patients with fibromyalgia: a randomized controlled trial. Clinical Rehabilitation. Sep. 2011;25(9):800-13. [pmid: 21673013].
13 Alda M, Luciano JV, Andres E, et al. Effectiveness of cognitive behaviour therapy for the treatment of catastrophisation in patients with fibromyalgia: a randomised controlled trial. Arthritis Research & Therapy. 2011;13(5):R173. [pmid: 22018333].
14 Pauer L, Winkelmann A, Arsenault P, et al. An international, randomized, double-blind, placebo-controlled, phase III trial of pregabalin monotherapy in treatment of patients with fibromyalgia. Journal of Rheumatology. Dec. 2011;38(12):2643-52. [pmid: 21965636].
15 Arnold LM, Wang F, Ahl J, et al. Improvement in multiple dimensions of fatigue in patients with fibromyalgia treated with duloxetine: secondary analysis of a randomized, placebo-controlled trial. Arthritis Research & Therapy. 2011;13(3):R86. [pmid: 21668963].
16 Mease PJ, Clauw DJ, Gendreau RM, et al. The efficacy and safety of milnacipran for treatment of fibromyalgia. a randomized, double-blind, placebo-controlled trial. [Erratum appears in J Rheumatol. 2009 Mar;36(3):661]. Journal of Rheumatology. Feb. 2009;36(2):398-409. [pmid: 19132781].
17 Mease PJ, Russell IJ, Arnold LM, et al. A randomized, double-blind, placebo-controlled, phase III trial of pregabalin in the treatment of patients with fibromyalgia. Journal of Rheumatology. Mar. 2008;35(3):502-14. [pmid: 18278830].
18 Cuatrecasas G, Alegre C, Fernandez-Sola J, et al. Growth hormone treatment for sustained pain reduction and improvement in quality of life in severe fibromyalgia. Pain. Jul. 2012;153(7):1382-9. [pmid: 22465047].
19 Cuatrecasas G, Riudavets C, Guell MA, et al. Growth hormone as concomitant treatment in severe fibromyalgia associated with low IGF-1 serum levels. A pilot study. BMC Musculoskeletal Disorders. 2007;8:119. [pmid: 18053120].
20 Jones KD, Deodhar AA, Burckhardt CS, et al. A combination of 6 months of treatment with pyridostigmine and triweekly exercise fails to improve insulin-like growth factor-I levels in fibromyalgia, despite improvement in the acute growth hormone response to exercise. Journal of Rheumatology. May. 2007;34(5):1103-11. [pmid: 17407215].

## Less Than 3 Months Followup (n=21)

1 Tavoni A, Vitali C, Bombardieri S, et al. Evaluation of S-adenosylmethionine in primary fibromyalgia. A double-blind crossover study. American Journal of Medicine. Nov. 20. 1987;83(5A):107-10. [pmid: 3318438].
2 Bagis S, Karabiber M, As I, et al. Is magnesium citrate treatment effective on pain, clinical parameters and functional status in patients with fibromyalgia?. Rheumatology International. Jan. 2013;33(1):167-72. [pmid: 22271372].
3 Scudds RA, McCain GA, Rollman GB, et al. Improvements in pain responsiveness in patients with fibrositis after successful treatment with amitriptyline. Journal of Rheumatology - Supplement. Nov. 1989;19:98-103. [pmid: 2481743].
4 Holton KF, Taren DL, Thomson CA, et al. The effect of dietary glutamate on fibromyalgia and irritable bowel symptoms. Clinical & Experimental Rheumatology. Nov-Dec. 2012;30(6 Suppl 74):10-7. [pmid: 22766026].
5 Goldenberg DL, Felson DT, Dinerman H. A randomized, controlled trial of amitriptyline and naproxen in the treatment of patients with fibromyalgia. Arthritis & Rheumatism. Nov. 1986;29(11):1371-7. [pmid: 3535811].
6 Kempenaers C, Simenon G, Vander Elst M, et al. Effect of an antidiencephalon immune serum on pain and sleep in primary fibromyalgia. Neuropsychobiology. 1994;30(2-3):66-72. [pmid: 7800166].
7 Ozerbil O, Okudan N, Gokbel H, et al. Comparison of the effects of two antidepressants on exercise performance of the female patients with fibromyalgia. Clinical Rheumatology. Jul. 2006;25(4):495-7. [pmid: 16267603].
8 Schwartz TL, Siddiqui UA, Raza S, et al. Armodafinil for fibromyalgia fatigue. Annals of Pharmacotherapy. Jul-Aug. 2010;44(7-8):1347-8. [pmid: 20551299].
9 Ware MA, Fitzcharles MA, Joseph L, et al. The effects of nabilone on sleep in fibromyalgia: results of a randomized controlled trial. Anesthesia & Analgesia. Feb. 1. 2010;110(2):604-10. [pmid: 20007734].
10 Sanudo B, de Hoyo M, Carrasco L, et al. Effect of whole-body vibration exercise on balance in women with fibromyalgia syndrome: a randomized controlled trial. Journal of Alternative & Complementary Medicine. Feb. 2012;18(2):158-64. [pmid: 22321155].
11 Cook DB, Stegner AJ, Nagelkirk PR, et al. Responses to exercise differ for chronic fatigue syndrome patients with fibromyalgia. Medicine & Science in Sports & Exercise. Jun. 2012;44(6):1186-93. [pmid: 22157881].
12 Passard A, Attal N, Benadhira R, et al. Effects of unilateral repetitive transcranial magnetic stimulation of the motor cortex on chronic widespread pain in fibromyalgia. Brain. Oct. 2007;130(Pt 10):2661-70. [pmid: 17872930].
13 Roizenblatt S, Fregni F, Gimenez R, et al. Site-specific effects of transcranial direct current stimulation on sleep and pain in fibromyalgia: a randomized, sham-controlled study. Pain Practice. Dec. 2007;7(4):297-306. [pmid: 17986164].
14 Thomas AW, Graham K, Prato FS, et al. A randomized, double-blind, placebo-controlled clinical trial using a low-frequency magnetic field in the treatment of musculoskeletal chronic pain. Pain Research & Management. 2007;12(4):249-58. [pmid: 18080043].
15 Casanueva-Fernandez B, Llorca J, Rubio JB, et al. Efficacy of a multidisciplinary treatment program in patients with severe fibromyalgia. Rheumatology International. Aug. 2012;32(8):2497-502. [pmid: 21785956].
16 Miro E, Lupianez J, Martinez MP, et al. Cognitive-behavioral therapy for insomnia improves attentional function in fibromyalgia syndrome: a pilot, randomized controlled trial. Journal of Health Psychology. Jul. 2011;16(5):770-82. [pmid: 21346020].
17 Finset A, Wigers SH, Gotestam KG. Depressed mood impedes pain treatment response in patients with fibromyalgia. Journal of Rheumatology. May. 2004;31(5):976-80. [pmid: 15124260].
18 Affaitati G, Costantini R, Fabrizio A, et al. Effects of treatment of peripheral pain generators in fibromyalgia patients. European Journal of Pain. Jan. 2011;15(1):61-9. [pmid: 20889359].
19 Konuk N, Ortancil O, Bostanci B, et al. A comparison of reboxetine and amitryptilline in the treatment of fibromyalgia syndrome with co-morbid depressive symptoms: An open-label preliminary study. Klinik Psikofarmakoloji Bulteni. 2010;20(1):29-37.
20 Vlaeyen JW, Teeken-Gruben NJ, Goossens ME, et al. Cognitive-educational treatment of fibromyalgia: a randomized clinical trial. I. Clinical effects. Journal of Rheumatology. Jul. 1996;23(7):1237-45. [pmid: 8823699].
21 Hoeger Bement MK, Weyer A, Hartley S, et al. Pain perception after isometric exercise in women with fibromyalgia. Archives of Physical Medicine & Rehabilitation. Jan. 2011;92(1):89-95. [pmid: 21187210].

## Other

### Post Hoc Subgroup/Exploratory (n=6)

1 Moore RA, Straube S, Paine J, et al. Fibromyalgia: Moderate and substantial pain intensity reduction predicts improvement in other outcomes and substantial quality of life gain. Pain. May. 2010;149(2):360-4. [pmid: 20347225].
2 Pauer L, Atkinson G, Murphy TK, et al. Long-term maintenance of response across multiple fibromyalgia symptom domains in a randomized withdrawal study of pregabalin. Clinical Journal of Pain. Sep. 2012;28(7):609-14. [pmid: 22688598].
3 King SJ, Wessel J, Bhambhani Y, et al. The effects of exercise and education, individually or combined, in women with fibromyalgia. Journal of Rheumatology. Dec. 2002;29(12):2620-7. [pmid: 12465163].
4 Arnold LM, Palmer RH, Ma Y. A 3-Year, open-label, flexible-dosing study of milnacipran for the treatment of fibromyalgia. Clinical Journal of Pain. Dec. 2013;29(12):1021-8. [pmid: 23446068].
5 Burckhardt CS, Clark SR, Bennett RM. Long-term follow-up of fibromyalgia patients who completed a structured treatment program versus patients in routine treatment. Journal of Musculoskeletal Pain. 2005;13(1):5-14.
6 Sayar K, Aksu G, Ak I, et al. Venlafaxine treatment of fibromyalgia. Annals of Pharmacotherapy. Nov. 2003;37(11):1561-5. [pmid: 14565792].

### Predictors of Treatment Response (n=3)

1 Thieme K, Turk DC, Flor H. Responder criteria for operant and cognitive-behavioral treatment of fibromyalgia syndrome. Arthritis & Rheumatism. Jun. 15. 2007;57(5):830-6. [pmid: 17530683].
2 Pae CU, Masand PS, Marks DM, et al. History of early abuse as a predictor of treatment response in patients with fibromyalgia: a post-hoc analysis of a 12-week, randomized, double-blind, placebo-controlled trial of paroxetine controlled release. World Journal of Biological Psychiatry. 2009;10(4 Pt 2):435-41. [pmid: 19382010].
3 Pae CU, Masand PS, Marks DM, et al. History of depressive and/or anxiety disorders as a predictor of treatment response: a post hoc analysis of a 12-week, randomized, double-blind, placebo-controlled trial of paroxetine controlled release in patients with fibromyalgia. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Aug. 31. 2009;33(6):996-1002. [pmid: 19433129].

### Duplicate Sample (n=2)

1 Marangell LB, Clauw DJ, Choy E, et al. Comparative pain and mood effects in patients with comorbid fibromyalgia and major depressive disorder: secondary analyses of four pooled randomized controlled trials of duloxetine. Pain. Jan. 2011;152(1):31-7. [pmid: 20598442].
2 Arnold LM, Pritchett YL, D’Souza DN, et al. Duloxetine for the treatment of fibromyalgia in women: pooled results from two randomized, placebo-controlled clinical trials. Journal of Women’s Health. Oct. 2007;16(8):1145-56. [pmid: 17937567].

### Not Fibromyalgia Per Criteria (n=2)

1 Spitzer AR, Broadman M. A retrospective review of the sleep characteristics in patients with chronic fatigue syndrome and fibromyalgia. Pain Practice. Jul-Aug. 2010;10(4):294-300. [pmid: 20230458].
2 Skouen JS, Grasdal A, Haldorsen EM. Return to work after comparing outpatient multidisciplinary treatment programs versus treatment in general practice for patients with chronic widespread pain. European Journal of Pain. Feb. 2006;10(2):145-52. [pmid: 16310718].

### Non U.S. Drug or Treatment (n=2)

1 Drewes AM, Andreasen A, Jennum P, et al. Zopiclone in the treatment of sleep abnormalities in fibromyalgia. Scandinavian Journal of Rheumatology. 1991;20(4):288-93. [pmid: 1925417].
2 Distler O, Eich W, Dokoupilova E, et al. Evaluation of the efficacy and safety of terguride in patients with fibromyalgia syndrome: results of a twelve-week, multicenter, randomized, double-blind, placebo-controlled, parallel-group study. Arthritis & Rheumatism. Jan. 2010;62(1):291-300. [pmid: 20039417].

### Review of Another Trial (n=2)

1 Williams DA. Utility of cognitive behavioral therapy as a treatment for insomnia in patients with fibromyalgia. Nature Clinical Practice Rheumatology. Apr. 2006;2(4):190-1. [pmid: 16932684].
2 Mohs R, Mease P, Arnold LM, et al. The effect of duloxetine treatment on cognition in patients with fibromyalgia. Psychosomatic Medicine. Jul-Aug. 2012;74(6):628-34. [pmid: 22753629].

### Cannot Differentiate Outcomes (n=1)

1 Fjorback LO, Arendt M, Ornbol E, et al. Mindfulness therapy for somatization disorder and functional somatic syndromes: randomized trial with one-year follow-up. Journal of Psychosomatic Research. Jan. 2013;74(1):31-40. [pmid: 23272986].

### Inappropriate Comparison Group (n=2)

1 Rasmussen LB, Mikkelsen K, Haugen M, et al. Treatment of fibromyalgia at the Maharishi Ayurveda Health Centre in Norway II--a 24-month follow-up pilot study. Clinical Rheumatology. May. 2012;31(5):821-7. [pmid: 22278161].
2 Rasmussen LB, Mikkelsen K, Haugen M, et al. Treatment of fibromyalgia at the Maharishi Ayurveda Health Centre in Norway. A six-month follow-up study. Clinical & Experimental Rheumatology. Sep-Oct. 2009;27(5 Suppl 56):S46-50. [pmid: 20074439].