# Treatments for Fibromyalgia in Adult Subgroups Risk of Bias Assessment for Observational Studies

RCT Risk of bias assessment: Fibromyalgia subgroup studies

Pooled individual patient data RCTs risk of bias assessment: Fibromyalgia subgroup studies