# Fibromyalgia Search Strings

## Database: Ovid MEDLINE® Search Strategy

1. meta analysis as topic/ (14174)
2. meta-analy$.tw. (58094)
3. metaanaly$.tw. (1283)
4. meta-analysis/ (51865)
5. (systematic adj (review$1 or overview$1)).tw. (47251)
6. exp Review Literature as Topic/ (7718)
7. or/1-6 (115989)
8. cochrane.ab. (33481)
9. embase.ab. (29939)
10. (psychlit or psyclit).ab. (1190)
11. (psychinfor or psycinfo).ab. (8325)
12. or/8-11 (48550)
13. reference list$.ab. (11704)
14. bibliograph$.ab. (11806)
15. hand search.ab. (876)
16. relevant journals.ab. (904)
17. manual search$.ab. (2248)
18. or/13-17 (25683)
19. selection criteria.ab. (26165)
20. data extraction.ab. (10119)
21. 19 or 20 (33811)
22. review/ (1921415)
23. 21 and 22 (26055)
24. comment/ (537610)
25. letter/ (807565)
26. editorial/ (337037)
27. animal/ (5506319)
28. human/ (13689930)
29. 27 not (28 and 27) (3970292)
30. or/24-26,29 (5167730)
31. 7 or 12 or 18 or 23 (144954)
32. 31 not 30 (135948)
33. randomized controlled trials as topic/ (102691)
34. randomized controlled trial/ (390224)
35. random allocation/ (81795)
36. double blind method/ (131905)
37. single blind method/ (19625)
38. clinical trial/ (504861)
39. clinical trial, phase i.pt. (16220)
40. clinical trial, phase ii.pt. (26918)
41. clinical trial, phase iii.pt. (10181)
42. clinical trial, phase iv.pt. (997)
43. controlled clinical trial.pt. (89925)
44. randomized controlled trial.pt. (390224)
45. multicenter study.pt. (182851)
46. clinical trial.pt. (504861)
47. exp Clinical trials as topic/ (296596)
48. or/33-46 (959756)
49. (clinical adj trial$).tw. (211765)
50. ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$3)).tw. (129589)
51. placebos/ (33783)
52. placebo$.tw. (161799)
53. randomly allocated.tw. (16078)
54. (allocated adj2 random$).tw. (18581)
55. 49 or 50 or 51 or 52 or 53 or 54 (418203)
56. 48 or 55 (1126654)
57. case report.tw. (184302)
58. case report.tw. (184302)
59. letter/ (807565)
60. historical article/ (300466)
61. 57 or 58 or 59 or 60 (1281048)
62. 56 not 61 (1102751)
63. exp cohort studies/ (1371088)
64. cohort$.tw. (263920)
65. controlled clinical trial.pt. (89925)
66. epidemiologic methods/ (30994)
67. limit 66 to yr=1971-1983 (5365)
68. 63 or 64 or 65 or 67 (1546297)
69. exp case-control study/ (666622)
70. (case$ and control$).tw. (314550)
71. 69 or 70 (892406)
72. exp Fibromyalgia/ (6360)
73. fibromyalgia.ti,ab. (6304)
74. myofascial pain syndrome*.ti,ab. (387)
75. 32 or 62 or 68 or 71 (2692964)
76. 72 or 73 or 74 (7791)
77. 75 and 76 (2584)
78. limit 77 to “all adult (19 plus years)” (1910)
79. limit 78 to “all child (0 to 18 years)” (309)
80. 77 not 79 (2275)
81. 78 or 80 (2584)

## Database: Embase Classic+Embase Search Strategy

1. fibromyalgia/ (13099)
2. fibromyalgia.ti,ab. (10216)
3. exp myofascial pain/ (6786)
4. myofacial pain syndrome*.ti,ab. (27)
5. 1 or 2 or 3 or 4 (20091)
6. retracted article/ (7252)
7. (random$ or placebo$ or single blind$ or double blind$ or triple blind$).ti,ab. (1017703)
8. (animal$ not human$).sh,hw. (3953097)
9. (book or conference paper or editorial or letter or review).pt. not exp randomized controlled trial/ (4100517)
10. 6 or 7 (1024797)
11. 10 not (8 or 9) (836009)
12. exp cohort analysis/ (170749)
13. exp longitudinal study/ (69111)
14. exp prospective study/ (264902)
15. exp follow up/ (816417)
16. cohort$.tw. (389844)
17. 12 or 13 or 14 or 15 or 16 (1380858)
18. exp case-control study/ (94713)
19. (case$ and control$).tw. (472185)
20. 18 or 19 (507755)
21. (case$ and series).tw. (193606)
22. exp review/ (2091689)
23. (literature adj3 review$).ti,ab. (234902)
24. exp meta analysis/ (80432)
25. exp “Systematic Review”/ (70130)
26. 22 or 23 or 24 or 25 (2301941)
27. (medline or embase or pubmed or cinahl or amed or psychlit or psychinfo or scisearch or cochrane).ti,ab. (106533)
28. retracted article/ (7252)
29. 27 or 28 (113736)
30. 26 and 29 (84397)
31. (systematic$ adj2 (review$ or overview)).ti,ab. (72028)
32. (meta?anal$ or meta anal$ or metaanal$ or metanal$).ti,ab. (80995)
33. 30 or 31 or 32 (170495)
34. 11 or 17 or 20 or 21 or 33 (2715453)
35. 5 and 34 (4204)
36. limit 35 to (embryo <first trimester> or infant <to one year> or child <unspecified age> or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>) (379)
37. limit 36 to (adult <18 to 64 years> or aged <65+ years>) (289)
38. 35 not 36 (3825)
39. 37 or 38 (4114)
40. limit 39 to (book or book series or conference abstract or conference paper or conference proceeding or “conference review” or editorial or letter or note or report or short survey or trade journal) (887)
41. 39 not 40 (3227)

## Database: PsycINFO® Search Strategy

1. fibromyalgia/ (1194)
2. myofacial pain syndrome*.ti,ab. (2)
3. fibromyalgia.ti. (1331)
4. 1 or 2 or 3 (1594)
5. limit 4 to (“0200 book” or “0240 authored book” or “0280 edited book” or “0300 encyclopedia” or “0400 dissertation abstract”) (168)
6. 4 not 5 (1426)
7. limit 6 to (abstract collection or bibliography or chapter or “column/opinion” or “comment/reply” or dissertation or editorial or encyclopedia entry or letter or obituary or poetry or publication information or reprint or review-book or review-media or review-software & other) (126)
8. 6 not 7 (1300)
9. limit 8 to (childhood <birth to 12 years> or adolescence <13 to 17 years>) (34)
10. limit 9 to adulthood <18+ years> (23)
11. 8 not 9 (1266)
12. 10 or 11 (1289)

## Database: Cochrane Library Search Strategy

Fibromyalgia’ in title, abstract, keyword

## AMED (Allied and Complementary Medicine)

Set | Search
001 | meta analysis.af.
002 | meta-analy$.tw.
003 | metaanaly$.tw.
004 | meta-analysis/
005 | (systematic adj (review$1 or overview$1)).tw.
006 | literature review.af.
007 | 1 or 2 or 3 or 4 or 5 or 6
008 | cochrane.ab.
009 | embase.ab.
010 | (psychlit or psyclit).ab.
011 | (psychinfor or psycinfo).ab.
012 | 8 or 9 or 10 or 11
013 | reference list$.ab.
014 | bibliograph$.ab.
015 | hand search.ab.
016 | relevant journals.ab.
017 | manual search$.ab.
018 | 13 or 14 or 15 or 16 or 17
019 | selection criteria.ab.
020 | data extraction.ab.
021 | 19 or 20
022 | review.af.
023 | 21 and 22
024 | letter.pt.
025 | comment.pt.
026 | editorial.pt.
027 | animal.af.
028 | human.af.
029 | (animal not (human and animal)).af.
030 | 24 or 25 or 26 or 29
031 | 7 or 12 or 18 or 23
032 | ((meta analysis or meta-analy$ or metaanaly$ or meta-analysis or (systematic adj (review$1 or overview$1)) or literature review or (cochrane or embase or (psychlit or psyclit) or ( psychinfor or psycinfo)) or (reference list$ or bibliograph$ or hand search or relevant journals or manual search$) or ((selection criteria or data extraction) and review)) not (letter or comment or editorial or (animal not (human and animal)))).af.
033 | randomized controlled trials/
034 | randomized controlled trial/
035 | random allocation/
036 | double blind method/
037 | single blind method/
038 | clinical trial/
039 | clinical trial.pt.
040 | controlled clinical trial.pt.
041 | randomized controlled trial.pt.
042 | multicenter study.pt.
043 | clinical trial.pt.
044 | clinical trial.af.
045 | 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42
046 | (clinical adj trial$).tw.
047 | ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$ 3)).tw.
048 | placebos/
049 | placebo$.tw.
050 | randomly allocated.tw.
051 | (allocated adj2 random$).tw.
052 | 46 or 47 or 48 or 49 or 50 or 51
053 | 45 or 52
054 | case report.tw.
055 | case report.tw.
056 | letter.pt.
057 | historical article.af.
058 | 54 or 56 or 57
059 | 53 not 58
060 | exp cohort studies/
061 | cohort$.tw.
062 | controlled clinical trial.pt.
063 | epidemiologic methods/
064 | 60 or 61 or 62
065 | exp Case Control Studies.
066 | (case$ and control$).tw.
067 | 65 or 66
068 | exp FIbromyalgia/
069 | fibromyalgia.ti,ab.
070 | myofascial pain syndrome*.ti,ab
071 | 32 or 59 or 64 or 67
072 | 68 or 69 or 70
073 | 71 and 72
074 | adult/ or aged/ or middle aged/
075 | child/ or infant/
076 | 73 and 74
077 | 76 not 75
078 | (adult or aged or middle aged).af
079 | (child or infant).af.
080 | 73 and 78
081 | (73 and 78) not 79