# Medications Used Off Label for Fibromyalgia Syndrome in the United States

Trade Name | Generic Name | Manufacturer | Therapeutic Class | FDA-Fibro | Subclass
Prozac | Fluoxetine | Eli Lilly and Co | Antidepressants | Off label | SNRI
Elavil | Amitriptyline | AstraZeneca | Antidepressants | Off label | Tricyclic anti-depressant
Paxil CR | Paroxetine | GlaxoSmithKline | Antidepressants | Off label | SNRI
Mirapex | Pramepixole | Boehringer Ingelheim | Anti-Dyskinetic | Off label | Nonergot Dopamine Agonist
Amrix | Cyclobenzapine | Cephalon, Inc | Muscle relaxant | Off label | Centally-acting skeletal muscle relaxant
Ultracet | Tramadol | Janssen Pharmaceuticals | Analgesic | Off label | Synthetic opioid analgesic, SNRI
Ultram | Tramadol | Janssen Pharmaceuticals | Analgesic | Approved for chronic pain | Synthetic opioid analgesic, SNRI
ConZip | Tramadol | Vertical Pharmaceuticals | Analgesic | Off label | Synthetic opioid analgesic, SNRI
Neurontin | Gabapentin | Pfizer | Anti-convulsant | Off label | GABA (gamma amino-butyric acid) analog
Deptran | Doxepin | Generic | Antidepressant, Anxiolytic, Antipruritic | Off label | Tricyclic antidepressant
Tizanadine | Xanaflex | Cephalon, Inc | Muscle relaxant | Off label | Central alpha-2 Adrenergic Agonist
Flexeril | Cyclobenzapine | McNeil Consumer and Specialty | Muscle relaxant | Off label | Centrally-acting skeletal muscle relaxant
Ambien | Zolpidem | Sanofi Aventis | Sedative-Hypnotic(Non-Barbiturate) | Off label | Imidazopyridine
Lunesta | Eszipoclone | Sunovion Pharms Inc | Non-barbiturate hypnotic | Off label | Non-benzodoazepine
Klonopin | Clonazepam | Roche | Anxiolytic | Off label | Benzodiazepine
Lexapro | Escitalopram | Forest Labs | Antidepressants | Off label | SSRI
Zoloft | Sertraline | Pfizer | Antidepressants | Off label | SSRI
Motrin | Ibuprofen | Pfizer | Analgesic/Anti-inflammatory | Off label | NSAID
Advil | Ibuprofen | Pfizer | Analgesic/Anti-inflammatory | Off label | NSAID
Aleve | Naproxen | Bayer | Analgesic/Anti-inflammatory | Off label | NSAID
Celebrex | Celecoxib | Pfizer | Analgesic/Anti-inflammatory | Off label | NSAID
Aspirin | Acetylsalicyclic acid | Bayer | Analgesic/Anti-inflammatory | Off label | NSAID
Tylenol | Acetaminophen | McNeil Consumer Healthcare | Analgesics | Off label | Non-opioid Analgesics
Desyrel | Trazadone | Generic | Antidepressants | Off label | serotonin antagonist reuptake inhibitor
Oxycontin | Oxycodone | Purdue | Analgesics | Off label | Opioid Analgesics
Percocet | Oxycodone | Endo | Analgesics | Off label | Opioid Analgesics
Vicodin | Hydrocodone | AbbVie | Analgesics | Off label | Opioid Analgesics
Dilaudid | Hydromorphine | Purdue | Analgesics | Off label | Opioid Analgesics
MsContin | Morphine | Purdue | Analgesics | Off label | Opioid Analgesics
Duragesic | Fentanyl | Generic | Analgesics | Off label | Opioid Analgesics
Valium | Diazepam | Roche | Anxiolytic | Off label | Benzodiazepine
Clinoxan | Tetrazapem | Generic | Anxiolytic | Off label | Benzodiazepine
Millipred | Prednisolone | Generic | Anti-inflammatory-Immunosuppressant | Off label | Corticosteroid, Glucocorticosteroid
Xyrem | Sodium Oxybate | Jazz Pharmaceuticals | CNS depressant | Off label | Narcotic sedative: FDA rejected for FM

Abbreviations: FDA-Food and Drug Administration; FM-Fibromyalgia; NSAID-Non-Steroidal Anti-Inflammatory Drugs; SNRI-Serotonin Norepinephrine Re-uptake Inhibitors; SSRI-Selective Serotonin Reuptake Inhibitors