# Abbreviations

ACR: American College of Rheumatology
AE: Adverse effects
AMED: Allied and Complementary Medicine
AS: Ankylosing spondylitis
BDI: Beck Depression Inventory
BPI: Brief Pain Inventory
BMI: Body Mass Index
CAM: Complementary and alternative medicine
CENTRAL: Cochrane Central Register of Controlled Trials
CER: Comparative effectiveness review
CGI-S: Clinical Global Impression of Severity Scale
EMG: Electromyography
EQ-5D: EuroQol health outcomes assessment
ESR: Erythrocyte Sedimentation Rate
FDA: Food and Drug Administration
FIQ: Fibromyalgia Impact Questionnaire
FIQR: Revised FIQ
FM: Fibromyalgia
GAD: Generalized Anxiety Disorder
GI: Gastrointestinal
HAMD: Hamilton Rating Scale for Depression
HRQoL: Health-related quality of life
IBS: Irritable Bowel Syndrome
IPD: Individual patient data
ICTRP: International Controlled Trial Registry Platform
MAF: Multidimensional Assessment of Fatigue
MCID: Minimum Clinically Important Difference
MDD: Major Depressive Disease
MeSH: Medical subject headings
MOS: Medical Outcomes Study sleep scale
MFI: Multidimensional Fatigue Inventory
MMPI: Minnesota Multiphasic Personality Inventory
MT: Multidisciplinary Treatment
NR: Not Reported
NW: Non White
OA: Osteoarthritis
PGART: Patient’s Global Assessment of Response to Therapy
PGIC: Patient Global Impression of Change Score
PGI-I: Patient Global Impression of Improvement Scale
PICOTS: Population, Intervention, Comparator, Outcomes, Timing, Setting
PSQI: Pittsburgh Sleep Quality Index
QoL: Quality of Life
RA: Rheumatoid arthritis
RCT: Randomized controlled trial
SCL-90-R: Symptom Checklist-90-Revised
SDS: Sheehan Disability Scale
SF-36: MOS Short-Form 36-item Health Survey
SLE: Lupus
SSRI: Selective Serotonin Reuptake Inhibitors
SNRI: Serotonin Nor-epinephrine Reuptake Inhibitors
W: White
VAS: Visual Analogue Scale