# References

1 Soules MR, Sherman S, Parrott E, et al. Executive summary: Stages of Reproductive Aging Workshop (STRAW). Climacteric : the journal of the International Menopause Society. Dec. 2001;4(4):267-72. [pmid: 11770182].
2 Soules MR, Sherman S, Parrott E, et al. Executive summary: Stages of Reproductive Aging Workshop (STRAW) Park City, Utah, July, 2001. Menopause. Nov-Dec. 2001;8(6):402-7. [pmid: 21141649].
3 Soules MR, Sherman S, Parrott E, et al. Executive summary: Stages of Reproductive Aging Workshop (STRAW). Fertil Steril. Nov. 2001;76(5):874-8. [pmid: 11704104].
4 Amundsen DW, Diers CJ. The age of menopause in classical Greece and Rome. Hum Biol. Feb. 1970;42(1):79-86. [pmid: 4910710].
5 North American Menopause Society. Menopause Practice: A Clinician's Guide. 4th Edition ed. Mayfield Heights, OH. North American Menopause Society. 2010.
6 Harlow S. Executive Summary of the Stages of Reproductive Aging Workshop + 10: Addressing the Unfinished Agenda of Staging Reproductive Aging. J Clin Endocrinol Metab. 2012;97(4):1159-68. PMID:. [pmid: 22344196].
7 McKinlay SM, Brambilla DJ, Posner JG. The normal menopause transition. Maturitas. Jan. 1992;14(2):103-15. [pmid: 1565019].
8 Nelson HD, Haney E, Humphrey L, et al. Management of menopause-related symptoms. Evid Rep Technol Assess (Summ). Mar. 2005;(120):1-6. [pmid: 15910013].
9 Woods NF, Mitchell ES. Symptoms during the perimenopause: prevalence, severity, trajectory, and significance in women's lives. Am J Med. Dec. 19. Suppl 12B. 2005;118:14-24. [pmid: 16414323].
10 Proceedings from the NIH State-of-the-Science Conference on Management of Menopause-Related Symptoms. March 21-23, 2005. Bethesda, Maryland, USA. Am J Med. Dec. 19. Suppl 12B. 2005;118:1-171. [pmid: 16414320].
11 Politi MC, Schleinitz MD, Col NF. Revisiting the duration of vasomotor symptoms of menopause: a meta-analysis. J Gen Intern Med. Sep. 2008;23(9):1507-13. [pmid: 18521690].
12 Freeman EW, Sammel MD, Lin H, et al. Duration of menopausal hot flushes and associated risk factors. Obstet Gynecol. May. 2011;117(5):1095-104. [pmid: 21508748].
13 Gold EB, Block G, Crawford S, et al. Lifestyle and demographic factors in relation to vasomotor symptoms: baseline results from the Study of Women's Health Across the Nation. Am J Epidemiol. Jun. 15. 2004;159(12):1189-99. [pmid: 15191936].
14 Keating NL, Cleary PD, Rossi AS, et al. Use of hormone replacement therapy by postmenopausal women in the United States. Ann Intern Med. Apr. 6. 1999;130(7):545-53. [pmid: 10189323].
15 Rossouw JE, Anderson GL, Prentice RL, et al. Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results From the Women's Health Initiative randomized controlled trial. JAMA. Jul. 17. 2002;288(3):321-33. [pmid: 12117397].
16 Prentice RL, Langer R, Stefanick ML, et al. Combined postmenopausal hormone therapy and cardiovascular disease: toward resolving the discrepancy between observational studies and the Women's Health Initiative clinical trial. Am J Epidemiol. Sep. 1. 2005;162(5):404-14. [pmid: 16033876].
17 Tsai SA, Stefanick ML, Stafford RS. Trends in menopausal hormone therapy use of US office-based physicians, 2000-2009. Menopause. Apr. 2011;18(4):385-92. [pmid: 21127439].
18 Somboonporn. Testosterone for peri and postmenopausal women. Cochrane Database Syst Rev. 2005(4). [pmid: 16235365].
19 North American Menopause S. The 2012 hormone therapy position statement of: The North American Menopause Society. Menopause. Mar. 2012;19(3):257-71. [pmid: 22367731].
20 Bioidentical hormones. Med Lett Drugs Ther. May. 31. 2010;52(1339):43-4. [pmid: 20508582].
21 Siyam T, Yuksel N. Abstract: Bioidentical Hormone Therapy: A Survey of Pharmacists Beliefs. Menopause. 2011;18(12):1. PMID:.
22 Iftikhar S, Shuster L, Johnson R, et al. Abstract: Use of Bio-identical Hormones in Patients Presenting to a Women's Health Clinic. Menopause. 207. 14(6):1. PMID:.
23 Galston SK. Federal and State Role in Pharmacy Compounding and Reconstitution: Exploring the Right Mix to Protect Patients. 2003. [cited 2014 October]; Available from: http://www.fda.gov/NewsEvents/Testimony/ucm115010.htm.
24 Patsner B. What every scientist should know about FDA. 2004. [cited 2014 October 13]; Available from: https://baylorcollegeofmedicine.org/pda/index.cfm?pmid=9920.
25 Nelson HD, Vesco KK, Haney E, et al. Nonhormonal therapies for menopausal hot flashes: systematic review and meta-analysis. JAMA. May. 3. 2006;295(17):2057-71. [pmid: 16670414].
26 Loprinzi CL, Sloan JA, Perez EA, et al. Phase III evaluation of fluoxetine for treatment of hot flashes. J Clin Oncol. Mar. 15. 2002;20(6):1578-83. [pmid: 11896107].
27 Bair YA, Gold EB, Zhang G, et al. Use of complementary and alternative medicine during the menopause transition: longitudinal results from the Study of Women's Health Across the Nation. Menopause. Jan-Feb. 2008;15(1):32-43. [pmid: 18090037].
28 Nelson HD, Walker M, Zakher B, et al. Menopausal Hormone Therapy for the Primary Prevention of Chronic Conditions: Systematic Review to Update the 2002 and 2005 US Preventive Services Task Force Recommendations. Rockville (MD). 2012.
29 Estrogen and progestogen use in postmenopausal women: 2010 position statement of The North American Menopause Society. Menopause. Mar. 2010;17(2):242-55. [pmid: 20154637].
30 Pines A, Sturdee DW, Birkhauser MH, et al. IMS updated recommendations on postmenopausal hormone therapy. Climacteric. Jun. 2007;10(3):181-94. [pmid: 17487645].
31 Santen RJ, Allred DC, Ardoin SP, et al. Postmenopausal hormone therapy: an Endocrine Society scientific statement. J Clin Endocrinol Metab. Jul. 2010;95(7 Suppl 1):s1-s66. [pmid: 20566620].
32 The American College of Obstetricians and Gynecologists Committee Opinion: Compounded Bioidentical Hormones. Obstetrics & Gynecology. 2005;106(5):2. PMID:. [pmid: 15994608].
33 U.S. FDA. Compounded Menopausal Hormone Therapy Questions and Answers. US Food and Drug Administration. 2010. [cited 2014 October]; Available from: http://www.fda.gov/Drugs/GuidanceComplianceRegulatoryInformation/PharmacyCompounding/ucm183088.htm.
34 Szmuilowicz ED, Manson JE, Rossouw JE, et al. Vasomotor symptoms and cardiovascular events in postmenopausal women. Menopause. Jun. 2011;18(6):603-10. [pmid: 21358352].
35 Welton AJ, Vickers MR, Kim J, et al. Health related quality of life after combined hormone replacement therapy: randomised controlled trial. BMJ. 2008;337:a1190. [pmid: 18719013].
36 Loprinzi CL, Diekmann B, Novotny PJ, et al. Newer antidepressants and gabapentin for hot flashes: a discussion of trial duration. Menopause. Sep-Oct. 2009;16(5):883-7. [pmid: 19295449].
37 AHRQ. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2014.
38 The Endocrine Society Position Statement: Bioidentical Hormones. 2006. [cited 2014 October]; Position Statement]. Available from: https://www.endocrine.org/~/media/endosociety/Files/Advocacy%20and%20Outreach/Position%20Statements/All/BH_Position_Statement_final_10_25_06_w_Header.pdf.
39 American Association of Clinical Endocrinologists (AACE) Reproductive Medicine Committee Position Statement on Bioidentical Hormones. 2007. [cited 2014 October]; Available from: https://www.aace.com/files/position-statements/aacebhstatement071507.pdf.
40 SPECIAL COMMITTEE ON AGING UNITED STATES SENATE. Bioidentical Hormones: Sound Science or Bad Medicine. 2007. [cited 2014 October]; Available from: www.aging.senate.gov/download/hearing-041907.
41 Somers S. Ageless: The Naked Truth About Bioidentical Hormones. 1st ed. New York. Crown Publishers. 2006.
42 Guttuso T Jr, Kurlan R, et al. Gabapentin's effects on hot flashes in postmenopausal women: a randomized controlled trial. Obstet Gynecol. Feb. 2003;(2):337-45. [pmid: 12576259].
43 Prentice RL. Observational studies, clinical trials, and the women's health initiative. Lifetime data analysis. Dec. 2007;13(4):449-62. [pmid: 17943443].
44 Tanaka S, Matsuyama Y, Shiraki M, et al. Estimating the effects of time-varying treatments: incidence of fractures among postmenopausal Japanese women. Epidemiology. Sep. 2007;18(5):529-36. [pmid: 17700241].
45 Hernán MA, Alonso A, Logan R, et al. Observational studies analyzed like randomized experiments: an application to postmenopausal hormone therapy and coronary heart disease. Epidemiology. Nov. 2008;19(6):766-79. [pmid: 18854702].
46 Morois S, Fournier A, Clavel-Chapelon F, et al. Menopausal hormone therapy and risks of colorectal adenomas and cancers in the French E3N prospective cohort: true associations or bias?. Eur J Epidemiol. Jun. 2012;27(6):439-52. [pmid: 22644109].
47 Prentice RL, Manson JE, Langer RD, et al. Benefits and risks of postmenopausal hormone therapy when it is initiated soon after menopause. Am J Epidemiol. Jul. 1. 2009;170(1):12-23. [pmid: 19468079].
48 Furness S, Roberts H, Marjoribanks J, et al. Hormone therapy in postmenopausal women and risk of endometrial hyperplasia. Cochrane Database Syst Rev. 2009(2):CD000402. [pmid: 19370558].
49 R Development Core Team. R: A Language and Environment for Statistical Computing. Vienna, Austria. R Foundation for Statistical Computing. 2014. Available from: http://www.R-project.org/.
50 Organization MMaSS. Introductory Guide to MeDRA Version 14.0. Chantilly, VA. International Federation of Pharmaceutical Manufacturers and Associations. 2011.
51 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. American journal of preventive medicine. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
52 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
53 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the risk of bias of individual studies in systematic reviews of health care interventions. In: Quality AfHRa, editor. 2012.
54 Hernán MA, Robins JM. Estimating causal effects from epidemiological data. Journal of epidemiology and community health. Jul. 2006;60(7):578-86. [pmid: 16790829].
55 Vandenbroucke JP. What is the best evidence for determining harms of medical treatment?. CMAJ : Canadian Medical Association journal = journal de l'Association medicale canadienne. Feb. 28. 2006;174(5):645-6. [pmid: 16505461].
56 Balshem H, Helfand M, Schunemann HJ, et al. GRADE guidelines: 3. Rating the quality of evidence. Journal of clinical epidemiology. Apr. 2011;64(4):401-6. [pmid: 21208779].
57 Gøtzsche PC, Hrobjartsson A, Maric K, et al. Data extraction errors in meta-analyses that use standardized mean differences. JAMA. Jul. 25. 2007;298(4):430-7. [pmid: 17652297].
58 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. Journal of clinical epidemiology. Nov. 2011;64(11):1187-97. [pmid: 21477993].
59 Schwarzer G. meta: Meta-Analysis with R (version 3.6-0). 2014. [cited 2014 July 31]; Available from: http://CRAN.R-project.org/package=meta.
60 Re ACD. compute.es: Compute Effect Sizes. 2013. [cited 2014 July 31]; Available from: http://CRAN.R-project.org/web/packages/compute.es.
61 Wickham H. ggplot2: elegant graphics for data analysis. Springer. New York. 2009.
62 Hedges LV, Vevea JL. Fixed- and random-effects models in meta-analysis. Psychol Meth. 1998;3(4):486-504. PMID: none.
63 Rucker G, Schwarzer G, Carpenter JR, et al. Undue reliance on I(2) in assessing heterogeneity may mislead. BMC Med Res Methodol. 2008;8:79. [pmid: 19036172].
64 Huntley AL, Ernst E. A systematic review of herbal medicinal products for the treatment of menopausal symptoms. Menopause. Sep-Oct. 2003;10(5):465-76. [pmid: 14501609].
65 Kupperman HS, Wetchler BB, Blatt MH. Contemporary therapy of the menopausal syndrome. Journal of the American Medical Association. Nov. 21. 1959;171:1627-37. [pmid: 14412840].
66 Morrison MF, Kallan MJ, Ten Have T, et al. Lack of efficacy of estradiol for depression in postmenopausal women: a randomized, controlled trial. Biological psychiatry. Feb. 15. 2004;55(4):406-12. [pmid: 14960294].
67 Zollner YF, Acquadro C, Schaefer M. Literature review of instruments to assess health-related quality of life during and after menopause. Quality of life research : an international journal of quality of life aspects of treatment, care and rehabilitation. Mar. 2005;14(2):309-27. [pmid: 15892422].
68 Hilditch JR, Lewis J, Peter A, et al. A menopause-specific quality of life questionnaire: development and psychometric properties. Maturitas. Sep-Oct. 2008;61(1-2):107-21. [pmid: 19434884].
69 Lewis JE, Hilditch JR, Wong CJ. Further psychometric property development of the Menopause-Specific Quality of Life questionnaire and development of a modified version, MENQOL-Intervention questionnaire. Maturitas. Mar. 14. 2005;50(3):209-21. [pmid: 15734602].
70 Wyrwich KW, Fihn SD, Tierney WM, et al. Clinically important changes in health-related quality of life for patients with chronic obstructive pulmonary disease: an expert consensus panel report. J Gen Intern Med. Mar. 2003;18(3):196-202. [pmid: 12648251].
71 Samsa G, Edelman D, Rothman ML, et al. Determining clinically important differences in health status measures: a general approach with illustration to the Health Utilities Index Mark II. PharmacoEconomics. Feb. 1999;15(2):141-55. [pmid: 10351188].
72 Levine DW, Dailey ME, Rockhill B, et al. Validation of the Women's Health Initiative Insomnia Rating Scale in a multicenter controlled clinical trial. Psychosomatic medicine. Jan-Feb. 2005;67(1):98-104. [pmid: 15673630].
73 DeRogatis LR, Graziottin A, Bitzer J, et al. Clinically relevant changes in sexual desire, satisfying sexual activity and personal distress as measured by the profile of female sexual function, sexual activity log, and personal distress scale in postmenopausal women with hypoactive sexual desire disorder. J Sex Med. Jan. 2009;6(1):175-83. [pmid: 19170847].
74 Song F, Altman DG, Glenny AM, et al. Validity of indirect comparison for estimating efficacy of competing interventions: empirical evidence from published meta-analyses. BMJ. Mar. 1. 2003;326(7387):472. [pmid: 12609941].
75 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. Journal of clinical epidemiology. May. 2010;63(5):513-23. [pmid: 19595577].
76 Treadwell JR, Uhl S, Tipton K, et al. Assessing equivalence and noninferiority. Journal of clinical epidemiology. Nov. 2012;65(11):1144-9. [pmid: 22732455].
77 Fu R, Vandermeer BW, Shamliyan TA, et al. Handling Continuous Outcomes in Quantitative Synthesis. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). 2013.
78 Moher D, Liberati A, Tetzlaff J, et al. Reprint--preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. Phys Ther. Sep. 2009;89(9):873-80. [pmid: 19723669].
79 Johnston BC, Patrick DL, Thorlund K, et al. Patient-reported outcomes in meta-analyses-part 2: methods for improving interpretability for decision-makers. Health Qual Life Outcomes. 2013;11:211. [pmid: 24359184].
80 Guyatt GH, Thorlund K, Oxman AD, et al. GRADE guidelines: 13. Preparing summary of findings tables and evidence profiles-continuous outcomes. Journal of clinical epidemiology. Feb. 2013;66(2):173-83. [pmid: 23116689].
81 Sloan JA, Loprinzi CL, Novotny PJ, et al. Methodologic lessons learned from hot flash studies. Journal of clinical oncology : official journal of the American Society of Clinical Oncology. Dec. 1. 2001;19(23):4280-90. [pmid: 11731510].
82 Carroll DG, Kelley KW. Use of antidepressants for management of hot flashes. Pharmacotherapy. Nov. 2009;29(11):1357-74. [pmid: 19857151].
83 Wyrwich KW, Spratt DI, Gass M, et al. Identifying meaningful differences in vasomotor symptoms among menopausal women. Menopause. Jul-Aug. 2008;15(4 Pt 1):698-705. [pmid: 18369313].
84 Oktem M, Eroglu D, Karahan HB, et al. Black cohosh and fluoxetine in the treatment of postmenopausal symptoms: a prospective, randomized trial. Adv Ther. Mar-Apr. 2007;(2):448-61. [pmid: 17565936].
85 Kaari C, Haidar MA, Junior JM, et al. Randomized clinical trial comparing conjugated equine estrogens and isoflavones in postmenopausal women: a pilot study. Maturitas. Jan. 2006;10(1):49-58. [pmid: 16257151].
86 Schellenberg R, Saller R, Hess L, et al. Dose-Dependent Effects of the Cimicifuga racemosa Extract Ze 450 in the Treatment of Climacteric Complaints: A Randomized, Placebo-Controlled Study. Evidence-based complementary and alternative medicine : eCAM. 2012;2012:260301. [pmid: 23346194].
87 Hidalgo LA, Chedraui PA, Morocho N, et al. The effect of red clover isoflavones on menopausal symptoms, lipids and vaginal cytology in menopausal women: a randomized, double-blind, placebo-controlled study. Gynecol Endocrinol. Nov. 2005;(5):257-64. [pmid: 16373244].
88 Wiklund IK, Mattsson LA, Lindgren R, et al. Effects of a standardized ginseng extract on quality of life and physiological parameters in symptomatic postmenopausal women: a double-blind, placebo-controlled trial. Swedish Alternative Medicine Group. Int J Clin Pharmacol Res. 1999(3):89-99. [pmid: 10761538].
89 Hartley DE, Elsabagh S, File SE. Gincosan (a combination of Ginkgo biloba and Panax ginseng): the effects on mood and cognition of 6 and 12 weeks' treatment in post-menopausal women. Nutr Neurosci. Oct-Dec. 2004;(5-6):325-33. [pmid: 15682929].
90 Odabasi AR, Yuksel H, Demircan SS, et al. A prospective randomized comparative study of the effects of intranasal and transdermal 17 beta-estradiol on postmenopausal symptoms and vaginal cytology. J Postgrad Med. Oct-Dec. 2007;(4):221-7. [pmid: 18097108].
91 Davis SR, Davison SL, Wilson S, et al. Intranasal versus transdermal matrix oestrogen replacement in Australasian women. Maturitas. Jun. 2005;16(2):163-71. [pmid: 15917157].
92 Ozsoy M, Oral B, Ozsoy D. Clinical equivalence of intranasal estradiol and oral estrogens for postmenopausal symptoms. Int J Gynaecol Obstet. Nov. 2002;(2):143-6. [pmid: 12427399].
93 Lopes P, Rozenberg S, Graaf J, et al. Aerodiol versus the transdermal route: perspectives for patient preference. Maturitas. Jun. 2001;15:S31-9. [pmid: 11390122].
94 Mattsson LA, Christiansen C, Colau JC, et al. Clinical equivalence of intranasal and oral 17beta-estradiol for postmenopausal symptoms. Am J Obstet Gynecol. Mar. 2000;(3):545-52. [pmid: 10739506].
95 Studd JW, McCarthy K, Zamblera D, et al. Efficacy and tolerance of Menorest compared to Premarin in the treatment of postmenopausal women. A randomised, multicentre, double-blind, double-dummy study. Maturitas. Sep. 1995;(2):105-14. [pmid: 8538478].
96 Parsey K, Ellman H, Rahman M. Randomised, controlled comparison of transdermal estradiol with oral conjugated estrogens for the relief of hot flushes. Clinical Drug Investigation. 2000;(4):207-14. PMID:.
97 Good WR, John VA, Ramirez M, et al. Comparison of Alora estradiol matrix transdermal delivery system with oral conjugated equine estrogen therapy in relieving menopausal symptoms. Alora Study Group. Climacteric. Mar. 1999;(1):29-36. [pmid: 11915854].
98 Serrano D, Mariani L, Mora S, et al. Quality of life assessment in a chemoprevention trial: fenretinide and oral or transdermal HRT. Maturitas. Aug. 2006;20(1):69-75. [pmid: 16500052].
99 Akhila V, Pratapkumar. A comparison of transdermal and oral HRT for menopausal symptom control. Int J Fertil Womens Med. Mar-Apr. 2006;(2):64-9. [pmid: 16881381].
100 Rozenberg S, Ylikorkala O, Arrenbrecht S. Comparison of continuous and sequential transdermal progestogen with sequential oral progestogen in postmenopausal women using continuous transdermal estrogen: vasomotor symptoms, bleeding patterns, and serum lipids. Int J Fertil Womens Med. 1997:376-87. [pmid: 9397385].
101 Gambacciani M, Spielmann D, Genazzani AR. Efficacy on climacteric symptoms of a continuous combined regimen of 1 mg 17beta-estradiol and trimegestone versus two regimens combining 1 or 2 mg 17beta-estradiol and norethisterone acetate. Gynecol Endocrinol. Aug. 2005;(2):65-73. [pmid: 16294457].
102 Benster B, Carey A, Wadsworth F, et al. A double-blind placebo-controlled study to evaluate the effect of progestelle progesterone cream on postmenopausal women. Menopause Int. Jun. 2009;15(2):63-9. [pmid: 19465671].
103 Wren BG, Champion SM, Willetts K, et al. Transdermal progesterone and its effect on vasomotor symptoms, blood lipid levels, bone metabolic markers, moods, and quality of life for postmenopausal women. Menopause. Jan-Feb. 2003;(1):13-8. [pmid: 12544672].
104 Leonetti HB, Longo S, Anasti JN. Transdermal progesterone cream for vasomotor symptoms and postmenopausal bone loss. Obstet Gynecol. Aug. 1999;(2):225-8. [pmid: 10432132].
105 Joffe H, Petrillo L, Viguera A, et al. Eszopiclone improves insomnia and depressive and anxious symptoms in perimenopausal and postmenopausal women with hot flashes: a randomized, double-blinded, placebo-controlled crossover trial. American Journal of Obstetrics & Gynecology. 2010;202(2):11. [pmid: 20035910].
106 Clayden JR, Bell JW, Pollard P. Menopausal flushing: double-blind trial of a non-hormonal medication. British medical journal. Mar. 9. 1974;1(5905):409-12. [pmid: 4593554].
107 Haines CJ, Lam PM, Chung TK, et al. A randomized, double-blind, placebo-controlled study of the effect of a Chinese herbal medicine preparation (Dang Gui Buxue Tang) on menopausal symptoms in Hong Kong Chinese women. Climacteric. Jun. 2008;11(3):244-51. [pmid: 18568789].
108 Garcia JT, Gonzaga F, Tan D, et al. Use of a multibotanical (Nutrafem) for the relief of menopausal vasomotor symptoms: a double-blind, placebo-controlled study. Menopause. Mar. 2010;(2):303-8. [pmid: 19934777].
109 van der Sluijs CP, Bensoussan A, Chang S, et al. A randomized placebo-controlled trial on the effectiveness of an herbal formula to alleviate menopausal vasomotor symptoms. Menopause. Mar-Apr. 2009;(2):336-44. [pmid: 19057416].
110 Yang HM, Liao MF, Zhu SY, et al. A randomised, double-blind, placebo-controlled trial on the effect of Pycnogenol on the climacteric syndrome in peri-menopausal women. Acta Obstet Gynecol Scand. 2007(8):978-85. [pmid: 17653885].
111 Mucci M, Carraro C, Mancino P, et al. Soy isoflavones, lactobacilli, Magnolia bark extract, vitamin D3 and calcium. Controlled clinical study in menopause. Minerva Ginecol. Aug. 2006;(4):323-34. [pmid: 16957676].
112 Heger M, Ventskovskiy BM, Borzenko I, et al. Efficacy and safety of a special extract of Rheum rhaponticum (ERr 731) in perimenopausal women with climacteric complaints: a 12-week randomized, double-blind, placebo-controlled trial. Menopause. Sep-Oct. 2006;(5):744-59. [pmid: 16894335].
113 Winther K, Rein E, Hedman C. Femal, a herbal remedy made from pollen extracts, reduces hot flushes and improves quality of life in menopausal women: a randomized, placebo-controlled, parallel study. Climacteric. Jun. 2005;(2):162-70. [pmid: 16096172].
114 Davis SR, Briganti EM, Chen RQ, et al. The effects of Chinese medicinal herbs on postmenopausal vasomotor symptoms of Australian women. A randomised controlled trial. Med J Aust. Jan. 2001;15(2):68-71. [pmid: 11245505].
115 Hirata JD, Swiersz LM, Zell B, et al. Does dong quai have estrogenic effects in postmenopausal women? A double-blind, placebo-controlled trial. Fertil Steril. Dec. 1997;(6):981-6. [pmid: 9418683].
116 Chenoy R, Hussain S, Tayob Y, et al. Effect of oral gamolenic acid from evening primrose oil on menopausal flushing. BMJ. Feb. 1994;19(6927):501-3. [pmid: 8136666].
117 Hsu CC, Kuo HC, Chang SY, et al. The assessment of efficacy of Diascorea alata for menopausal symptom treatment in Taiwanese women. Climacteric. Feb. 2011;(1):132-9. [pmid: 20653397].
118 Auerbach L, Rakus J, Bauer C, et al. Pomegranate seed oil in women with menopausal symptoms: a prospective randomized, placebo-controlled, double-blinded trial. Menopause. 2012. Jan. 11. [pmid: 22240636].
119 Chang A, Kwak BY, Yi K, et al. The Effect of Herbal Extract (EstroG-100) on Pre-, Peri- and Post-Menopausal Women: A Randomized Double-blind, Placebo-controlled Study. Phytother Res. 2011. Sep. 2. [pmid: 21887807].
120 Xia Y, Zhao Y, Ren M, et al. A randomized double-blind placebo-controlled trial of a Chinese herbal medicine preparation (Jiawei Qing'e Fang) for hot flashes and quality of life in perimenopausal women. Menopause. 2012(2):234-44. [pmid: 22089177].
121 von Hagens C, Schiller P, Godbillon B, et al. Treating menopausal symptoms with a complex remedy or placebo: a randomized controlled trial. Climacteric. Aug. 2012;15(4):358-67. [pmid: 22017387].
122 Yang H, Yang J, Wen Z, et al. Effect of combining therapy with traditional chinese medicine-based psychotherapy and herbal medicines in women with menopausal syndrome: a randomized controlled clinical trial. Evidence-based complementary and alternative medicine : eCAM. 2012;2012:354145. [pmid: 23304198].
123 Zhong LL, Tong Y, Tang GW, et al. A randomized, double-blind, controlled trial of a Chinese herbal formula (Er-Xian decoction) for menopausal symptoms in Hong Kong perimenopausal women. Menopause. Jul. 2013;20(7):767-76. [pmid: 23793167].
124 Plotnikoff GA, Watanabe K, Torkelson C, et al. The TU-025 keishibukuryogan clinical trial for hot flash management in postmenopausal women: Results and lessons for future research. Menopause. 2011(8):886-92. [pmid: 21738077].
125 Kohama T, Negami M. Effect of low-dose French maritime pine bark extract on climacteric syndrome in 170 perimenopausal women: a randomized, double-blind, placebo-controlled trial. The Journal of reproductive medicine. Jan-Feb. 2013;58(1-2):39-46. [pmid: 23447917].
126 Chung DJ, Kim HY, Park KH, et al. Black cohosh and St. John's wort (GYNO-Plus) for climacteric symptoms. Yonsei Med J. Apr. 2007;30(2):289-94. [pmid: 17461529].
127 Verhoeven MO, Mooren MJvd, Weijer PHvd, et al. Effect of a combination of isoflavones and Actaea racemosa Linnaeus on climacteric symptoms in healthy symptomatic perimenopausal women: a 12-week randomized, placebo-controlled, double-blind study. Menopause. Jul-Aug. 2005;(4):412-20. [pmid: 16037756].
128 Uebelhack R, Blohmer JU, Graubaum HJ, et al. Black cohosh and St. John's wort for climacteric complaints: a randomized trial. Obstet Gynecol. Feb. 2006;(2 Pt 1):247-55. [pmid: 16449108].
129 Die MDv, Burger HG, Bone KM, et al. Hypericum perforatum with Vitex agnus-castus in menopausal symptoms: a randomized, controlled trial. Menopause. Jan-Feb. 2009;(1):156-63. [pmid: 18791483].
130 Barnhart KT, Freeman E, Grisso JA, et al. The effect of dehydroepiandrosterone supplementation to symptomatic perimenopausal women on serum endocrine profiles, lipid parameters, and health-related quality of life. J Clin Endocrinol Metab. Nov. 1999;(11):3896-902. [pmid: 10566625].
131 Dodin S, Lemay A, Jacques H, et al. The effects of flaxseed dietary supplement on lipid profile, bone mineral density, and symptoms in menopausal women: a randomized, double-blind, wheat germ placebo-controlled clinical trial. J Clin Endocrinol Metab. Mar. 2005;(3):1390-7. [pmid: 15613422].
132 Andrikoula M, Baker D, Nesic J, et al. The effects of micronutrient supplementation on vasomotor symptoms in postmenopausal women. Climacteric. 2011(5):544-50. [pmid: 21413865].
133 Pandit S, Umbardand S, Ghodake V, et al. Evaluation of the efficacy and tolerability of micronutrient supplementation in treatment of post menopausal symptoms. Internet Journal of Genomics and Proteomics. 2012;6(2). PMID:.
134 Chandeying V, Sangthawan M. Efficacy comparison of Pueraria mirifica (PM) against conjugated equine estrogen (CEE) with/without medroxyprogesterone acetate (MPA) in the treatment of climacteric symptoms in perimenopausal women: phase III study. J Med Assoc Thai. Sep. 2007;(9):1720-6. [pmid: 17957910].
135 Menati L, Khaleghinezhad K, Tadayon M, et al. Evaluation of contextual and demographic factors on licorice effects on reducing hot flashes in postmenopause women. Health care for women international. Jan. 2014;35(1):87-99. [pmid: 23663094].
136 Virojchaiwong P, Suvithayasiri V, Itharat A. Comparison of Pueraria mirifica 25 and 50 mg for menopausal symptoms. Archives of Gynecology and Obstetrics. 2011(2):411-9. [pmid: 20872225].
137 Yang TS, Wang SY, Yang YC, et al. Effects of standardized phytoestrogen on Taiwanese menopausal women. Taiwanese journal of obstetrics & gynecology. Jun. 2012;51(2):229-35. [pmid: 22795099].
138 Agosta C, Atlante M, Benvenuti C. Randomized controlled study on clinical efficacy of isoflavones plus Lactobacillus sporogenes, associated or not with a natural anxiolytic agent in menopause. Minerva Ginecol. Feb. 2011;63(1):11-7. [pmid: 21311416].
139 Zervoudis SI, G., Navrozoglou I, Tsionis C, Chaniotis D, Diakakis I. Soja Isoflavones with Lactobascillus Sporogenes in Recent Menopause Women: Effects on Clinical Symptoms and Bone Density: A Comparative Prospective Study of 62 Patients. 12th World Congress on Menopause. Madrid, Spain. Climacteric. Climacteric. 2008:223. (Abstract PS-32).
140 Raynaud JP, Levrier M, Calaf J, et al. Comparison of the efficacy and tolerability of a new once-a-week matricial estradiol transdermal system (Estrapatch 40 and Estrapatch 60) with a twice week system. J Steroid Biochem Mol Biol. Feb. 2005;(2-5):309-18. [pmid: 15860275].
141 Hidalgo MJC, Castelo-Branco C, Blumel JE, et al. Effect of a compound containing isoflavones, primrose oil and vitamin E in two different doses on climacteric symptoms. J Obstet Gynaecol. May. 2006;(4):344-7. [pmid: 16753687].
142 Lobo RA, Rosen RC, Yang HM, et al. Comparative effects of oral esterified estrogens with and without methyltestosterone on endocrine profiles and dimensions of sexual function in postmenopausal women with hypoactive sexual desire. Fertil Steril. Jun. 2003;(6):1341-52. [pmid: 12798881].
143 Gupta B, Mittal P, Khuteta R, et al. A comparative study of CEE, tibolone, and DHEA as hormone replacement therapy for surgical menopause. Journal of Obstetrics and Gynecology of India. 2013;63(3):194-8. PMID:. [pmid: 24431637].
144 Brunner RL, Gass M, Aragaki A, et al. Effects of conjugated equine estrogen on health-related quality of life in postmenopausal women with hysterectomy: results from the Women's Health Initiative Randomized Clinical Trial. Arch Intern Med. Sep. 2005;26(17):1976-86. [pmid: 16186467].
145 Hays J, Ockene JK, Brunner RL, et al. Effects of estrogen plus progestin on health-related quality of life. N Engl J Med. May. 2003;8(19):1839-54. [pmid: 12642637].
146 Lubbert H, Nauert C. Continuous versus cyclical transdermal estrogen replacement therapy in postmenopausal women: influence on climacteric symptoms, body weight and bleeding pattern. Maturitas. Dec. 1997;15(2):117-25. [pmid: 9522319].
147 Polvani F, Zichella L, Bocci A, et al. A randomized comparative study for the clinical evaluation of hormone replacement by transdermal and oral routes. Clin Exp Obstet Gynecol. 1991(4):207-13. [pmid: 1790601].
148 Soares CN, Almeida OP, Joffe H, et al. Efficacy of estradiol for the treatment of depressive disorders in perimenopausal women: a double-blind, randomized, placebo-controlled trial. Arch Gen Psychiatry. Jun. 2001;(6):529-34. [pmid: 11386980].
149 Labrie F, Archer D, Bouchard C, et al. Effect of intravaginal dehydroepiandrosterone (Prasterone) on libido and sexual dysfunction in postmenopausal women. Menopause. Sep-Oct. 2009;(5):923-31. [pmid: 19424093].
150 Panjari M, Bell RJ, Jane F, et al. A randomized trial of oral DHEA treatment for sexual function, well-being, and menopausal symptoms in postmenopausal women with low libido. J Sex Med. Sep. 2009;(9):2579-90. [pmid: 19619146].
151 Sammartino A, Tommaselli GA, Gargano V, et al. Short-term effects of a combination of isoflavones, lignans and Cimicifuga racemosa on climacteric-related symptoms in postmenopausal women: a double-blind, randomized, placebo-controlled trial. Gynecol Endocrinol. Nov. 2006;(11):646-50. [pmid: 17145651].
152 Lewis JE, Nickell LA, Thompson LU, et al. A randomized controlled trial of the effect of dietary soy and flaxseed muffins on quality of life and hot flashes during menopause. Menopause. Jul-Aug. 2006;(4):631-42. [pmid: 16837885].
153 Shen CL, Chyu MC, Pence BC, et al. Green tea polyphenols supplementation and Tai Chi exercise for postmenopausal osteopenic women: safety and quality of life report. BMC Complement Altern Med. 2010:76. [pmid: 21143878].
154 Veerus P, Fischer K, Hovi SL, et al. Symptom reporting and quality of life in the Estonian Postmenopausal Hormone Therapy Trial. BMC Womens Health. 2008;5. [pmid: 18366766].
155 Liske E, Hanggi W, Zepelin HHH-v, et al. Physiological investigation of a unique extract of black cohosh (Cimicifugae racemosae rhizoma): a 6-month clinical study demonstrates no systemic estrogenic effect. J Womens Health Gend Based Med. Mar. 2002;(2):163-74. [pmid: 11975864].
156 Foidart JM, Vervliet J, Buytaert P. Efficacy of sustained-release vaginal oestriol in alleviating urogenital and systemic climacteric complaints. Maturitas. Jun. 1991;(2):99-107. [pmid: 1921739].
157 Greene JG. Constructing a standard climacteric scale. Maturitas. May. 20. 1998;29(1):25-31. [pmid: 9643514].
158 Beck AT, Epstein N, Brown G, et al. An inventory for measuring clinical anxiety: psychometric properties. J Consult Clin Psychol. Dec. 1988;56(6):893-7. [pmid: 3204199].
159 Beck AT, Ward CH, Mendelson M, et al. An inventory for measuring depression. Arch Gen Psychiatry. Jun. 1961;4(6):561-71. [pmid: 13688369].
160 Hamilton M. The assessment of anxiety states by rating. The British journal of medical psychology. 1959;32(1):50-5. [pmid: 13638508].
161 Hamilton M. A rating scale for depression. J Neurol Neurosurg Psychiatry. Feb. 1960;23(1):56-62. [pmid: 14399272].
162 Hays RD, Morales LS. The RAND-36 measure of health-related quality of life. Ann Med. Jul. 2001;33(5):350-7. [pmid: 11491194].
163 Kupperman HS. Comparative clinical evaluation of estrogenic preparations by the menopausal and amenorrheal indices. J Clin Endocrinol Metab. 1953;13:688-703. [pmid: 13061588].
164 Evans ML, Pritts E, Vittinghoff E, et al. Management of postmenopausal hot flushes with venlafaxine hydrochloride: a randomized, controlled trial. Obstet Gynecol. Jan. 2005;(1):161-6. [pmid: 15625158].
165 Kalay A, Demir B, Haberal A, et al. Efficacy of citalopram on climacteric symptoms. Menopause: The Journal of The North American Menopause Society. 2007;14(2):7. [pmid: 17224858].
166 Bouchard P, Panay N, Villiers TJD, et al. Randomized placebo- and active-controlled study of desvenlafaxine for menopausal vasomotor symptoms. Climacteric. 2012(1):12-20. [pmid: 22066790].
167 Freeman EW, Guthrie KA, Caan B, et al. Efficacy of escitalopram for hot flashes in healthy menopausal women: a randomized controlled trial. JAMA. Jan. 19. 2011;305(3):267-74. [pmid: 21245182].
168 Pinkerton JV, Archer DF, Guico-Pabia CJ, et al. Maintenance of the efficacy of desvenlafaxine in menopausal vasomotor symptoms: a 1-year randomized controlled trial. Menopause. Jan. 2013;20(1):38-46. [pmid: 23266839].
169 Suvanto-Luukkonen E, Koivunen R, Sundstrom H, et al. Citalopram and fluoxetine in the treatment of postmenopausal symptoms: a prospective, randomized, 9-month, placebo-controlled, double-blind study. Menopause. Jan-Feb. 2005;(1):18-26. [pmid: 15668596].
170 Soares CN, Joffe H, Viguera A, et al. Paroxetine Versus Placebo for Women in Midlife After Hormone Therapy Discontinuation. The American Journal of Medicine. 2008;121(2):5. [pmid: 18261506].
171 Archer DF, Dupont CM, Constantine GD, et al. Desvenlafaxine for the treatment of vasomotor symptoms associated with menopause: a double-blind, randomized, placebo-controlled trial of efficacy and safety. Am J Obstet Gynecol. Mar. 2009;(3):238 e1-e10. [pmid: 19167693].
172 Kornstein SG, Jiang Q, Reddy S, et al. Short-term efficacy and safety of desvenlafaxine in a randomized, placebo-controlled study of perimenopausal and postmenopausal women with major depressive disorder. The Journal of clinical psychiatry. Aug. 2010;71(8):1088-96. [pmid: 20797382].
173 Wiklund I, Karlberg J, Mattsson LA. Quality of life of postmenopausal women on a regimen of transdermal estradiol therapy: a double-blind placebo-controlled study. Am J Obstet Gynecol. Mar. 1993;(3 Pt 1):824-30. [pmid: 8456888].
174 Derman RJ, Dawood MY, Stone S. Quality of life during sequential hormone replacement therapy -- a placebo-controlled study. Int J Fertil Menopausal Stud. Mar-Apr. 1995;(2):73-8. [pmid: 7599662].
175 Baerug U, Winge T, Nordland G, et al. Do combinations of 1 mg estradiol and low doses of NETA effectively control menopausal symptoms?. Climacteric. Sep. 1998;(3):219-28. [pmid: 11907946].
176 Rozenbaum H, Chevallier O, Moyal M, et al. Efficacy and tolerability of pulsed estrogen therapy: a 12-week double-blind placebo-controlled study in highly symptomatic postmenopausal women. Climacteric. Sep. 2002;(3):249-58. [pmid: 12419083].
177 Gelfand MM, Moreau M, Ayotte NJ, et al. Clinical assessment and quality of life of postmenopausal women treated with a new intermittent progestogen combination hormone replacement therapy: a placebo-controlled study. Menopause. Jan-Feb. 2003;10(1):29-36. [pmid: 12544674].
178 Haines CJ, Yim SF, Chung TK, et al. A prospective, randomized, placebo-controlled study of the dose effect of oral oestradiol on menopausal symptoms, psychological well being, and quality of life in postmenopausal Chinese women. Maturitas. Mar. 2003;28(3):207-14. [pmid: 12648884].
179 Speroff L. Efficacy and tolerability of a novel estradiol vaginal ring for relief of menopausal symptoms. Obstet Gynecol. Oct. 2003;102(4):823-34. [pmid: 14551014].
180 Yang TS, Wang HL, Chen YJ, et al. Effect of continuous administration of conjugated estrogen plus medroxyprogesterone acetate (Premelle) in postmenopausal women in Taiwan. J Chin Med Assoc. Jul. 2004;(7):336-43. [pmid: 15510930].
181 Nielsen TF, Ravn P, Pitkin J, et al. Pulsed estrogen therapy improves postmenopausal quality of life: a 2-year placebo-controlled study. Maturitas. Jan. 2006;20(2):184-90. [pmid: 16368471].
182 Simon JA, Bouchard C, Waldbaum A, et al. Low dose of transdermal estradiol gel for treatment of symptomatic postmenopausal women: a randomized controlled trial. Obstet Gynecol. Mar. 2007;(3):588-96. [pmid: 17329509].
183 Utian W, Yu H, Bobula J, et al. Bazedoxifene/conjugated estrogens and quality of life in postmenopausal women. Maturitas. Aug. 20. 2009;63(4):329-35. [pmid: 19647382].
184 Bachmann G, Bobula J, Mirkin S. Effects of bazedoxifene/conjugated estrogens on quality of life in postmenopausal women with symptoms of vulvar/vaginal atrophy. Climacteric. Apr. 2010;13(2):132-40. [pmid: 19863455].
185 Demetrio FN, Renno J Jr, Gianfaldoni A, et al. Effect of estrogen replacement therapy on symptoms of depression and anxiety in non-depressive menopausal women: a randomized double-blind, controlled study. Arch Womens Ment Health. Dec. 2011;14(6):479-86. [pmid: 22016254].
186 Pinkerton JV, Pan K, Abraham L, et al. Sleep parameters and health-related quality of life with bazedoxifene/conjugated estrogens: a randomized trial. Menopause. 2013. Aug. 12. [pmid: 23942245].
187 Campbell S, Whitehead, et al. Oestrogen therapy and the menopausal syndrome. Clin Obstet Gynaecol. Apr. 1977;(1):31-47. [pmid: 322905].
188 Coope J. Is oestrogen therapy effective in the treatment of menopausal depression?. J R Coll Gen Pract. Mar. 1981;(224):134-40. [pmid: 6268783].
189 Saletu B, Brandstatter N, Metka M, et al. Double-blind, placebo-controlled, hormonal, syndromal and EEG mapping studies with transdermal oestradiol therapy in menopausal depression. Psychopharmacology (Berl). Dec. 1995;(4):321-9. [pmid: 8657828].
190 Bech P, Munk-Jensen N, Obel EB, et al. Combined versus sequential hormonal replacement therapy: a double-blind, placebo-controlled study on quality of life-related outcome measures. Psychother Psychosom. Jul-Oct. 1998;(4-5):259-65. [pmid: 9693354].
191 Polo-Kantola P, Erkkola R, Irjala K, et al. Effect of short-term transdermal estrogen replacement therapy on sleep: a randomized, double-blind crossover trial in postmenopausal women. Fertil Steril. May. 1999;(5):873-80. [pmid: 10231049].
192 Gambacciani M, Ciaponi M, Cappagli B, et al. Effects of low-dose, continuous combined estradiol and noretisterone acetate on menopausal quality of life in early postmenopausal women. Maturitas. Feb. 2003;25(2):157-63. [pmid: 12590012].
193 Rudolph I, Palombo-Kinne E, Kirsch B, et al. Influence of a continuous combined HRT (2 mg estradiol valerate and 2 mg dienogest) on postmenopausal depression. Climacteric. Sep. 2004;(3):301-11. [pmid: 15669555].
194 Onalan G, Onalan R, Selam B, et al. Mood scores in relation to hormone replacement therapies during menopause: a prospective randomized trial. Tohoku J Exp Med. Nov. 2005;(3):223-31. [pmid: 16210834].
195 Pefanco MA, Kenny AM, Kaplan RF, et al. The effect of 3-year treatment with 0.25 mg/day of micronized 17beta-estradiol on cognitive function in older postmenopausal women. J Am Geriatr Soc. Mar. 2007;(3):426-31. [pmid: 17341247].
196 Baksu B, Baksu A, Goker N, et al. Do different delivery systems of hormone therapy have different effects on psychological symptoms in surgically menopausal women? A randomized controlled trial. Maturitas. Feb. 2009;20(2):140-5. [pmid: 19179026].
197 Hassa H, Tanir HM, Oge T. Is placebo as effective as estrogen regimens on vasomotor symptoms in women with surgical menopause?. Clin Exp Obstet Gynecol. 2010(2):135-7. [pmid: 21077506].
198 Polisseni AF, Andrade AT, Ribeiro LC, et al. Effects of a continuous-combined regimen of low-dose hormone therapy (oestradiol and norethindrone acetate) and tibolone on the quality of life in symptomatic postmenopausal women: a double-blind, randomised study. Maturitas. Feb. 2013;74(2):172-8. [pmid: 23201326].
199 Strickler R, Stovall DW, Merritt D, et al. Raloxifene and estrogen effects on quality of life in healthy postmenopausal women: a placebo-controlled randomized trial. Obstet Gynecol. Sep. 2000;(3):359-65. [pmid: 10960626].
200 Butt D, Deng L, Lewis J, et al. Minimal decrease in hot flashes desired by postmenopausal women in family practice. Menopause: The Journal of The North American Menopause Society. 2007;14(2):5. [pmid: 17099324].
201 Tice JA, Ettinger B, Ensrud K, et al. Phytoestrogen supplements for the treatment of hot flashes: the Isoflavone Clover Extract (ICE) Study: a randomized controlled trial. JAMA. Jul. 2003;9(2):207-14. [pmid: 12851275].
202 Kok L, Kreijkamp-Kaspers S, Grobbee DE, et al. A randomized, placebo-controlled trial on the effects of soy protein containing isoflavones on quality of life in postmenopausal women. Menopause. Jan-Feb. 2005;(1):56-62. [pmid: 15668601].
203 Ho SC, Chan AS, Ho YP, et al. Effects of soy isoflavone supplementation on cognitive function in Chinese postmenopausal women: a double-blind, randomized, controlled trial. Menopause. May-Jun. 2007;(3 Pt 1):489-99. [pmid: 17308499].
204 Basaria S, Wisniewski A, Dupree K, et al. Effect of high-dose isoflavones on cognition, quality of life, androgens, and lipoprotein in post-menopausal women. J Endocrinol Invest. Feb. 2009;(2):150-5. [pmid: 19411814].
205 Evans M, Elliott JG, Sharma P, et al. The effect of synthetic genistein on menopause symptom management in healthy postmenopausal women: a multi-center, randomized, placebo-controlled study. Maturitas. Feb. 2011;(2):189-96. [pmid: 21163595].
206 Amato P, Young RL, Steinberg FM, et al. Effect of soy isoflavone supplementation on menopausal quality of life. Menopause. Apr. 2013;20(4):443-7. [pmid: 23211877].
207 Kotsopoulos D, Dalais FS, Liang YL, et al. The effects of soy protein containing phytoestrogens on menopausal symptoms in postmenopausal women. Climacteric. Sep. 2000;(3):161-7. [pmid: 11910617].
208 Sousa-Munoz RLd, Filizola RG. Efficacy of soy isoflavones for depressive symptoms of the climacteric syndrome. Maturitas. May. 2009;20(1):89-93. [pmid: 19339127].
209 Lipovac M, Chedraui P, Gruenhut C, et al. Improvement of postmenopausal depressive and anxiety symptoms after treatment with isoflavones derived from red clover extracts. Maturitas. Mar. 2010;(3):258-61. [pmid: 19948385].
210 Jassi HK, Jain A, Arora S, et al. Effect of soy proteins Vs soy isoflavones on lipid profile in postmenopausal women. Indian Journal of Clinical Biochemistry. 2010(2):201-7. [pmid: 23105910].
211 Chi XX, Zhang T. The effects of soy isoflavone on bone density in north region of climacteric Chinese women. J Clin Biochem Nutr. Sep. 2013;53(2):102-7. [pmid: 24062607].
212 Casini ML, Marelli G, Papaleo E, et al. Psychological assessment of the effects of treatment with phytoestrogens on postmenopausal women: a randomized, double-blind, crossover, placebo-controlled study. Fertil Steril. Apr. 2006;(4):972-8. [pmid: 16580383].
213 Nathorst-Boos J, Floter A, Jarkander-Rolff M, et al. Treatment with percutanous testosterone gel in postmenopausal women with decreased libido--effects on sexuality and psychological general well-being. Maturitas. Jan. 2006;10(1):11-8. [pmid: 16183220].
214 Zheng TP, Sun AJ, Xue W, et al. Efficacy and safety of Cimicifuga foetida extract on menopausal syndrome in Chinese women. Chinese medical journal. 2013;126(11):2034-8. [pmid: 23769553].
215 Nappi RE, Malavasi B, Brundu B, et al. Efficacy of Cimicifuga racemosa on climacteric complaints: a randomized study versus low-dose transdermal estradiol. Gynecol Endocrinol. Jan. 2005;(1):30-5. [pmid: 15969244].
216 Osmers R, Friede M, Liske E, et al. Efficacy and safety of isopropanolic black cohosh extract for climacteric symptoms. Obstet Gynecol. May. 2005;(5 Pt 1):1074-83. [pmid: 15863547].
217 Soares CN. Desvenlafaxine and escitalopram for the treatment of postmenopausal women with major depressive disorder. Menopause. 2010;17(4):700-11. [pmid: 20539246].
218 Raz. Effects of menopausal hormone therapy on serum serotinin and self-report depression in healthy, recently menopausal women. J of Women's Health. 2013;22(3):18. PMID:.
219 Yalamanchili V, Gallagher JC. Treatment with hormone therapy and calcitriol did not affect depression in older postmenopausal women: no interaction with estrogen and vitamin D receptor genotype polymorphisms. Menopause. Jun. 2012;19(6):697-703. [pmid: 22205149].
220 Bachmann G, Bouchard C, Hoppe D, et al. Efficacy and safety of low-dose regimens of conjugated estrogens cream administered vaginally. Menopause. Jul-Aug. 2009;(4):719-27. [pmid: 19436223].
221 Freedman M, Kaunitz AM, Reape KZ, et al. Twice-weekly synthetic conjugated estrogens vaginal cream for the treatment of vaginal atrophy. Menopause. Jul-Aug. 2009;(4):735-41. [pmid: 19252451].
222 Dessole S, Rubattu G, Ambrosini G, et al. Efficacy of low-dose intravaginal estriol on urogenital aging in postmenopausal women. Menopause. Jan-Feb. 2004;(1):49-56. [pmid: 14716182].
223 Simunic V, Banovic I, Ciglar S, et al. Local estrogen treatment in patients with urogenital symptoms. Int J Gynaecol Obstet. Aug. 2003;(2):187-97. [pmid: 12873780].
224 Casper F, Petri E. Local treatment of urogenital atrophy with an estradiol-releasing vaginal ring: a comparative and a placebo-controlled multicenter study. Vaginal Ring Study Group. Int Urogynecol J Pelvic Floor Dysfunct. 1999(3):171-6. [pmid: 10430010].
225 Eriksen PS, Rasmussen H. Low-dose 17 beta-estradiol vaginal tablets in the treatment of atrophic vaginitis: a double-blind placebo controlled study. Eur J Obstet Gynecol Reprod Biol. Apr. 1992;21(2):137-44. [pmid: 1587379].
226 Parsons A, Merritt D, Rosen A, et al. Effect of raloxifene on the response to conjugated estrogen vaginal cream or nonhormonal moisturizers in postmenopausal vaginal atrophy. Obstet Gynecol. Feb. 2003;(2):346-52. [pmid: 12576260].
227 Cano A, Estevez J, Usandizaga R, et al. The therapeutic effect of a new ultra low concentration estriol gel formulation (0.005% estriol vaginal gel) on symptoms and signs of postmenopausal vaginal atrophy: results from a pivotal phase III study. Menopause. Oct. 2012;19(10):1130-9. [pmid: 22914208].
228 Vestergaard P, Hermann AP, Stilgren L, et al. Effects of 5 years of hormonal replacement therapy on menopausal symptoms and blood pressure-a randomised controlled study. Maturitas. Oct. 2003;20(2):123-32. [pmid: 14559383].
229 Simon JA, Reape KZ, Wininger S, et al. Randomized, multicenter, double-blind, placebo-controlled trial to evaluate the efficacy and safety of synthetic conjugated estrogens B for the treatment of vulvovaginal atrophy in healthy postmenopausal women. Fertil Steril. Oct. 2008;90(4):1132-8. [pmid: 18053998].
230 Gast MJ, Freedman MA, Vieweg AJ, et al. A randomized study of low-dose conjugated estrogens on sexual function and quality of life in postmenopausal women. Menopause. Mar-Apr. 2009;(2):247-56. [pmid: 19034054].
231 Haines C, Yu SL, Hiemeyer F, et al. Micro-dose transdermal estradiol for relief of hot flushes in postmenopausal Asian women: a randomized controlled trial. Climacteric. Oct. 2009;(5):419-26. [pmid: 19479489].
232 Raghunandan C, Agrawal S, Dubey P, et al. A comparative study of the effects of local estrogen with or without local testosterone on vulvovaginal and sexual dysfunction in postmenopausal women. J Sex Med. Mar. 2010;(3):1284-90. [pmid: 20102444].
233 Osmanagaoglu MA, Atasaral T, Baltaci D, et al. Effect of different preparations of hormone therapy on sexual dysfunction in naturally postmenopausal women. Climacteric. Dec. 2006;(6):464-72. [pmid: 17085380].
234 Maki PM, Gast MJ, Vieweg AJ, et al. Hormone therapy in menopausal women with cognitive complaints: a randomized, double-blind trial. Neurology. Sep. 2007;25(13):1322-30. [pmid: 17893293].
235 Archer DF, Seidman L, Constantine GD, et al. A double-blind, randomly assigned, placebo-controlled study of desvenlafaxine efficacy and safety for the treatment of vasomotor symptoms associated with menopause. Am J Obstet Gynecol. Feb. 2009;(2):172 e1-10. [pmid: 19110224].
236 Cianci A, Cicero AF, Colacurci N, et al. Activity of isoflavones and berberine on vasomotor symptoms and lipid profile in menopausal women. Gynecol Endocrinol. 2012. Feb. 8. [pmid: 22313171].
237 Colacurci N, De Franciscis P, Atlante M, et al. Endometrial, breast and liver safety of soy isoflavones plus Lactobacillus sporogenes in post-menopausal women. Gynecol Endocrinol. Mar. 2013;29(3):209-12. [pmid: 23194023].
238 Davis SR, Mooren MJvd, Lunsen RHv, et al. Efficacy and safety of a testosterone patch for the treatment of hypoactive sexual desire disorder in surgically menopausal women: a randomized, placebo-controlled trial. Menopause. May-Jun. 2006;(3):387-96. [pmid: 16735935].
239 Braunstein GD, Sundwall DA, Katz M, et al. Safety and efficacy of a testosterone patch for the treatment of hypoactive sexual desire disorder in surgically menopausal women: a randomized, placebo-controlled trial. Arch Intern Med. Jul. 2005;25(14):1582-9. [pmid: 16043675].
240 Simon J, Braunstein G, Nachtigall L, et al. Testosterone patch increases sexual activity and desire in surgically menopausal women with hypoactive sexual desire disorder. J Clin Endocrinol Metab. Sep. 2005;(9):5226-33. [pmid: 16014407].
241 Buster JE, Kingsberg SA, Aguirre O, et al. Testosterone patch for low sexual desire in surgically menopausal women: a randomized trial. Obstet Gynecol. May. 2005;(5 Pt 1):944-52. [pmid: 15863529].
242 Panay N, Al-Azzawi F, Bouchard C, et al. Testosterone treatment of HSDD in naturally menopausal women: the ADORE study. Climacteric. Apr. 2010;(2):121-31. [pmid: 20166859].
243 Penteado SR, Fonseca AM, Bagnoli VR, et al. Effects of the addition of methyltestosterone to combined hormone therapy with estrogens and progestogens on sexual energy and on orgasm in postmenopausal women. Climacteric. Feb. 2008;(1):17-25. [pmid: 18202961].
244 Davis SR, Moreau M, Kroll R, et al. Testosterone for low libido in postmenopausal women not taking estrogen. N Engl J Med. Nov. 2008;6(19):2005-17. [pmid: 18987368].
245 Shifren JL, Davis SR, Moreau M, et al. Testosterone patch for the treatment of hypoactive sexual desire disorder in naturally menopausal women: results from the INTIMATE NM1 Study. Menopause. Sep-Oct. 2006;(5):770-9. [pmid: 16932240].
246 Cieraad D, Conradt C, Jesinger D, et al. Clinical study comparing the effects of sequential hormone replacement therapy with oestradiol/dydrogesterone and conjugated equine oestrogen/norgestrel on lipids and symptoms. Arch Gynecol Obstet. May. 2006;(2):74-80. [pmid: 16491367].
247 Utian WH, Speroff L, Ellman H, et al. Comparative controlled trial of a novel oral estrogen therapy, estradiol acetate, for relief of menopause symptoms. Menopause. Nov-Dec. 2005;(6):708-15. [pmid: 16278614].
248 Loh FH, Chen LH, Yu SL, et al. The efficacy of two dosages of a continuous combined hormone replacement regimen. Maturitas. Feb. 2002;26(2):123-31. [pmid: 11836043].
249 Limpaphayom KK, Darmasetiawan MS, Hussain RI, et al. Differential prevalence of quality-of-life categories (domains) in Asian women and changes after therapy with three doses of conjugated estrogens/medroxyprogesterone acetate: the Pan-Asia Menopause (PAM) study. Climacteric. Jun. 2006;(3):204-14. [pmid: 16766434].
250 Pitkin J, Smetnik VP, Vadasz P, et al. Continuous combined hormone replacement therapy relieves climacteric symptoms and improves health-related quality of life in early postmenopausal women. Menopause Int. Sep. 2007;(3):116-23. [pmid: 17785037].
251 Barentsen R, van de Weijer PH, Schram JH. Continuous low dose estradiol released from a vaginal ring versus estriol vaginal cream for urogenital atrophy. Eur J Obstet Gynecol Reprod Biol. Jan. 1997;71(1):73-80. [pmid: 9031963].
252 Ayton RA, Darling GM, Murkies AL, et al. A comparative study of safety and efficacy of continuous low dose oestradiol released from a vaginal ring compared with conjugated equine oestrogen vaginal cream in the treatment of postmenopausal urogenital atrophy. Br J Obstet Gynaecol. Apr. 1996;(4):351-8. [pmid: 8605133].
253 Hilditch JR, Lewis J, Ross AH, et al. A comparison of the effects of oral conjugated equine estrogen and transdermal estradiol-17 beta combined with an oral progestin on quality of life in postmenopausal women. Maturitas. Jul. 1996;(3):177-84. [pmid: 8844631].
254 Buckler H, Al-Azzawi F. The effect of a novel vaginal ring delivering oestradiol acetate on climacteric symptoms in postmenopausal women. BJOG. Aug. 2003;(8):753-9. [pmid: 12892687].
255 Weisberg E, Ayton R, Darling G, et al. Endometrial and vaginal effects of low-dose estradiol delivered by vaginal ring or vaginal tablet. Climacteric. Mar. 2005;(1):83-92. [pmid: 15804736].
256 Long CY, Liu CM, Hsu SC, et al. A randomized comparative study of the effects of oral and topical estrogen therapy on the vaginal vascularization and sexual function in hysterectomized postmenopausal women. Menopause. Sep-Oct. 2006;(5):737-43. [pmid: 16946685].
257 Henriksson L, Stjernquist M, Boquist L, et al. A comparative multicenter study of the effects of continuous low-dose estradiol released from a new vaginal ring versus estriol vaginal pessaries in postmenopausal women with symptoms and signs of urogenital atrophy. Am J Obstet Gynecol. Sep. 1994;(3):624-32. [pmid: 8092207].
258 Constantine G, Graham S, Koltun WD, et al. Assessment of Ospemifene or Lubricants on Clinical Signs of VVA. J Sex Med. 2014. Jan. 21. [pmid: 24443923].
259 Lima SM, Yamada SS, Reis BF, et al. Effective treatment of vaginal atrophy with isoflavone vaginal gel. Maturitas. 2013. Jan. 8. [pmid: 23312487].
260 Bachmann G, Lobo RA, Gut R, et al. Efficacy of low-dose estradiol vaginal tablets in the treatment of atrophic vaginitis: a randomized controlled trial. Obstet Gynecol. Jan. 2008;(1):67-76. [pmid: 18165394].
261 Chung TK, Yip SK, Lam P, et al. A randomized, double-blind, placebo-controlled, crossover study on the effect of oral oestradiol on acute menopausal symptoms. Maturitas. Oct. 1996;(2):115-23. [pmid: 8905602].
262 von Holst T, Salbach B. Efficacy and tolerability of a new 7-day transdermal estradiol patch versus placebo in hysterectomized women with postmenopausal complaints. Maturitas. Feb. 15. 2000;34(2):143-53. [pmid: 10714909].
263 Schurmann R, Holler T, Benda N. Estradiol and drospirenone for climacteric symptoms in postmenopausal women: a double-blind, randomized, placebo-controlled study of the safety and efficacy of three dose regimens. Climacteric. Jun. 2004;(2):189-96. [pmid: 15497908].
264 Lee BS, Kang BM, Yoon BK, et al. Efficacy and tolerability of estradiol 1 mg and drospirenone 2 mg in postmenopausal Korean women: a double-blind, randomized, placebo-controlled, multicenter study. Maturitas. Aug. 2007;20(4):361-9. [pmid: 17467203].
265 Lin SQ, Sun LZ, Lin JF, et al. Estradiol 1mg and drospirenone 2mg as hormone replacement therapy in postmenopausal Chinese women. Climacteric. 2011(4):472-81. [pmid: 21469973].
266 Lee J, Kim KW, Kim HK, et al. The effect of Rexflavone (Sophorae fructus extract) on menopausal symptoms in postmenopausal women: a randomized double-blind placebo controlled clinical trial. Arch Pharm Res. Apr. 2010;(4):523-30. [pmid: 20422360].
267 Dugal R, Hesla K, Sordal T, et al. Comparison of usefulness of estradiol vaginal tablets and estriol vagitories for treatment of vaginal atrophy. Acta Obstet Gynecol Scand. Apr. 2000;(4):293-7. [pmid: 10746845].
268 Shulman LP, Yankov V, Uhl K. Safety and efficacy of a continuous once-a-week 17beta-estradiol/levonorgestrel transdermal system and its effects on vasomotor symptoms and endometrial safety in postmenopausal women: the results of two multicenter, double-blind, randomized, controlled trials. Menopause. May-Jun. 2002;(3):195-207. [pmid: 11973443].
269 Donne ML, Caruso C, Mancuso A, et al. The effect of vaginally administered genistein in comparison with hyaluronic acid on atrophic epithelium in postmenopause. Arch Gynecol Obstet. Jun. 2011;(6):1319-23. [pmid: 20577750].
270 Hunter MS. The Women's Health Questionnaire (WHQ): Frequently Asked Questions (FAQ). Health Qual Life Outcomes. 2003;1(41):41. [pmid: 14521718].
271 Panay N, Ylikorkala O, Archer DF, et al. Ultra-low-dose estradiol and norethisterone acetate: effective menopausal symptom relief. Climacteric. Apr. 2007;(2):120-31. [pmid: 17453860].
272 Pornel B, Spielmann D. A study of the control of climacteric symptoms in postmenopausal women following sequential regimens of 1 mg 17beta-estradiol and trimegestone compared with a regimen containing 1 mg estradiol valerate and norethisterone over a two-year period. Gynecol Endocrinol. Aug. 2005;(2):74-81. [pmid: 16294458].
273 Pinkerton JV, Kagan R, Portman D, et al. Phase 3 randomized controlled study of gastroretentive gabapentin for the treatment of moderate-to-severe hot flashes in menopause. Menopause. 2013. PMID:.
274 Han KK, Soares JM Jr, et al. Benefits of soy isoflavone therapeutic regimen on menopausal symptoms. Obstet Gynecol. Mar. 2002;(3):389-94. [pmid: 11864664].
275 White CM, Ip S, McPheeters M, et al. Using Existing Systematic Reviews To Replace De Novo Processes in Conducting Comparative Effectiveness Reviews. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). 2008.
276 Chlebowski RT, Anderson GL, Gass M, et al. Estrogen plus progestin and breast cancer incidence and mortality in postmenopausal women. JAMA. Oct. 2010;20(15):1684-92. [pmid: 20959578].
277 Cirillo DJ, Wallace RB, Rodabough RJ, et al. Effect of estrogen therapy on gallbladder disease. JAMA. Jan. 19. 2005;293(3):330-9. [pmid: 15657326].
278 Heiss G, Wallace R, Anderson GL, et al. Health risks and benefits 3 years after stopping randomized treatment with estrogen and progestin. JAMA. Mar. 5. 2008;299(9):1036-45. [pmid: 18319414].
279 Anderson GL, Judd HL, Kaunitz AM, et al. Effects of estrogen plus progestin on gynecologic cancers and associated diagnostic procedures: the Women's Health Initiative randomized trial. JAMA. Oct. 1. 2003;290(13):1739-48. [pmid: 14519708].
280 Anderson GL, Limacher M, Assaf AR, et al. Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women's Health Initiative randomized controlled trial. JAMA. Apr. 14. 2004;291(14):1701-12. [pmid: 15082697].
281 LaCroix AZ, Chlebowski RT, Manson JE, et al. Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy: a randomized controlled trial. JAMA. Apr. 2011;6(13):1305-14. [pmid: 21467283].
282 Shumaker SA, Legault C, Rapp SR, et al. Estrogen plus progestin and the incidence of dementia and mild cognitive impairment in postmenopausal women: the Women's Health Initiative Memory Study: a randomized controlled trial. JAMA. May. 28. 2003;289(20):2651-62. [pmid: 12771112].
283 Espeland MA, Brunner RL, Hogan PE, et al. Long-term effects of conjugated equine estrogen therapies on domain-specific cognitive function: results from the Women's Health Initiative study of cognitive aging extension. J Am Geriatr Soc. Jul. 2010;58(7):1263-71. [pmid: 20649689].
284 Grady D, Applegate W, Bush T, et al. Heart and Estrogen/progestin Replacement Study (HERS): design, methods, and baseline characteristics. Controlled clinical trials. Aug. 1998;19(4):314-35. [pmid: 9683309].
285 Hulley S, Furberg C, Barrett-Connor E, et al. Noncardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II). JAMA. Jul. 3. 2002;288(1):58-66. [pmid: 12090863].
286 Vickers MR, Martin J, Meade TW, et al. The Women's international study of long-duration oestrogen after menopause (WISDOM): a randomised controlled trial. BMC Womens Health. 2007;7:2. [pmid: 17324282].
287 Cherry N, Gilmour K, Hannaford P, et al. Oestrogen therapy for prevention of reinfarction in postmenopausal women: a randomised placebo controlled trial. Lancet. Dec. 21-28. 2002;360(9350):2001-8. [pmid: 12504395].
288 Tierney MC, Oh P, Moineddin R, et al. A randomized double-blind trial of the effects of hormone therapy on delayed verbal recall in older women. Psychoneuroendocrinology. Aug. 2009;34(7):1065-74. [pmid: 19297102].
289 Ettinger B, Ensrud KE, Wallace R, et al. Effects of ultralow-dose transdermal estradiol on bone mineral density: a randomized clinical trial. Obstet Gynecol. Sep. 2004;104(3):443-51. [pmid: 15339752].
290 Anderson GL, Chlebowski RT, Aragaki AK, et al. Conjugated equine oestrogen and breast cancer incidence and mortality in postmenopausal women with hysterectomy: extended follow-up of the Women's Health Initiative randomised placebo-controlled trial. The Lancet Oncology. 2012. [pmid: 22401913].
291 Marjoribanks J, Farquhar C, Roberts H, et al. Long term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database Syst Rev. 2012;7(7):CD004143. [pmid: 22786488].
292 Hansson L, Hedner T, Dahlof B. Prospective randomized open blinded end-point (PROBE) study. A novel design for intervention trials. Prospective Randomized Open Blinded End-Point. Blood pressure. Aug. 1992;1(2):113-9. [pmid: 1366259].
293 Schierbeck LL, Rejnmark L, Tofteng CL, et al. Effect of hormone replacement therapy on cardiovascular events in recently postmenopausal women: randomised trial. BMJ. 2012;345:e6409. [pmid: 23048011].
294 Simon MS, Chlebowski RT, Wactawski-Wende J, et al. Estrogen plus progestin and colorectal cancer incidence and mortality. J Clin Oncol. Nov. 10. 2012;30(32):3983-90. [pmid: 23008295].
295 Greiser CM, Greiser EM, Doren M. Menopausal hormone therapy and risk of ovarian cancer: systematic review and meta-analysis. Hum Reprod Update. Sep-Oct. 2007;(5):453-63. [pmid: 17573406].
296 Prentice RL, Chlebowski RT, Stefanick ML, et al. Estrogen plus progestin therapy and breast cancer in recently postmenopausal women. Am J Epidemiol. May. 2008;15(10):1207-16. [pmid: 18372396].
297 Beral V. Breast cancer risk in relation to the interval between menopause adn starting hormone therapy. J Natl Cancer Inst. 2011;103(4):296-305. [pmid: 21278356].
298 Prentice RL, Chlebowski RT, Stefanick ML, et al. Conjugated equine estrogens and breast cancer risk in the Women's Health Initiative clinical trial and observational study. Am J Epidemiol. Jun. 2008;15(12):1407-15. [pmid: 18448442].
299 Hersh. National use of postmenopausal hormone therapy. JAMA. 2004;291(1):47-53. [pmid: 14709575].
300 Jemal. Recent trends in breast cancer incidence rates by age and tumor characteristics among U.S. women. Breast Cancer Res. 2007;9(3):R28. [pmid: 17477859].
301 Grodstein F. Postmenopausal hormone use and cholecystectomy in a large prospective study. Obstet Gynecol. 1994;83:5-11. [pmid: 8272307].
302 Liu B, Beral V, Balkwill A, et al. Gallbladder disease and use of transdermal versus oral hormone replacement therapy in postmenopausal women: prospective cohort study. BMJ. 2008:a386. [pmid: 18617493].
303 Boland. Hyperinsulinemia, dyslipidemia, and obesity as risk factors for hospitalized gallbladder disease: a prospective study. Ann Epidemiol. 2002;12(2):131-40. [pmid: 11880221].
304 Johnson. Menopausal hormone therapy and risk of colorectal cancer. Cancer Epidemiol Biomarkers Prev. 2009;18(1):196-203. [pmid: 19124498].
305 Grodstein F, Martinez ME, Platz EA, et al. Postmenopausal hormone use and risk for colorectal cancer and adenoma. Ann Intern Med. May. 1. 1998;128(9):705-12. [pmid: 9556463].
306 Rennert G, Rennert HS, Pinchev M, et al. Use of hormone replacement therapy and the risk of colorectal cancer. J Clin Oncol. Sep. 20. 2009;27(27):4542-7. [pmid: 19704062].
307 Green J, Czanner G, Reeves G, et al. Menopausal hormone therapy and risk of gastrointestinal cancer: nested case-control study within a prospective cohort, and meta-analysis. Int J Cancer. May. 15. 2012;130(10):2387-96. [pmid: 21671473].
308 Rossouw JE, Prentice RL, Manson JE, et al. Postmenopausal hormone therapy and risk of cardiovascular disease by age and years since menopause. JAMA. Apr. 2007;4(13):1465-77. [pmid: 17405972].
309 Sweetland S, Beral V, Balkwill A, et al. Venous thromboembolism risk in relation to use of different types of postmenopausal hormone therapy in a large prospective study. J Thromb Haemost. Nov. 2012;10(11):2277-86. [pmid: 22963114].
310 Karageorgi. Reproductive factors and postmenopausal hormone use in relation to endometrial cancer risk in the Nurses' Health Study cohort 1976-2004. Int J Cancer. 2010;126(1):208-16. [pmid: 19551854].
311 Allen NE, Tsilidis KK, Key TJ, et al. Menopausal hormone therapy and risk of endometrial carcinoma among postmenopausal women in the European Prospective Investigation Into Cancer and Nutrition. Am J Epidemiol. Dec. 15. 2010;172(12):1394-403. [pmid: 20961969].
312 Tsilidis. Menopausal hormone therapy and risk of ovarian cancer in the European prospective investigation into cancer and nutrition. Cancer Causes Control. 2011;22:1075-84. [pmid: 21637986].
313 Hildebrand. Postmenopausal hormone use and incident ovarian cancer: associations differ by regimen. Int J Cancer. 2010;127:2928-35. [pmid: 21351271].
314 Chien C LC, Heckbert SR, et al. Antidepressant use and breast cancer risk. Breast Cancer Res and Treatment. 2006;95:131-40. [pmid: 16322894].
315 Davis S MD. Medication use and the risk of breast cancer. Eur J Epidemiol. 2007;22:319-25. [pmid: 17487555].
316 Wernli KJ HJ, Trentham-Dietz A, Newcomb PA. Antidepressant medication use and breast cancer risk. Pharmacoepidemiol Drug Saf. 2009;18(4):284-90. [pmid: 19226540].
317 Lonn E, Bosch J, Yusuf S, et al. Effects of long-term vitamin E supplementation on cardiovascular events and cancer: a randomized controlled trial. JAMA. Mar. 16. 2005;293(11):1338-47. [pmid: 15769967].
318 Lee IM, Cook NR, Gaziano JM, et al. Vitamin E in the primary prevention of cardiovascular disease and cancer: the Women's Health Study: a randomized controlled trial. JAMA. Jul. 6. 2005;294(1):56-65. [pmid: 15998891].
319 Lin J, Cook NR, Albert C, et al. Vitamins C and E and beta carotene supplementation and cancer risk: a randomized controlled trial. J Natl Cancer Inst. Jan. 7. 2009;101(1):14-23. [pmid: 19116389].
320 Spangler L, Scholes D, Brunner RL, et al. Depressive symptoms, bone loss, and fractures in postmenopausal women. J Gen Intern Med. May. 2008;(5):567-74. [pmid: 18286345].
321 Maugeri D, Panebianco P, Russo MS, et al. Ipriflavone-treatment of senile osteoporosis: results of a multicenter, double-blind clinical trial of 2 years. Archives of gerontology and geriatrics. Nov-Dec. 1994;19(3):253-63. [pmid: 15374271].
322 Agnusdei D, Bufalino L. Efficacy of ipriflavone in established osteoporosis and long-term safety. Calcified tissue international. Suppl 1. 1997;61:S23-7. [pmid: 9263613].
323 Alexandersen P, Toussaint A, Christiansen C, et al. Ipriflavone in the treatment of postmenopausal osteoporosis: a randomized controlled trial. JAMA. Mar. 2001;21(11):1482-8. [pmid: 11255425].
324 Cook NR, Albert CM, Gaziano JM, et al. A randomized factorial trial of vitamins C and E and beta carotene in the secondary prevention of cardiovascular events in women: results from the Women's Antioxidant Cardiovascular Study. Arch Intern Med. Aug. 13-27. 2007;167(15):1610-8. [pmid: 17698683].
325 Brasky TM, Lampe JW, Potter JD, et al. Specialty supplements and breast cancer risk in the VITamins And Lifestyle (VITAL) Cohort. Cancer Epidemiol Biomarkers Prev. Jul. 2010;19(7):1696-708. [pmid: 20615886].
326 Obi N, Chang-Claude J, Berger J, et al. The use of herbal preparations to alleviate climacteric disorders and risk of postmenopausal breast cancer in a German case-control study. Cancer Epidemiol Biomarkers Prev. Aug. 2009;(8):2207-13. [pmid: 19661079].
327 Rebbeck TR, Troxel AB, Norman S, et al. A retrospective case-control study of the use of hormone-related supplements and association with breast cancer. Int J Cancer. Apr. 1. 2007;120(7):1523-8. [pmid: 17205521].
328 Archer DF, Pinkerton JV, Guico-Pabia CJ, et al. Cardiovascular, cerebrovascular, and hepatic safety of desvenlafaxine for 1 year in women with vasomotor symptoms associated with menopause. Menopause. Jan. 2013;20(1):47-56. [pmid: 23266840].
329 Workshop on guidelines to the epidemiology of weak associations. Prev Med. Mar. 1987;16(2):139-212. [pmid: 3588559].
330 Lloyd-Jones DM, Martin DO, Larson MG, et al. Accuracy of death certificates for coding coronary heart disease as the cause of death. Ann Intern Med. Dec. 15. 1998;129(12):1020-6. [pmid: 9867756].
331 Clarkson TB, Utian WH, Barnes S, et al. The role of soy isoflavones in menopausal health: Report of the North American Menopause Society/Wulf H. Utian Translational Science Symposium in Chicago, IL. October 2010. Menopause. 2011(7):732-53. [pmid: 21685820].
332 Horn-Ross PL, John EM, Canchola AJ, et al. Phytoestrogen intake and endometrial cancer risk. J Natl Cancer Inst. Aug. 2003;6(15):1158-64. [pmid: 12902445].
333 Bandera EV, Williams MG, Sima C, et al. Phytoestrogen consumption and endometrial cancer risk: a population-based case-control study in New Jersey. Cancer Causes Control. Sep. 2009;20(7):1117-27. [pmid: 19353280].
334 Xu WH, Zheng W, Xiang YB, et al. Soya food intake and risk of endometrial cancer among Chinese women in Shanghai: population based case-control study. BMJ. May. 29. 2004;328(7451):1285. [pmid: 15136343].
335 Bolanos R, Francia J. Isoflavones versus hormone therapy for reduction of vertebral fracture risk: indirect comparison. Menopause. Nov-Dec. 2010;(6):1201-5. [pmid: 20613672].
336 Moher D, Jadad AR, Nichol G, et al. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Controlled clinical trials. Feb. 1995;16(1):62-73. [pmid: 7743790].
337 Salanti G. Indirect and mixed-treatment comparison, network, or multiple-treatments meta-analysis: many names, many benefits, many concerns for the next generation evidence synthesis tool. Res Synth Methods. 2012;3(2). PMID:.
338 Sood R, Shuster L, Schroeder D, et al. Abstract: Bioidentical Compounded Hormones - A pharmacokinetic evaluation int he setting of a randomized controlled trial. Menopause. 2010;17(6):1. PMID:.
339 Speroff L, Gass M, Constantine G, et al. Efficacy and tolerability of desvenlafaxine succinate treatment for menopausal vasomotor symptoms: a randomized controlled trial. Obstet Gynecol. Jan. 2008;(1):77-87. [pmid: 18165395].
340 Depomed. Study of Gabapentin Extended Release (G-ER) in the Treatment of Vasomotor (Hot Flashes/Hot Flushes) Symptoms in Postmenopausal Women. NCT00755417. 2012. PMID:.
341 Albertazzi P, Pansini F, Bonaccorsi G, et al. The effect of dietary soy supplementation on hot flushes. Obstet Gynecol. Jan. 1998;(1):6-11. [pmid: 9464712].
342 Levis S, Strickman-Stein N, Ganjei-Azar P, et al. Soy isoflavones in the prevention of menopausal bone loss and menopausal symptoms: A randomized, double-blind trial. Archives of Internal Medicine. 2011(15):1363-9. [pmid: 21824950].
343 Radhakrishnan G, Rashmi, Agarwal N, et al. Evaluation of isoflavone rich soy protein supplementation for postmenopausal therapy. Pakistan Journal of Nutrition. 2009(7):1009-17. [pmid: 15754123].
344 Newton KM, Reed SD, LaCroix AZ, et al. Treatment of vasomotor symptoms of menopause with black cohosh, multibotanicals, soy, hormone therapy, or placebo: a randomized trial. Ann Intern Med. Dec. 2006;19(12):869-79. [pmid: 17179056].
345 Borrelli F, Ernst E. Black cohosh (Cimicifuga racemosa): a systematic review of adverse events. Am J Obstet Gynecol. Nov. 2008;(5):455-66. [pmid: 18984078].
346 Naser B, Schnitker J, Minkin MJ, et al. Suspected black cohosh hepatotoxicity: no evidence by meta-analysis of randomized controlled clinical trials for isopropanolic black cohosh extract. Menopause. Apr. 2011;(4):366-75. [pmid: 21228727].
347 Aso T, Uchiyama S, Matsumura Y, et al. A natural S-equol supplement alleviates hot flushes and other menopausal symptoms in equol nonproducing postmenopausal Japanese women. J Womens Health (Larchmt). Jan. 2012;21(1):92-100. [pmid: 21992596].
348 Hedrick RE, Ackerman RT, Koltun WD, et al. Estradiol gel 0.1% relieves vasomotor symptoms independent of age, ovarian status, or uterine status. Menopause. Nov-Dec. 2010;(6):1167-73. [pmid: 20720511].
349 Rigano A, Rigano M, Cancellieri F, et al. Sexually and well-being in early menopause. Effect of transdermal estradiol therapy. Panminerva Med. Jun. 2001;(2):115-8. [pmid: 11449182].
350 Simon JA, Stevens RE, Ayres SA, et al. Perimenopausal women in estrogen vasomotor trials: contribution to placebo effect and efficacy outcome. Climacteric. Mar. 2001;(1):19-27. [pmid: 11379374].
351 Lobo RA, Pinkerton JV, Gass ML, et al. Evaluation of bazedoxifene/conjugated estrogens for the treatment of menopausal symptoms and effects on metabolic parameters and overall safety profile. Fertil Steril. Sep. 2009;92(3):1025-38. [pmid: 19635615].
352 Frei-Kleiner S, Schaffner W, Rahlfs VW, et al. Cimicifuga racemosa dried ethanolic extract in menopausal disorders: a double-blind placebo-controlled clinical trial. Maturitas. Aug. 2005;16(4):397-404. [pmid: 16039414].
353 Crisafulli A, Marini H, Bitto A, et al. Effects of genistein on hot flushes in early postmenopausal women: a randomized, double-blind EPT- and placebo-controlled study. Menopause. Jul-Aug. 2004;(4):400-4. [pmid: 15243277].
354 Burke GL, Legault C, Anthony M, et al. Soy protein and isoflavone effects on vasomotor symptoms in peri- and postmenopausal women: the Soy Estrogen Alternative Study. Menopause. Mar-Apr. 2003;(2):147-53. [pmid: 12627040].
355 Freeman EW, Sammel MD, Lin H, et al. Associations of hormones and menopausal status with depressed mood in women with no history of depression. Arch Gen Psychiatry. Apr. 2006;63(4):375-82. [pmid: 16585466].
356 Cohen LS, Soares CN, Vitonis AF, et al. Risk for new onset of depression during the menopausal transition: the Harvard study of moods and cycles. Arch Gen Psychiatry. Apr. 2006;63(4):385-90. [pmid: 16585467].
357 Shifren JL, Monz BU, Russo PA, et al. Sexual problems and distress in United States women: prevalence and correlates. Obstet Gynecol. Nov. 2008;112(5):970-8. [pmid: 18978095].
358 Myers LS. Methodological review and meta-analysis of sexuality and menopause research. Neuroscience and biobehavioral reviews. Summer. 1995;19(2):331-41. [pmid: 7630587].
359 Krychman ML. Vaginal estrogens for the treatment of dyspareunia. J Sex Med. Mar. 2011;8(3):666-74. [pmid: 21091878].
360 Suckling J, Lethaby A, Kennedy R. Local oestrogen for vaginal atrophy in postmenopausal women. Cochrane Database Syst Rev. 2006(4):CD001500. [pmid: 17054136].
361 National Sleep Foundation. Women and Sleep. 2007.
362 Carpenter JS, Johnson D, Wagner L, et al. Hot flashes and related outcomes in breast cancer survivors and matched comparison women. Oncology nursing forum. Apr. 2002;29(3):E16-25. [pmid: 11979290].
363 Bardia A, Novotny P, Sloan J, et al. Efficacy of nonestrogenic hot flash therapies among women stratified by breast cancer history and tamoxifen use: a pooled analysis. Menopause. May-Jun. 2009;16(3):477-83. [pmid: 19188850].
364 Sood R, Warndahl RA, Schroeder DR, et al. Bioidentical compounded hormones: a pharmacokinetic evaluation in a randomized clinical trial. Maturitas. Apr. 2013;74(4):375-82. [pmid: 23384975].
365 NIH. Estrogen Use and Postmenopausal Women. National Institutes of Health Consensus Development Conference Statement. September 13-14, 1979. 1979. [cited 2014 October]; Available from: http://consensus.nih.gov/1979/1979EstrogenPostmenopause018html.htm.
366 Go AS, Mozaffarian D, Roger VL, et al. Heart disease and stroke statistics--2013 update: a report from the American Heart Association. Circulation. Jan. 1. 2013;127(1):e6-e245. [pmid: 23239837].
367 Clarkson TB, Melendez GC, Appt SE. Timing hypothesis for postmenopausal hormone therapy: its origin, current status, and future. Menopause. Mar. 2013;20(3):342-53. [pmid: 23435033].
368 Barrett-Connor E. Hormones and heart disease in women: the timing hypothesis. Am J Epidemiol. Sep. 1. 2007;166(5):506-10. [pmid: 17849510].
369 Manson JE, Bassuk SS. Invited commentary: hormone therapy and risk of coronary heart disease why renew the focus on the early years of menopause?. Am J Epidemiol. Sep. 1. 2007;166(5):511-7. [pmid: 17646204].
370 Harman SM, Black DM, Naftolin F, et al. Arterial imaging outcomes and cardiovascular risk factors in recently menopausal women: a randomized trial. Ann Intern Med. Aug. 19. 2014;161(4):249-60. [pmid: 25069991].
371 Miller ER 3rd, Pastor-Barriuso R, Dalal D, et al. Meta-analysis: high-dosage vitamin E supplementation may increase all-cause mortality. Ann Intern Med. Jan. 4. 2005;142(1):37-46. [pmid: 15537682].
372 Mahady GB, Low Dog T, Barrett ML, et al. United States Pharmacopeia review of the black cohosh case reports of hepatotoxicity. Menopause. Jul-Aug. 2008;15(4 Pt 1):628-38. [pmid: 18340277].
373 Teschke R, Schmidt-Taenzer W, Wolff A. Spontaneous reports of assumed herbal hepatotoxicity by black cohosh: is the liver-unspecific Naranjo scale precise enough to ascertain causality?. Pharmacoepidemiol Drug Saf. Jun. 2011;20(6):567-82. [pmid: 21702069].
374 Salpeter SR, Buckley NS, Liu H, et al. The cost-effectiveness of hormone therapy in younger and older postmenopausal women. Am J Med. Jan. 2009;122(1):42-52 e2. [pmid: 19114171].
375 Senn S. Statistical issues in drug development. 2nd ed. Chichester, England; Hoboken, NJ. John Wiley & Sons. 2007.