# Methods

This comparative effectiveness review (CER) followed the methods suggested in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”37 Methods were applied as appropriate for the evidence available for each Key Question. For KQ1 and KQ4, evidence included only randomized, controlled trials (RCTs). For KQ2, systematic reviews of randomized controlled trials were supplemented by observational studies when appropriate to assess applicability. Evidence sought for KQ3 included systematic reviews, meta-analyses, randomized controlled trials, and observational studies. The topic refinement process, literature search strategies, inclusion/exclusion criteria, data extraction and management procedures, evidence syntheses, and quality assessment methods are described below, specific to each Key Question.

## Topic Refinement and Review Protocol

The topic for this report was nominated in a public process. Input was sought from Key Informants representing clinicians (internal medicine, family practice, and gynecology), academicians, and patients during topic refinement. Key Questions were subsequently posted and public comment obtained. A Technical Expert Panel (TEP) was assembled including content and clinical experts. Public comments were reviewed along with input from Key Informants and the TEP to assure that the questions were specific and explicit concerning the evidence reviewed. The Key Questions were finalized by the EPC after review of the comments (http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=1022).

A review protocol was drafted by the EPC in consultation with the TEP and also posted for public comment. Comments were reviewed by the EPC, discussed with the TEP, and appropriate changes made to the protocol. The protocol was amended during the course of the review in two main respects. First, for KQ1 vasomotor symptom and quality-of-life outcomes, for the most common treatments a network meta-analysis was judged appropriate. Second, the USPSTF report28 was released addressing KQ2 in its entirety, save issues of applicability. With the release of that report and the discrepant conclusions concerning associations observed from observational studies and randomized, controlled trials, evidence for effects was limited to randomized comparisons.

## Literature Search Strategy

Search strategies were developed (see Appendix A) by an expert librarian in collaboration with the trial team. No date limitations were applied. Only English-language articles were included.

The literature search was run on MEDLINE^®^, EMBASE^®^, Cochrane Controlled Trials Register, and AMED Allied and Complementary Medicine. The search included articles through January 2014. Duplicate records were deleted. The reference lists for systematic reviews and meta-analyses were screened to identify additional references which may not have been included in the original search. The search strings are provided in Appendix A. A single search strategy was used for all Key Questions, but different inclusion/exclusion criteria were used for the different Key Questions, details of which are outlined in the Inclusion and Exclusion Criteria section below.

### Gray Literature Search Strategy

Searches were performed in clinicaltrials.gov, the FDA Web site, and relevant conference abstracts (conferences identified by TEP members). Attempts to locate related publications were made and trial authors were contacted for unpublished results if two senior team members concurred that the evidence could impact results meaningfully (i.e., potentially alter the strength of evidence). A text search for the following words was used to identify relevant conference abstracts: random, meta, systematic, testosterone, sertraline, citalo, fluoxetine, paroxetine, vilazodone, venlafax, eszopiclone, gaba, clonidine, methyl, myocardial, stroke, thromboembol, breast ca, endometrial ca, ovarian ca, colorectal ca, gallbladder disease, fracture.

References identified in the gray literature search were then screened using the same inclusion criteria as the original literature search and were incorporated into the review process when appropriate. Potentially unpublished evidence was also requested by the Scientific Resource Center from manufacturers.

Additional strategies were conducted to identify relevant literature on compounded—often referred to as “bioidentical” hormone therapies. Based on the absence of clinical trials for compounded menopausal hormone therapy, specific position statements containing keywords: “compounded or bioidentical hormones” were identified, reviewed, and selected from the following professional societies:

- North American Menopause Society19
- American College of Obstetricians and Gynecologists32
- The Endocrine Society38
- American Association of Clinical Endocrinologists39

Special committee reports from the United States Senate40 and U.S. FDA33 were also identified for review. Finally, we reviewed an influential lay-press publication on compounded “bioidentical” hormones to provide further perspective regarding the controversial topic of compounded menopausal hormone therapy.41

## Inclusion and Exclusion Criteria

### Population(s), Interventions, Comparators, Outcomes

- Population(s)
  Women experiencing symptoms accompanying natural menopause (during perimenopausal or postmenopausal periods) or surgically induced menopause (during the postmenopausal period). Exclusions: KQ1—women with breast cancer; trial populations that consisted of only participants with preexisting conditions such as fibromyalgia, rheumatoid arthritis, or cardiovascular disease; KQ2 and 3—dietary population studies and studies including both pre- and postmenopausal women.
- Interventions
  Menopausal hormone therapy including estrogen therapy and estrogen-progestogen (or estrogen-androgen) therapy administered by oral, transdermal, or vaginal route; combined estrogen-progestogen and progesterone-only contraceptives; compounded menopausal hormone therapy, often referred to as “bioidentical hormones” (Key Questions [KQs] 1 and 2). Exclusions: Women receiving tamoxifen, either alone or in combination with other treatments.
  Nonhormone therapies are listed under KQ1.
- Comparators
  Placebo or direct comparison between therapies, including hormone dose and formulation.
- Outcomes
  ○ No intermediate outcomes are included.
  ○ Final outcomes - menopausal symptom-related:
    - Vasomotor symptoms
    - Sleep disturbance
    - Psychological symptoms
    - Urogenital atrophy
    - Sexual function
    - Quality of life
  ○ Final outcomes - other benefits and harms:
    - Coronary heart disease
    - Stroke
    - Venous Thromboembolism
    - Breast cancer
    - Endometrial cancer
    - Ovarian cancer
    - Colorectal cancer
    - Gallbladder disease
    - Osteoporotic fractures
    - Agent-specific adverse events
- Timing
  For hormone and nonhormone therapies, exposure to treatment will be at least 12 weeks from the baseline assessment. For centrally acting agents such as SSRIs, SNRIs, and gabapentin, trial duration will be at least four weeks from baseline assessment.
- Setting
  Primary care and community (biologic complementary and alternative therapies).

## Study Designs—Inclusion and Exclusion Criteria

### Key Question 1—Symptom Relief

We included RCTs with placebo or an active comparator. Anticipating sufficient RCTs for this Key Question, nonrandomized studies were not included. RCTs should have at least 25 women randomized per arm who are studied for at least 12 weeks for hormone and nonhormone therapies, 4 weeks for centrally acting agents (SNRIs, SSRIs, gabapentin); these conditions are minimums consistent with trials used to define efficacy for vasomotor symptoms. Other meta-analyses and systematic reviews will not be included. Table 1 summarizes the inclusion and exclusion criteria.

Table 1 All therapies: inclusion/exclusion criteria for the relief of vasomotor symptoms, sleep disturbance, psychological symptoms, urogenital atrophy, sexual function, and quality of life

Trial Design | Criteria
RCTs with placebo comparator or active comparator | Include^a^
Meta-analyses and systematic reviews | Exclude^b^
Observational studies | Exclude
Single arm/case series | Exclude
Case reports | Exclude
Minimum duration^c^ | ≥12 weeks
Sample size | ≥25 participants randomized per arm

a Women with breast cancer excluded.

b Bibliographies of meta-analyses and systematic reviews will be reviewed for any trials not identified in the literature search.

c Minimum duration for centrally acting agents such as SSRI, SNRI, and gabapentin, is 4 weeks. This is based on evidence that efficacy in treating vasomotor symptoms with these agents is demonstrable by 4 to 8 weeks.36, 42

RCTs: randomized controlled trials

Several of the nonhormone therapies are consumed as part of a regular diet (soy, vitamin E, ginseng, for example) and are therefore often part of large population-based food consumption observational studies. For the purposes of this report, those studies were not included. Only studies in which the nonhormone therapies are treatments were included.

Therapies were required to be administered during the perimenopausal or menopausal years for study inclusion. If therapies were used only during the premenopausal years, those studies were excluded. If we were unable to determine if the nonhormone therapies were administered during the perimenopausal or menopausal years, for example, studies reporting “ever” use, those studies were excluded.

### Key Question 2—Other Benefits/Harms of Hormones

The associations of hormone therapies with the other benefits and harms considered here has been the subject of controversy, considerable research, and a motivation for conducting the WHI trials. Discrepant conclusions concerning these associations have been observed from observational studies and randomized controlled trials.43 The discrepancies have been attributed to two primary reasons—selection bias and time-varying confounding.44-46 While the association with cardiovascular outcomes has been most scrutinized, difficulties assessing causal effects of menopausal hormone therapy on the KQ2 outcomes from observational data appear to extend to other outcomes as well, including hip fractures44 and colorectal cancer.46 Relying on observational data employing standard analyses to examine these outcomes is problematic.45 Accordingly, study selection to evaluate treatment effects (i.e., those causal) for KQ2 will be limited to systematic reviews of RCTs.

Systematic reviews examining relevant outcomes (coronary heart disease, stroke, or venous thromboembolism; gallbladder disease; osteoporotic fractures; or endometrial, breast, colorectal, or ovarian cancer) will be considered if meeting the following criteria derived from the AMSTAR tool and AHRQ guidance: 1) at least two electronic sources were searched; key words and/or MeSH® terms stated; 2) study inclusion/exclusion criteria reported; 3) study quality (potential bias) of included trials assessed and documented. However, during the course of this review, Nelson et al. completed a review for the USPSTF on the effects of menopausal hormone therapy for chronic disease prevention28 which met all criteria and addressed outcomes included in KQ2. Accordingly, it was used as the primary basis for KQ2.

It is important to note that the approach adopted was not to appraise conclusions of the identified review, but to use the review to identify relevant trials meeting our inclusion criteria and appraise and synthesize evidence from them, including assigning a strength of evidence rating.

Given the natural history of osteoporosis, as well as breast, ovarian, and colorectal cancer, minimum trial duration of 5 years was specified as an inclusion criterion for longitudinal studies investigating those outcomes. A minimum sample size of 250 women per trial was imposed to allow valid assessment of event rates. Outcomes were identified in consultation with the TEP to capture those most consequential. They were not intended to be an exhaustive list.

We anticipated evidence for KQ2 to ultimately derive in whole or in part from the WHI trials. These trials enrolled an older sample overlapping the target population of this review.47 Owing to this difference, applicability of evidence requires scrutiny. This step is in addition to those outlined in AHRQ guidance37 (which notes “the exact process needs to be flexible and will likely evolve”) and adopted by the review team owing to the controversy surrounding applicability of WHI results to the review target population. To assess applicability for KQ2 we examined our search to identify trials and observational studies enrolling peri- and recently menopausal women and consulted a clinical content expert. Informative studies were selected based on recommendations from the content expert in consultation with the review team. Results from these studies were included in the applicability discussion.

### Key Question 3—Other Benefits/Harms of Nonhormones

For nonhormone prescription treatments, we limited our review to studies using the drugs to treat menopausal symptoms (and not for other indications for which the interventions may be commonly used) to increase the applicability of the review to the population of women with menopausal symptoms. An evaluation of all safety data on the nonhormonal agents was beyond the scope of the review.

For nonhormone nonprescription treatments, any study design identifying agent-specific harms was included. Due to scope issues, we limited the list of included agents as prioritized in consultation with the TEP. The list is not exhaustive—see KQ1 for included agents.

The evidence base for agent-specific adverse events for nonhormone therapies consisted of articles included in KQ1 that also reported adverse events, as well as meta-analyses, systematic reviews, and observational studies. Reference lists in the systematic reviews and meta-analyses were reviewed, to identify RCTs and observational studies meeting inclusion criteria (Table 2 and Table 3).

Table 2 Inclusion/exclusion criteria for agent-specific adverse events of nonhormone therapies

Trial Design | Prescription Therapies | Nonprescription Therapies
RCTs with placebo comparator or with active comparator | Include | Include
Meta-analyses and systematic reviews | Include | Include
Observational studies | Include | Include
Single arm and case series | Exclude | Include
Case reports | Exclude | Include
Minimum duration | ≥12 weeks | None
Sample size | ≥25 participants randomized per arm | None

RCTs: randomized controlled trials

Table 3 Inclusion/exclusion criteria for long-term effects (coronary heart disease, stroke, or venous thromboembolism; gallbladder disease; osteoporotic fractures; or endometrial, breast, colorectal, or ovarian cancer) of nonhormone therapies

Trial Design | Prescription Therapies | Nonprescription Therapies
RCTs with placebo comparator or with active comparator | Include | Include
Meta-analyses and systematic reviews | Include | Include
Observational studies | Include | Include
Single arm and case series | Exclude | Exclude
Case reports | Exclude | Exclude
Minimum duration | 5 years^a^ 1 year^b^ | 5 years^a^ 1 year^b^
Sample size | >250 | >250

a Longitudinal studies of colorectal, breast, or ovarian cancers; and fracture outcomes (does not apply to case-control studies).

b All other outcomes (does not apply to case-control studies).

RCTs: randomized controlled trials

### Key Question 4—Subgroups

Subgroups (age, BMI, prior use of therapies, vasomotor severity of symptoms, time since menopause, uterine status, therapy schedule, comorbidities [smoking, anxiety, premenstrual syndrome or postnatal depression]) were selected from included trials in KQ1. Women with breast cancer were excluded.

### Key Question 1 and Key Question 4 Duplicate Populations

Duplicate populations already described in an included article not reporting additional outcomes of interest (KQ1 and KQ4) were excluded.

## Study Selection Process

Articles from the literature search were transferred into EndNote^®^ (Thomson Reuters, New York, NY) and then into DistillerSR (Evidence Partners Inc., Manotick, ON, Canada) for trial selection. A pilot training set of 50 titles was screened by two team members. Titles alone did not provide sufficient screening information and the review proceeded with title/abstract screening. A set of 50 titles/abstracts was used to train the team members. In the title/abstract screening phase, all references underwent dual review for inclusion in the full-text review. Disagreements were resolved by an independent team member.

Citations marked for inclusion during the title/abstract screening phase were retrieved for full text review. A dual screening process was conducted to determine inclusion/exclusion status from the full text. Disagreements between reviewers were resolved by an independent team member. Articles were excluded if they did not meet the criteria specific for each Key Question for appropriate trial design, minimum number of participants, and minimum length of followup. Reasons for exclusion were recorded in the DistillerSR database (Appendix B).

## Data Extraction and Management

### Key Question 1 and Key Question 4

Data elements were defined in a data dictionary and abstracted into tables created in DistillerSR (Appendix C). Two training sets of three articles each were abstracted by all team members. Meetings were held after each training set of articles was abstracted, to discuss potential abstraction discrepancies. The data dictionary and abstraction forms were modified based on input from team members. After finalizing the data dictionary, abstraction forms, and abstraction instructions, data abstraction was conducted. Abstraction was performed by one team member, and verified by a second team member. Inconsistencies identified were resolved by consensus with publication review. For crossover trials only the first phase was included.

Included in abstracted data were the following (see data dictionary Appendix C) for complete listing):

- Trial Characteristics: author, year, country, number of trial sites, trial design, total number randomized, intervention, surgical or natural menopause, disclosures and conflicts of interest, funding, primary and secondary outcomes, and if required for inclusion into trial frequency or intensity of climacteric symptoms
- Trial Arm Characteristics: number of participants, age, ethnicity, BMI, time since menopause, tobacco use, and treatment specifics such as type of treatment, dosage, and route of administration
- Outcomes: scale or measurement; results from baseline, 12-weeks, and final assessments; depending on how the results were reported, mean scores, mean changes, percent reductions, standard deviations, 95% confidence intervals, preintervention/postintervention comparisons, and between group comparisons.
- Many trials included in KQ1 reported outcomes using more than one scale or metric for each domain (with up to 6 arms per trial). For example, psychological symptoms reported may have included depressive symptoms, anxiety, and a global measure of psychological well-being; vasomotor symptoms may have been reported as frequency, severity, and with a menopausal symptom instrument. Selecting outcome metrics to abstract a priori could potentially introduce bias if one was chosen not uniformly or most frequently reported. In addition, data reported with one metric/scale for the same outcome might not provide sufficient quantitative data to estimate an effect while another did. Therefore, we abstracted (digitizing figures when necessary) up to 3 metrics/scales per KQ1 outcome from each trial.

Treatment dosages were recorded for all agents. For analytical purposes, estrogen doses were classified: ultralow, low, standard, and high. With oral treatments, the dosing category definitions were based on those used in the 2009 Cochrane review on hormone replacement therapy and endometrial hyperplasia.48 For example, dose categories for oral conjugated equine estrogens were: ultralow (0.15 to 0.3 mg); low (0.4 mg); standard (0.625 mg); and high (1.25 mg). For other routes of administration, such as transdermal and spray, dosing categorizations were established in consultation (i.e., primarily) with the clinical content expert. For a complete list of estrogen dose categories, by type of estrogen and route of administration, refer to Appendix D.

When only graphical outcomes were presented, figures were digitized. Data were exported to and analyzed with R.49 Data were abstracted into separate datasets. For KQ1 we three study level data sets: study characteristics, study quality ratings, and a data set including characteristics for each study arm; and six datasets or one for each outcome. With few exceptions, trial-level and summary evidence tables were created by manipulating, analyzing, and formatting data in R, then exporting to Microsoft Excel^®^. Inaccuracies produced in this manner are then due to either abstraction or coding.

### Key Question 2

Data from trials identified through the Nelson report for the USPSTF 28 were abstracted, including treatment type, treatment dose, length of followup, and results.

### Key Question 3

With a limited literature base for the effect of nonhormone therapies on long-term conditions, quantitative synthesis was not possible. Descriptive summaries of the available evidence were generated. Summary tables were created and contained the following information: condition, treatment, trial design, trial descriptions, and results.

Adverse events reported for nonhormone therapies included a wide variety of symptoms. Events were categorized according to the International Federation of Pharmaceutical Manufacturers and Associations50 recommended scheme: blood and lymphatic system; cardiac; congenital, familial, and genetic disorders; ear and labyrinth disorders; eye; endocrine disorders; gastrointestinal; general disorders and administration site conditions; hepatobiliary disorders; immune system disorders; infections and infestations; investigations; injury, poisoning, and procedural complications; metabolism/nutritional; musculoskeletal; neoplasms benign, malignant, and unspecified (including cysts and polyps); nervous system; psychiatric disorders; renal/urinary; respiratory, thoracic, and mediastinal disorders; skin and subcutaneous tissue; and vascular.

Data were abstracted into adverse events tables including: author, year, country, treatment, dose, trial population size, total adverse events, and percentage of events for each category.

## Evidence Tables

The body of evidence for KQ1 (and contributing to KQ4) was large, including multiple comparators and trials reporting multiple outcomes. Following exploratory and descriptive analyses, we organized seven sets of evidence tables according to nine generally exclusive categories of comparators: (1) hormone versus placebo; (2) SSRI/SNRI versus placebo; (3) other prescription agents versus placebo; (4) nonprescription agents versus placebo; (5) hormone, nonprescription, placebo comparisons; (6) hormone versus hormone; (7) nonprescription versus hormone; (8) nonprescription versus nonprescription; and (9) SSRI/SNRI versus nonprescription. The evidence tables generated included: (1) descriptive trial data; (2) patient age, body mass index, smoking history; (3) ethnicity/race; (4) uterine status, mean at menopause, years since menopause, prior menopausal hormone therapy; (5) outcomes reported; (6) treatment specifics including category, dose, route, generic and trade name, and estrogen dose if estrogen given (for each treatment arm); and (7) study quality elements and overall ratings. Only for the treatment specifics were trial arms specified which ranged from two to six (the single seven-arm trial footnoted). For each of the 63 tables, studies were ordered chronologically. These tables appear in Appendix E.

## Quality Assessment of Individual Studies

In adherence with the EPC Program “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (hereafter Methods Guide),37 quality (bias) assessment was performed by applying the criteria of the USPSTF.51 An assessment was performed by two independent reviewers. Studies were given ratings of good, fair, and poor.51 Discordant quality assessments were resolved with input from a third reviewer. We were typically unable to assess study quality for trials available only as abstracts or gray sources, such as posted results on clinicaltrials.gov, owing to insufficient trial detail. A modified version of AMSTAR, a validated tool, was used for quality assessment of meta-analyses and systematic reviews.52

When interpreting study quality ratings, it is important to note the study design along with the rating. Features such as randomization and control arms in RCTs inherently reduce risk of bias, while observational studies generally have more sources of bias.53 A “fair” rating for an RCT is not equivalent to a “fair” rating for an observational study. We therefore added the qualifier “observational study” next to the good, fair, and poor ratings in the quality assessment tables for the cohort and case control studies.

Even with appropriate analysis, the ability of observational studies to identify unconfounded associations and causal effects54 or ascertain harms55 can be highly variable. Moreover, all observational data are considered lesser (low) strength of evidence.56 The perspective here is that a qualitative appraisal of observational studies that scrutinizes both the design and analytic approaches used to evaluate any causal effects is informative alongside a more quantitative one (i.e., checklist).

### Randomized Controlled Trials

The following criteria were used to assess the study quality of RCTs: assembly of comparable groups; blinding of researchers and subjects; adequate concealment of group assignment; maintenance of comparable groups; differential loss to followup; equal and reliable measurements; clearly defined interventions; important outcomes considered and defined; and intention-to-treat analysis.

Based on these criteria, ratings for RCTs were defined as:

Good: Meets all criteria; comparable groups are assembled and maintained throughout study (followup at least 80 percent); reliable and valid measurement instruments used and applied equally between groups; interventions clearly defined; important outcomes defined; and intention-to-treat analysis performed.

Fair: Generally comparable groups assembled initially, but questions remain about differences in followup; measurement instruments acceptable and generally applied equally; some but not all important outcomes considered; some but not all potential confounders accounted for.

Poor: Groups assembled initially are not close to being comparable or maintained; unreliable or invalid measurement instruments used; key confounders are given little or no attention.

### Cohort Studies

The following criteria were used to assess the study quality of cohort studies: assembly of comparable groups; maintenance of comparable groups; differential loss to followup; equal and reliable measurements; important outcomes considered and defined; and statistical adjustment for potential confounders.

Based on these criteria, ratings for cohort studies were defined as:

Good: Meets all criteria; comparable groups are assembled and maintained throughout study (followup at least 80 percent); reliable and valid measurement instruments used and applied equally between groups; interventions clearly defined; important outcomes defined; and appropriate statistical adjustment for confounders.

Fair: Generally comparable groups assembled initially, but questions remain about differences in followup; measurement instruments acceptable and generally applied equally; some but not all important outcomes considered; some but not all potential confounders accounted for.

Poor: Groups assembled initially are not close to being comparable or maintained; unreliable or invalid measurement instruments used; key confounders are given little or no attention.

### Case Control Studies

The following criteria were used to assess study quality of case control studies: accurate ascertainment of cases; nonbiased selection of cases and controls; response rate; equal application of diagnostic tests to each group; accurate and equal measure of exposure to each group; and attention to potential confounders.

Based on these criteria, ratings for case control studies were defined as:

Good: Appropriate ascertainment of cases and nonbiased selection of controls; response rate ≥80 percent; diagnostic procedures and measurements accurate and applied equally; and appropriate attention to potential confounders.

Fair: No major selection or diagnostic bias among groups; response rate less than 80 percent; attention to some but not all potential confounders.

Poor: Major selection or diagnostic biases; response rate less than 50 percent; inaccurate or unequal exposure measurements; or inattention to potential confounders.

## Data Synthesis

### Overall Approaches and Meta-Analyses for Direct Comparisons

The approach adopted for evidence synthesis was inclusive to incorporate as much evidence as possible. The rationale for this approach has four primary underpinnings. First, while symptom severity varies, the experience of menopause is universal. Second, defining homogeneous populations of women within the evidence base of trials identified is potentially problematic due to varying patient characteristics, as well as reporting. For example, years since menopause was reported in 31.4 percent of trials. Thirdly, trials employed a variety of different patient-reported outcome instruments, some more commonly used than others. To apply an inclusion criterion stipulating use of particular instrument(s) could arguably introduce bias.

Lastly, combining outcomes obtained on different metrics requires calculating standardized effect measures—here standardized mean differences (SMD). Obtaining effects and some estimate of variance from trials reported in a myriad of ways is challenging. For example, as outlined below, outcomes can be reported in a host of different ways, each allowing calculation of an effect and variance. Excluding trials reporting a nonsignificant result from a pooled analysis would introduce bias and requires imputation. Further, in the end, potential reporting bias must also be considered. There are, therefore, numerous potential sources of uncertainty over and above those sometimes encountered in meta-analyses. Confidence and credible intervals for pooled estimates should be considered cautiously as their calculation does not incorporate some sources of statistical uncertainty; arguable most all should be penalized and a lower level of type I error applied than is convention. For example, normality of outcome metrics cannot be completely verified. For vasomotor symptoms, we examined qq plots according to metric which supported normality for most, but confirming for those metrics used in a few trials was not possible. Additionally, while data extraction was verified and each reverified for potential outliers e.g., (SMDs >1.0 or < -1.0) in preliminary analyses, data extraction for use in SMDs is difficult.57 Often p-values used to calculate variances were not reported as exact by as <0.05 or <0.01 so serving as upper bounds. We accordingly adopted a purposeful, pragmatic, but cautious approach to sifting, analyzing, and interpretation of KQ1 evidence. For example, clearly identifiable outliers were excluded from main pooled estimates (as apparent on forest, funnel, and radial plots) with results also provided including those estimates. Outliers had implausibly large or small estimated standardized effects. Pooling was also performed with and without lesser influential observations; and attempted to include in the network meta-analyses (vasomotor symptoms and quality of life consistent effects). Finally, sensitivity analyses were liberally performed.

### Use of Standardized Mean Differences

Standardized mean differences were calculated and pooled according to the EPC Program Methods Guide.58 Calculating the SMD, which is in simplest terms (mean change treatment – mean change comparator)/pooled standard deviation, allows for comparison of results across studies using different measures. We used Hedge’s G calculation for SMDs being considered less biased in small samples. Analyses were performed in R49 using the meta,59 compute.es,60 and ggplot2^61^ packages.

We estimated effects for each arm to calculate SMDs as follows: (1) from reported pre-post change and standard deviation (or error), (2) if baselines were similar using end of treatment means and standard deviation if reported, (3) if baselines differed with baseline and end of treatment standard deviations reported calculated change and estimated standard deviation (assuming 0.5 correlation between initial and final standard deviations), (4) using p-values (applying a t-distribution) with baseline and end of treatment value or reported change for arm-specific effect, (5) using between-arm differences, confidence intervals or p-values (applying a t-distribution) as from an ANCOVA. When more than one approach to calculating a standard deviation was feasible, we compared SMDs using from different approaches to assure consistency with trial results. If an effect was reported as nonsignificant but the trial was to be pooled, a nonsignificant p-value was imputed for pooling so not to selectively exclude nonsignificant results. Values were imputed randomly from a uniform distribution bounded by the approximate standard deviations of a normal distribution fitted to the sample of study values reported—e.g., for vasomotor symptoms 0.10 to 0.70. For trials reporting nonsignificant results but not pooled no imputation was performed. A small number of trials reported dichotomous outcomes; when feasible they were also included.

### Pooling

Analyses were performed in R49 using the meta59 package. For individual trials, SMDs and confidence intervals were calculated using the compute.es package.60 Clinical heterogeneity, and appropriateness for pooling, was judged on the basis of study characteristics in concert with subject matter knowledge—as interpreted by the study team. To facilitate generalizability, the approach was inclusive performing and reporting results from sensitivity analyses limited to set(s) of trials that might inform consistencies and inconsistencies. When multi-arm trials incorporated arms with treatments similar for the purposes of analyses here (e.g., same estrogen dose) effects from arms were combined prior to any pooling. Because the goal of any pooling is to estimate unconditional effects,62 random-effects models were used. The magnitude of statistical heterogeneity was examined by using tau^2^ owing to limitations of the I^2^ metric and because between-trial variances are more intuitively interpreted on the effect estimate scale.63 Evidence of possible reporting (publication) bias was explored by using funnel plots and Egger test when results from at least 10 studies were pooled. At the protocol stage, we anticipated examining subgroup-specific effects according vasomotor symptom severity, years since menopause (age), ethnicity, and comorbidities (smoking, obesity). Given inconsistent and incomplete reporting of these variables such analyses were not conducted. In addition, other than for KQ2 trial reporting did not allow evaluating results separately for women with and without a uterus. Outcomes were summarized and reported in the order specified by therapies in the KQs.

### Minimal Clinically Important Differences

To discuss the outcomes in the context of clinical relevance, attempts were made to find established thresholds for the minimal clinically important difference for each outcome. PubMed and Google Scholar were searched for minimal clinically important differences (MCID) for the following: Greene scale, MENQOL, MQOL, WHQ, Kupperman Index, hot flushes, night sweats, Hamilton Depression scale, SF-36, CES-D, McCoy scale, Menopause Rating Scale, Visual Analog Scale and WHI sleep scale. Search terms for MCID included “MCID,” “MID,” “minimal important difference,” “clinical important difference,” “clinically important difference,” “minimal difference”, “clinical difference” and “important difference.” Search terms for outcomes included “Greene scale,” “Greene,” “MENQOL,” “MQOL,” “menopause QOL,” “menopause quality of life,” “WHQ,” “WHQ scale,” “Kupperman Index,” “Kupperman,” “night sweats,” “vasomotor,” “Hamilton,” “HAMD,” “SF-36,” “RAND-36,” “CES-D,” “McCoy sex scale,” “McCoy scale,” “McCoy sex,” “Menopause Rating Scale,” “MRS,” Visual Analog Scale,” “VAS,” “WHI scale,” “WHI,” and “menopause.” Articles retrieved from the search that had a postmenopausal patient population were then searched for the MCIDs using the find function and MCID search terms. If MCIDs were not found in articles with a postmenopausal population, then articles with any patient population were searched. Table 4 summarizes the MCID for each outcome or scale.

Table 4 Minimal clinically important difference (MCID) or minimal clinically important improvement (MCII) for various scales

Article | Scale | MCID/MCII | Note
Huntley, 2003^64^ | Kupperman total score | final score ≤15 | Cites Kupperman, 1959^65^
Kupperman, 1959^65^ | Kupperman total score | final score ≤15
Morrison, 2004^66^ | Hamilton-Depression | -3 points
Zollner, 2005^67^ | MENQOL subscales | 1 point change | Cites Hilditch, 2008^68^
Hilditch, 2008^68^ | MENQOL subscales | 1 point change
Lewis, 2005^69^ | MENQOL subscales MENQOL summary | 1 point change
Wyrwich, 2003^70^ | SF-36 general health SF-36mental health | Small change: 10 Moderate change: 20 Large change: 30 State change: 5
Samsa, 1999^71^ | SF-36 | 3-5 point
Levine, 2005^72^ | WHI Insomnia Scale | 1/2 a SD change
DeRogatis, 2009^73^ | Satisfying sexual episodes | +1 episode/4-week period

MENQOL: Menopause Quality of Life; VAS: visual analog scale; WHI: Women’s Health Initiative

### Indirect Comparisons With Mixed Treatment Comparisons Techniques

A random-effects network meta-analysis was performed pooling standardized mean differences in a Bayesian model described by Chaimani (www.mtm.uoi.gr/). Models were fitted in OpenBUGS 3.2.2 using noninformative priors and convergence assessed using the Brooks-Gelman-Rubin plot and statistic (no value exceeded 1.002 in the model). A burn-in of 20,000 samples was discarded and subsequent 40,000 analyzed. Rankings were estimated for the probability a treatment was most effective, next most effective, and so on. SMDs and accompanying 95% credible intervals were obtained from the samples. To evaluate consistency we compared available pairwise estimates to the network results74 and explored graphically (www.mtm.uoi.gr/). We examined all pairwise comparisons individually in random effects models and graphically using forest plots.

### Outcome Measures

#### Key Questions 1 and 4

Outcomes for KQ1 and KQ4 were categorized into the following menopausal symptom categories: vasomotor symptoms, sleep disturbance, psychological symptoms, urogenital atrophy symptoms, sexual function, and quality of life. Outcomes were self-reported, from daily diaries or derived from validated survey instruments. Survey instrument details appear in each of the results sections.

There existed a wide variety of potential outcome measures for each of the categories, so abstraction was limited to the more common outcomes. The following outcomes, by category, were abstracted for analyses:

Vasomotor symptoms: self-reported hot flushes, night sweats, and severity of hot flushes; vasomotor subscores from instruments such as the Greene Climacteric Scale (GCS), the Kupperman Menopausal Index (KI), Women’s Health Questionnaire (WHQ), and the Menopause-specific Quality of Life (MENQOL)

Sleep disturbance: self-reported insomnia and sleep problems; Women’s Health Initiative Insomnia Rating Scale, and sleep subscales from GCS, KI, or MENQOL

Psychological symptoms: anxiety, depressive symptoms, and global measures; subscales from the larger menopause-related survey instruments such as KI, GCS, MENQOL, or from psychological survey instruments such as Beck and Hamilton

Urogenital atrophy: self-reported vaginal dryness; urogenital atrophy or vaginal atrophy subscale scores from KI, GCS, and MENQOL

Sexual function: dyspareunia, satisfying sexual episodes, number of sexual episodes; McCoy Sex Scale, and sexual function subscales from GCS, KI, WHQ, and MENQOL

Quality of life: total scores from GCS, KI, MENQOL

Some investigators devised their own scales rather than using the above standardized scales. We included outcomes that used these other scales as well.

#### Key Questions 2 and 3

Outcomes included heart disease (myocardial infarction, angina), stroke, or venous thromboembolism; cholecystitis; osteoporotic fractures; or endometrial, breast, colorectal, or ovarian cancer.

## Strength of the Body of Evidence

Strength of evidence (SOE) assessments were based on the EPC approach,75 which is conceptually similar to the GRADE system.56 Two reviewers graded the strength of evidence, resolving disagreements by consensus. Details for the strength of evidence approach are also available at the AHRQ Effective Health Care site, http://effectivehealthcare.ahrq.gov/ehc/products/60/318/CER-Methods-Guide-140109.pdf.

We adopted a point-based approach to SOE ratings in which each assessment started at high (3 points) and downgraded by one point each for: high risk of bias, inconsistent or unknown consistency, imprecise or unknown precision, indirect body of evidence, and suspected reporting bias (Table 5). Domain ratings were entered into a spreadsheet that provided a summary SOE for each outcome. If the summary SOE remained 3 with no downgrades, strength of evidence was rated high; if the summary SOE equaled 2, strength of evidence was rated moderate; if the summary SOE equaled 1, strength of evidence was rated low; if the summary SOE was zero or lower, strength of evidence was rated insufficient. Following AHRQ guidance for assessing evidence on equivalence and noninferiority, studies can be appropriately considered individually in the presence of clinical heterogeneity—“the lack of meta-analysis does not necessarily preclude a conclusion of EQ-NI [Equivalence-noninferiority], just as it does not preclude an evaluation of the strength of evidence in relation to a particular outcome.”76

Table 5 Downgrading of SOE according to domains from the initial SOE of high (3 points) to moderate (2 points), low (1 point), or insufficient (0 points)

Domain | Level | Change in Score
Risk of Bias | High | -1
Risk of Bias | Medium | 0
Risk of Bias | Low | 0
Consistency | Inconsistent | -1
Consistency | Unknown | -1
Consistency | Consistent | 0
Directness | Indirect | -1
Directness | Direct | 0
Precision | Imprecise | -1
Precision | Unknown | -1
Precision | Precise | 0
Reporting bias | Suspected | -1
Reporting bias | Undetected | 0

We imposed one departure from the SOE ratings. In the presence of a large number of trials (n≥10), even when a majority of the trials were rated poor quality, risk of bias was assigned medium rather than low. If there were 10 or more trials with consistent effects and no suspected reporting bias, we concluded that low trial quality did not justify a lower strength of evidence.

For KQ1, when sufficient trials allowed for evidence synthesis, strength of evidence was determined by outcome (vasomotor symptoms, quality of life, psychological symptoms, sexual function, urogenital atrophy symptoms, and sleep disturbance) and by comparators. For outcomes and comparator groups without poolable data represented by single trials, strength of evidence was deemed insufficient and not reported.

For KQ2, strength of evidence was determined by outcome (breast cancer; gallbladder disease; colorectal cancer; coronary heart disease, stroke, and venous thromboembolism; endometrial cancer; osteoporotic fractures, and ovarian cancer), and by treatment regimen (either estrogens alone or estrogens with progestogens).

For KQ 3, strength of evidence was determined by outcome (breast cancer; gallbladder disease; colorectal cancer; coronary heart disease, stroke, and venous thromboembolism; endometrial cancer; osteoporotic fractures, and ovarian cancer), and by treatment regimen (SSRI/SNRIs, isoflavones, and vitamin E).

For KQ 4, strength of evidence was determined by outcome (vasomotor symptoms, quality of life, psychological symptoms, sexual function, urogenital atrophy, and sleep dysfunction), by subgroup (age, body mass index, race, severity of symptoms, time since menopause, and uterine status), and by treatment regimen (estrogens, other prescription treatments, and nonprescription treatments). For outcomes and comparator subgroups represented by single trials, strength of evidence was deemed insufficient and not reported.

## Applicability

Applicability is defined as the extent to which treatment effects observed in published studies reflect expected results when treatments are applied to these populations in the real world. The population of interest for this review is women experiencing symptoms accompanying natural menopause (during perimenopausal or postmenopausal periods) or surgically induced menopause (during the postmenopausal period). Potential factors which may affect applicability in this body of evidence include:

- Study populations may consist of all menopausal women, regardless of presence of symptoms
- Study populations may combine results on menopausal women with and without a uterus
- Study populations may consist of menopausal women with different levels of symptom severity
- Study populations may have a larger proportion of older menopausal women

Limitations in the applicability of individual studies were identified. When there were questions applying results from randomized controlled trials for KQ2, we reviewed observational studies from the original literature search seeking more comparable populations. As suggested by the AHRQ Methods Guide, when applicability issues occurred, they were highlighted and clearly discussed following the evidence tables.

## Peer Review and Public Commentary

Key Informants are the end-users of research, including participants and caregivers, practicing clinicians, relevant professional and consumer organizations, purchasers of health care, and others with experience in making health care decisions. Within the EPC program, the Key Informant role is to provide input into identifying the Key Questions for research that will inform health care decisions. The EPC solicited input from Key Informants when developing questions for systematic review or when identifying high-priority research gaps and needed new research. Key Informants were not involved in analyzing the evidence or writing the report and have not reviewed the report, except as given the opportunity to do so through the peer or public review mechanism.

Key Informants disclosed any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals are invited to serve as Key Informants and those who present with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

Technical Experts comprise a multidisciplinary group of clinical, content, and methodological experts who provide input in defining populations, interventions, comparisons, or outcomes as well as identifying particular studies or databases to search. They are selected to provide broad expertise and perspectives specific to the topic under development. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore trial questions, design, and/or methodological approaches do not necessarily represent the views of individual technical and content experts. Technical Experts provide information to the EPC to identify literature search strategies and recommend approaches to specific issues as requested by the EPC. Technical Experts do not do analysis of any kind nor contribute to the writing of the report and have not reviewed the report, except as given the opportunity to do so through the public review mechanism.

Technical Experts disclosed any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals are invited to serve as Technical Experts and those who present with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

Peer reviewers are invited to provide written comments on the draft report based on their clinical, content, or methodological expertise. Peer review comments on the preliminary draft of the report are considered by the EPC in preparation of the final draft of the report. Peer reviewers do not participate in writing or editing of the final report or other products. The synthesis of the scientific literature presented in the final report does not necessarily represent the views of individual reviewers. The dispositions of the peer review comments are documented and will, for Comparative Effectiveness Reviews and Technical Briefs, be published 3 months after the publication of the Evidence report.

Potential Reviewers also disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Invited Peer Reviewers may not have any financial conflict of interest greater than $10,000. Peer reviewers who disclose potential business or professional conflicts of interest may submit comments on draft reports through the public comment mechanism.

Peer review comments were addressed formally with revisions to the review and text as appropriate. Following peer review and literature search update, some changes from the draft report are important to note. For KQ1, results from 29 previously not included trials were added. Additionally, published results contributing to different KQ1 outcomes were identified for another 16 trials. With the exception of the analysis for satisfying sexual episodes, all results required updating and conducted considering AHRQ’s finalized guidance for continuous outcomes.77 For vasomotor symptoms, an analysis translating SMDs to hot flush frequencies was performed. Additional sensitivity analyses were also included, particularly for the network result. Ospemifene for urogenital atrophy symptoms was not included in the protocol, but obtained FDA approval and so was added. Finally, we supplemented the analyses of sleep outcomes with network analysis to provide some comparison of agents generally used to treat menopausal symptoms with a sedative hypnotic agent, eszopiclone.