# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Kristine E. Ensrud, M.D., M.P.H.
  Professor
  Department of Medicine
  Adjunct Professor
  Division of Epidemiology & Community Health
  University of Minnesota
  Minneapolis, MN
- Charles L. Loprinzi, M.D.
  Regis Professor of Breast Cancer Research
  Mayo Clinic
  Rochester, MN
- Jan Shifren, M.D.
  Director, Midlife Women's Health Center, Massachusetts General Hospital
  Associate Professor of OB/Gyn and Reproductive Biology, Harvard Medical School
  Boston, MA
- Lynne Shuster, M.D., FACP
  Assistant Professor of Medicine
  Mayo Clinic
  Rochester, MN