# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Nananda Col, M.D., M.P.P., M.P.H., FACP
  President
  Shared Decision Making Resources
  Georgetown, ME
- Carolyn Crandall, M.D., M.S.
  Professor of Medicine, Division of General Internal Medicine and Health Services Research
  David Geffen School of Medicine at UCLA
  Los Angeles, CA
- Cynthia Pearson, B.A.
  Executive Director
  National Women’s Health Network
  Washington, DC