# Acknowledgments

The authors gratefully acknowledge the following individuals for contributions to this project: Tianjing Li, M.D., M.H.S., Ph.D., and Ryan Chopra, M.P.H.