# Discussion

## Introduction

For women experiencing menopausal symptoms considering any of the agents examined here, the choice of treatment is influenced by therapeutic efficacy while considering other potential benefits and harms—particularly over the long-term (Figure 1). The results and conclusions of this review offer an evidenced-based guide to comparative efficacy as well as other important benefits and harms. In this final section, we discuss what has been learned from evidence reviewed together with its limitations and gaps. But most importantly we place the evidence in the context of the analytic framework incorporating the four Key Questions considered not in isolation, but as a whole to inform decisions by women, health care providers, and policy makers.

## Symptom Relief

### Vasomotor Symptoms

A large body of evidence was identified comparing the efficacy of agents compared with placebo and other active treatments for the relief of vasomotor symptoms (Table 98). Trials were most numerous for estrogens, isoflavones, SSRI/SNRIs, gabapentin, ginseng, and black cohosh. Estrogens of any dose appeared more effective than other comparators without apparent meaningful differences between doses or routes of administration. Few differences were apparent in the network meta-analysis among isoflavones, SSRI/SNRIs, gabapentin, and black cohosh. Whether ginseng might have any effect is unclear. A host of other agents have been studied, but evidence is limited to single trials.

Table 98 Magnitude and strength of evidence of treatments for vasomotor symptoms: standardized mean differences from pairwise comparisons^a^

Number of Comparisons | Comparators | Standardized Mean Difference (SMD) (95% CI) | Effect Size Category^b^ | Strength of Evidence
9 | Estrogen (high) vs. placebo | -0.50 (-0.61 to -0.39) | ••• | High
39 | Estrogen (standard) vs. placebo | -0.64 (-0.74 to -0.53) | •••• | High
53 | Estrogen (low/ultralow) vs. placebo | -0.55 (-0.61 to -0.48) | ••• | High
13 | SSRI/SNRI vs. placebo | -0.35 (-0.46 to -0.24) | •• | High
35 | Isoflavones vs. placebo | -0.31 (-0.41 to -0.22) | •• | Low
5 | Gabapentin vs. placebo | -0.28 (-0.38 to -0.19) | •• | Moderate
4 | Black Cohosh vs. placebo | -0.31 (-0.46 to -0.15) | •• | Low
3 | Ginseng vs. placebo | -0.17 (-0.43 to 0.09) | • | Low
11 | Estrogen route a vs. route b | All SMDs close to 0; CrI included 0 | — | High

a To enable easy comparisons in this and the following tables, effect size categories are displayed to provide an indication of comparative efficacy. The categories are not intended to confer other significance and do not correspond to so-called small, medium, and large suggested by Cohen for the purposes of sample size calculation.

b • (0 to > -0.2); •• (-0.2 to > -0.4) ; ••• (-0.4 to > -0.6) ; •••• (< -0.6); — (equivalent)

CI: confidence interval; SMD: standard mean difference; SNRI: serotonin-norepinephrine reuptake inhibitor; SSRI: selective serotonin reuptake inhibitor

The efficacy of estrogens in treating vasomotor symptoms is well established. The comparative effectiveness of other agents relative to estrogens had been less clear. Albeit limited by trial quality, findings from the network analysis allow us to draw conclusions concerning comparative effectiveness. Although nonhormone agents can ameliorate vasomotor symptoms (SMDs ranging from -0.17 to -0.35), none have estrogen’s effectiveness (SMDs ranging from -0.50 to -0.64).

### Quality of Life

Trials evaluating numerous agents reported some quality-of-life metric, but the evidence base included more than a single trial for estrogens, isoflavones, SSRI/SNRIs, ginseng, and black cohosh. Compared with placebo, improved quality-of-life scores accompanied estrogens with standardized mean differences ranging from 0.36 to 0.76 with high strength of evidence; effect sizes for all other agents were lesser in magnitude or low SOE (Table 99). Similarly, estrogens ranked highest in the network comparison. For estrogens, there was no apparent meaningful difference in effect according to route of administration. Quality-of-life scores were reported from trials of many nonprescription agents, but results from single trials do not allow conclusions concerning effects.

Table 99 Magnitude and strength of evidence of treatments for quality of life: standardized mean differences from pairwise comparisons

Number of Comparisons | Comparators | Standardized Mean Difference (SMD) (95% CI) | Effect Size Category^a^ | Strength of Evidence
5 | Estrogen (high) vs. placebo | 0.76 (0.48 to 1.03) | •••• | High
26 | Estrogen (standard) vs. placebo | 0.55 (0.41 to 0.69) | ••• | High
17 | Estrogen (low/ultralow) vs. placebo | 0.36 (0.27 to 0.45) | •• | High
6 | SSRI/SNRI vs. placebo | 0.28 (0.17 to 0.39) | •• | High
24 | Isoflavones vs. placebo | 0.27 (0.17 to 0.37) | •• | Low
4 | Black cohosh vs. placebo | 0.26 (-0.15 to 0.66) | | Insufficient
3 | Ginseng vs. placebo | 0.19 (0.01 to 0.36) | • | Low
7 | Estrogen route a vs. route b | SMDs close to 0 | — | Moderate

a • (0 to < 0.2); •• (0.2 to < 0.4) ; ••• (0.4 to < 0.6) ; •••• (> 0.6); — (equivalent)

SNRI: serotonin-norepinephrine reuptake inhibitor; SSRI: selective serotonin reuptake inhibitor

We found improved global quality-of-life scores in women taking estrogens. Yet no effect was apparent in “Women’s International Study of long Duration Oestrogen after The Menopause” (WISDOM)35 or WHI.144, 145 Results from these trials appeared somewhat discrepant in the analyses and is likely attributable to older age and lesser symptom severity of enrolled women. For the larger body of comparisons in women receiving estrogens, despite between-trial variability, results were more consistent. The general pattern of comparative efficacy seen with quality-of-life scores paralleled results for other vasomotor and other symptoms.

### Psychological Symptoms

Just over one-third of trials examining symptom treatment reported a psychological outcome—depressive symptoms, anxiety symptoms, and global psychological well-being—and often more than one. Only half specified some psychological symptom as a primary outcome. Overall, the samples were not selected to represent populations with clinical depression or anxiety. Compared with placebo, standardized mean differences were in general not large (i.e., SMD between -0.5 and 0) for any of the agents studied for any psychological domain (Table 100). Compared with placebo, the strength of evidence was high for effects of SSRI/SNRIs and estrogens on all psychological measures.

Table 100 Magnitude and strength of evidence of treatments for psychological symptoms: standardized mean differences from pairwise comparisons

Domain | Number of Comparisons | Comparators | Standardized Mean Difference (SMD) (95% CI) | Effect Size Category^a^ | Strength of Evidence
Global | 6 | SSRI/SNRI vs. placebo | -0.42 (-0.60 to -0.24) | ••• | High
Depressive symptoms | 5 | SSRI/SNRI vs. placebo | -0.43 (-0.60 to -0.26) | ••• | High
Anxiety symptoms | 3 | SNRI vs. placebo | -0.31 (-0.50 to -0.12) | •• | High
Global | 14 | Estrogen vs. placebo | -0.26 (-0.40 to -0.13) | •• | High
Depressive symptoms | 18 | Estrogen vs. placebo | -0.36 (-0.53 to -0.20) | •• | High
Anxiety symptoms | 13 | Estrogen vs. placebo | -0.34 (-0.50 to -0.18) | •• | High
Global | 2 | Gabapentin vs. placebo | -0.23 (-0.48 to 0.02) | | Insufficient
Global | 7 | Isoflavones vs. placebo | -0.11 (-0.22 to 0.01) | • | Low
Depressive symptoms | 9 | Isoflavones vs. placebo | -0.29 (-0.49 to -0.09) | •• | Low
Anxiety symptoms | 7 | Isoflavones vs. placebo | -0.30 (-0.46 to -0.14) | •• | Moderate

a • (0 to < 0.2); •• (0.2 to < 0.4) ; ••• (0.4 to < 0.6) ; •••• (> 0.6); — (equivalent)

SNRI: serotonin-norepinephrine reuptake inhibitor; SSRI: selective serotonin reuptake inhibitor

An increased risk for depressive symptoms in the absence of prior depressive illness, during the menopausal transition has been described355 and may be associated with vasomotor symptoms.356 The evidence assessed here may provide guidance when menopausal women are experiencing psychological symptoms.

### Sexual Function

Some measure of sexual function was reported in about a third of trials; half of those trials specified the outcome as primary. Outcomes were reported in four domains: pain (dyspareunia), a global metric, activity, and interest (Table 101). Vaginal estrogens improved pain most convincingly compared with placebo (high strength of evidence), while improved pain scores with oral estrogens were less certain (moderate strength of evidence). There was an increase in global measures with estrogens and a modest improvement with SNRIs. Estrogens were the only agent enhancing measures of interest. Sexually satisfying episodes were more frequent in the comparison of testosterone with placebo—just over one extra episode reported every 4 weeks (strength of evidence moderate). Overall, these results are generally consistent with evidence-informed expert clinical opinion.5

Table 101 Magnitude and strength of evidence of treatments for sexual function: standardized mean differences from pairwise comparisons

Domain and Number of Comparisons | Comparators | Standardized Mean Difference (SMD) (95% CI) | Effect Size Category^a^ | Strength of Evidence
Pain (lower is better)
10 | Vaginal estrogens vs. placebo | -0.54 (-0.73 to -0.34) | ••• | High
4 | Oral estrogens vs. placebo | -0.22 (-0.35 to -0.09) | •• | Moderate
14 | All estrogens vs. placebo | -0.45 (-0.61 to -0.29) | ••• | High
Global (higher is better)
15 | All estrogens vs. placebo | 0.27 (0.19 to 0.35) | •• | High
2 | SSRI/SNRI vs. placebo | 0.27 (0.01 to 0.52) | | Insufficient
4 | Isoflavones vs. placebo | 0.24 (-0.12 to 0.61) | •• | Low
Interest (higher is better)
7 | All estrogens vs. placebo | 0.18 (0.10 to 0.26) | • | Moderate
2 | SNRI vs. placebo | 0.16 (-0.07 to 0.39) | | Insufficient
5 | Isoflavones vs. placebo | 0.26 (-0.001 to 0.52) | | Insufficient
Pain, Interest, Global
10 | Estrogen route a vs. route b | SMDs close to 0 | — | Moderate
Activity (higher is better) | | SSE/4 weeks
4 | Testosterone, no women with intact uteri/ovaries | 1.05 (0.64 to 1.45)^b^ | NA | Moderate
4 | Testosterone, women with/without uteri/ovaries | 1.31 (0.89 to 1.72) | NA | Moderate
8 | Testosterone, all trials | 1.17 (0.88 to 1.46) | NA | Moderate

a For negative effect sizes • (0 to > -0.2); •• (-0.2 to > -0.4) ; ••• (-0.4 to > -0.6) ; •••• (< -0.6). For positive effect sizes • (0 to < 0.2); •• (0.2 to < 0.4) ; ••• (0.4 to < 0.6) ; •••• (> 0.6); — (equivalent).

b number of satisfying sexual episodes per four weeks

SSE: Satisfying sexual episodes; NA: not applicable; SMD: standard mean difference

The Prevalence of Female Sexual Problems Associated with Distress and Determinants of Treatment Seeking (PRESIDE)357 estimated approximately 15 percent of women aged 45 to 64 experienced some form of sexual distress. We identified one quantitative review by Myers. The study included literature published between 1972 and 1992.^358^ In the analysis by Myers, standardized effect representing any domain were combined from 108 studies of estrogen therapy yielding -0.67—somewhat larger in magnitude than obtained in this review.

### Urogenital Atrophy

One-quarter of trials reported urogenital atrophy outcomes—a primary outcome in 60 percent. Ospemifene, an estrogen agonist/antagonist, was approved by the FDA in February 2013 to treat moderate to severe dyspareunia in postmenopausal women. Evidence from three clinical trials showed ospemifene improved vulvar and vaginal atrophy compared with placebo. Although vaginal estrogens showed a greater effect than oral estrogens (indirect comparison) in placebo comparisons, the strength of evidence was high that either oral or vaginal estrogens improved symptoms. The strength of evidence was low for isoflavones (Table 102).

Table 102 Magnitude and strength of evidence of treatments for urogenital atrophy: standardized mean differences from pairwise comparisons

Number of Comparisons | Comparators | Standardized Mean Difference (SMD) (95% CI) | Effect Size Category^a^ | Strength of Evidence
12 | Vaginal estrogen vs. placebo | -0.44 (-0.65 to -0.23) | ••• | High
15 | Nonvaginal estrogen vs. placebo | -0.35 (-0.44 to -0.26) | •• | High
5 | Isoflavones vs. placebo | -0.48 (-0.77 to -0.18) | ••• | Low
3 | Ospemifene vs. placebo | -0.75 (-1.05 to -0.45) | •••• | High

a • (0 to > -0.2); •• (-0.2 to > -0.4) ; ••• (-0.4 to > -0.6) ; •••• (< -0.6); — (equivalent)

The conclusions here are similar to those provided to clinicians5 when considering treating symptoms that may be experienced by as many as 40 percent of postmenopausal women.359 A 2006 Cochrane review including 19 trials concluded that vaginal or oral estrogens were equally effective for treating vaginal atrophy symptoms.360 These results indicate, albeit indirectly based on placebo comparisons, a greater magnitude of effect for vaginal compared with oral administration.

### Sleep

Many trials ascertained self-reported sleep outcomes, but only a single trial examined a drug FDA-approved for use in insomnia (eszopiclone). Compared with placebo, the standardized mean difference for improved sleep measures with eszopiclone was approximately three-fold greater than with estrogens or any other agent. This is consistent with modestly improved sleep accompanying other agents, including estrogens, used to treat menopausal symptoms (Table 103).

Table 103 Magnitude and strength of evidence of treatments for sleep: standardized mean differences from pairwise comparisons

Number of Comparisons | Comparators | Standardized Mean Difference (SMD) (95% CI) | Effect Size Category^a^ | Strength of Evidence
1 | Eszopiclone vs. placebo | 1.08 (0.53 to 1.62) | •••• | Not Rated^b^
24 | Estrogen vs. placebo | 0.32 (0.24 to 0.46) | •• | High
2 | SSRI vs. placebo | 0.46 (0.24 to 0.69) | ••• | Low
2 | Gabapentin vs. placebo | 0.33 (0.18 to 0.49) | •• | Low
6 | Isoflavones vs. placebo | 0.37 (0.10 to 0.64) | •• | Low
2 | Ginseng vs. placebo | 0.13 (-0.05 to 0.32) | | Insufficient

a • (0 to < 0.2); •• (0.2 to < 0.4) ; ••• (0.4 to < 0.6) ; •••• (> 0.6)

SSRI: selective serotonin reuptake inhibitor

b Eszopiclone, an oral sedative used to treat insomnia, was included as a referent. With only one trial comparing eszopiclone with placebo, a rating could not be made.

Although sleep disturbances during menopause are common,361 how often they are secondary to menopausal symptoms is not well defined. Sedative hypnotic agents are not generally used to treat menopausal symptoms and so were not represented in the trials identified. Reported improvements in sleep evident with other agents such as estrogens is possibly due to treatment of vasomotor symptoms, but requires evidence not considered here.

### Limitations of the Evidence Base on Symptom Relief

The body of evidence synthesized for KQ1 was large but many trials were rated poor quality. However, the challenges of synthesizing this evidence extend beyond trial quality to limitations only partially incorporated in strength of evidence assessments. These include:

- Use of different outcome scales or metrics
- Necessity of calculating standardized mean differences and inherent difficulties estimating from publications
- Potential differences in populations represented by trial samples
- Potential for selective outcome reporting

Some two decades ago, in a review of sexuality and menopause, Myers foreshadowed the difficulties encountered here across all outcomes—variable scales, metrics, and definitions.358 Even directionality of scales within the various outcomes often differed; authors did not always abide by conventions for a specific scale. The absence of standardized outcome reporting and common data elements limit the ability to quantify effects using metrics easily and transparently translated to quantities such as clinically meaningful improvement. Interpreting results when presented with continuous measures and multiple scales requiring the use of standardized mean differences is challenging. It is difficult to infer proportions of women achieving minimally clinically important improvements.79, 80

Given the well-described placebo effect, at least for vasomotor symptoms,81 this limitation is important to consider interpreting results. One alternative approach to that adopted here would be to limit trials synthesized to those reporting similar outcome scales or metrics. Although appealing in many respects, if studies reporting some identical outcome metric were not representative of all trials and symptomatic women, the potential for introducing bias exists. So while interpretive limitations accompany standardized mean differences, their use allows including and pooling evidence from multiple trials, which would not be feasible otherwise. In many instances here, it enabled at the very least providing examining comparative efficacy and rankings when subject to network meta-analysis

On the surface, calculating standardized mean differences might appear trivial—yet it is often not. As outlined in the methods, there are a number of ways to obtain effect sizes from the continuous measures reported; trials typically did not report a between group difference and variance (standard deviation) allowing the most straightforward calculating of standardized mean differences. To avoid excluding trial results, other calculations were required including the use of p-values that typically were sometimes not reported exactly. Additionally, other results were reported as simply nonsignificant. In the case where results were pooled, excluding nonsignificant results lacking a p-value would introduce bias. While imputation allowed including those results, it introduces uncertainty. Fortunately, the number of p-values requiring imputation was small. A separate issue was the occasional outlier encountered because trials sometimes reported unusually large effects. Potential outliers required performing analyses to be certain effects could not be attributed to them.

Another concern is that although trial populations included women experiencing menopause, there were differences in mean age, length of follow-up, and symptom severities. While the initial intent was to examine subgroups according to characteristics such as the presence of a uterus, lack of sufficient reporting did not allow doing so. Conclusions then apply to average women across all trials.

It is also difficult to evaluated potential selective outcome reporting from the included trials. Vasomotor symptoms were reported in about three quarters of trials but other outcomes in fewer than half. Some trials, such as those of reporting sexual function or vaginal atrophy symptoms, were clearly not designed to primarily assess all outcomes. However, insignificant results may have been unreported. For some of the outcomes, in only half of the trials was the outcome reported as primary.

The results do not allow assessing whether effects on different outcomes are independent and some may not be causal. It is conceivable that the consequence of fewer vasomotor symptoms is improved quality of life, sleep, or better psychological well-being. Causally, it may be that the focus of therapy need not consider treatment efficacy for all outcomes, but rather a few—most likely beginning with vasomotor symptoms.

The target population for this review did not encompass all women experiencing menopausal symptoms. We did not include studies examining effects among breast cancer survivors—women frequently affected by troublesome symptoms including hot flushes.362 Although effects of nonhormonal agents on hot flushes may be similar regardless of breast cancer history363 breast cancer survivors constitute a different population. Accordingly, these results are not intended to apply to those women.

Finally, compounded hormone therapies are commonly prescribed, often in combination with some testing for hormone levels, with effectively no direct evidence examining comparative efficacy. We identified a single randomized, controlled trial comparing solely the pharmacokinetics of a compounded preparation with a conventional estradiol patch in 40 women followed for 16 days. Outcomes did not include safety or efficacy measurements.364 No studies were identified examining the safety of the compounding practices for hormone therapies.

## Other Benefits and Harms

### Menopausal Hormone Therapy Preparations

In 1979, the National Institutes of Health convened their first consensus conference on estrogen use in postmenopausal women.365 While breast and endometrial cancer were prominent in the summary, there was no mention of heart disease. Some three decades later there is now a robust evidence base allowing many conclusions regarding both beneficial and harmful outcomes.

Trials included in the recent review by Nelson28 were assessed here with concordant conclusions. Because a majority of evidence derived from WHI trials, representing a target population overlapping the one for this review, assessing applicability of findings required considering observational study results. Still, a picture of long-term effects emerges with some clarity as summarized in Table 104. The USPSTF review reported differences in event rates with estrogen/progestin or estrogen compared with placebo. Extrapolating absolute rates from the WHI samples to the target population of this review is problematic. In broad absolute terms gallbladder disease is the most frequent occurrence with thromboembolic events, stroke, and breast cancer less frequent. Although less common they are not insignificant. For example, menopausal hormone therapy in women aged 50 to 74 years has been estimated responsible for 9 percent of all strokes in women in 2012.^366^

Table 104 Summary of long-term effects of menopausal hormone therapy preparations

Outcome | Risk | Treatment vs. Placebo | Strength of Evidence | Comment
Breast cancer | ⬆ | Estrogen/progestin | High
Breast cancer | ⬇ | Estrogen | Low | Inconsistent
Gallbladder disease | ⬆ | Estrogen/progestin | Moderate | Consistency unknown with 1 trial
Gallbladder disease | ⬆ | Estrogen | Moderate | Consistency unknown with 1 trial
Venous thromboembolic events | ⬆ | Estrogen/progestin | Moderate | Consistency unknown with 1 trial
Venous thromboembolic events | ⬆ | Estrogen | High
Stroke | ⬆ | Estrogen/progestin | Moderate | Consistency unknown with 1 trial
Stroke | ⬆ | Estrogen | High
Ovarian cancer | ⬆ | Estrogen/progestin | Low | Consistency unknown with 1 trial; imprecise with few cases
Colorectal cancer | ⬇ | Estrogen/progestin | Low | Consistency unknown with 1 trial
Colorectal cancer | — | Estrogen | Moderate | Consistency unknown with 1 trial
CHD | ⬆ | Estrogen/progestin | Moderate | Consistency unknown with 1 trial
CHD | — | Estrogen | Moderate | Consistency unknown
Endometrial cancer | — | Estrogen/progestin | Moderate | Imprecise
Osteoporotic fractures | ⬇ | Estrogen/progestin | Moderate | Inconsistency between 2 trials
Osteoporotic fractures | ⬇ | Estrogen | Moderate | Consistency unknown with 1 trial

Risk: ⬆ increased, ⬇ decreased, — no change

CHD: coronary heart disease

One limitation of the evidence base concerning long-term outcomes derives from necessity to rely on results of randomized controlled trials enrolling an overlapping, but not identical, target population that is the focus of this review. There are well described discrepant conclusions concerning these associations between observational studies and randomized controlled trials.43 The discrepancies have been attributed to two primary reasons—selection bias and time-varying confounding.44-46 Furthermore, although debate persists concerning the increased CHD risk, with some hypothesizing a protective effect from hormone therapy initiated soon after menopause,367-369 post-hoc but detailed WHI analyses do not provide support for this “timing hypothesis.” Moreover, the Kronos Early Estrogen Prevention Study, designed to examine the hypothesized cardiovascular benefit with early hormone therapy initiation, recently reported results.370 From a sample of 727 women within three years of menopause, randomized to hormone therapy or placebo, over four years, there was no significant decrease in progression of carotid artery intimal thickness (the primary endpoint) or coronary artery calcium score (a secondary endpoint). Although the association with cardiovascular outcomes has been most scrutinized, difficulties assessing causal effects of menopausal hormone therapy from observational data appear to extend to other outcomes including hip fractures44 and colorectal cancer.46 As noted throughout, trials have been conducted from a target population overlapping with the one for this review creating some challenges for assessing applicability. Still, there is considerable certainty in the effects assessed—a remarkable body of evidence accrued since the 1979 NIH consensus conference. Finally, although evidence concerning potential long-term benefits was considered this review did not address use of therapies for prevention of chronic conditions.

### Nonhormone Therapy Preparations

The evidence base informing other potential benefits and harms of nonhormone therapies is limited, but does not suggest harmful long-term effects are likely for those agents where studies were identified (Table 105). We included large trials examining vitamin E, small trials of isoflavones, and observational studies evaluating antidepressants that did not always distinguish risks for the classes of agents used to treat symptoms (SSRI/SNRI). While no salient benefits were identified, neither were safety signals apparent. However, given the large numbers of women potentially taking these agents some caution is advised particularly for nonprescription agents. For example, the possibility of increased mortality with high dose vitamin E has been raised.371 Additionally, case reports of hepatotoxicity with black cohosh have been published.372 This association has been debated,373 but surveillance for adverse effects of nonprescription agents is generally inadequate. Safety data are also needed for the broad array of herbs and botanicals used to treat menopausal symptoms.

Table 105 Summary of long-term effects of nonhormone therapy preparations

Outcome | Risk | Treatment vs. Placebo | Strength of Evidence
Breast cancer | — | Vitamin E | High
Breast cancer | | SSRI | Insufficient
Colorectal cancer | — | Vitamin E | High
Cardiovascular events | — | Vitamin E | High
Cardiovascular death | ⬇ | Vitamin E | Low
Osteoporotic fractures | ⬆ | SSRI | Low
Osteoporotic fractures | | Isoflavones | Insufficient
Ovarian cancer | | Vitamin E | Insufficient

Risk: ⬆ increased, ⬇ decreased, — no change

SSRI: selective serotonin reuptake inhibitor

There are several further limitations to this evidence to consider. Many studies included women of all ages and therefore were excluded unless subgroup analyses on older women or menopausal women were specified. Much of the research available on the long-term effects of isoflavones and vitamin E consisted of population-based dietary studies and therefore did not meet inclusion criteria. Intermediate outcomes were reported in many of the studies. For example, bone density rather than osteoporotic fractures, and cholesterol rather than cardiovascular events. Finally, in studies that included all women rather than focusing on menopausal women, it was difficult to discern if exposure (to SSRI/SNRIs, isoflavones) occurred during menopausal years.

## Symptom Relief in Subgroups

A small subset of trials identified for Key Question 1 reported subgroup analyses on symptom relief: 10 for hormone therapies, two nonhormone prescription therapies, and four nonprescription therapies. Trials with hormone therapies included analyses by age, severity of symptoms, time since menopause, and uterine status. One trial of a nonhormone prescription therapy (escitalopram) provided a subgroup analysis by race. Trials with nonprescription therapies reported outcomes by age, BMI, severity of symptoms, and time since menopause. For example, age group subpopulations were defined as younger than 50, 50-59, and 60 years and older in one trial and younger than 55 and 55 years or older in another trial. None of the subgroup analyses could be pooled, as no two trials had the same comparators, definitions of subgroups, and outcomes. The limited evidence did not allow rating strength of evidence.

## Research Gaps

The principal gaps in the evidence on symptom relief include the following: lack of common validated instruments and assessing meaningful clinical improvement, safety data on nonprescription agents, lack of evidence on compounded hormone therapies, potential for predicting treatment response, and independence of outcomes:

- The trials comprising the body of evidence included in this review had in common the evaluation of outcomes on continuous scales using multiple instruments. A standard set of common data elements using validated instruments would facilitate evidence synthesis and interpreting results across trials. In place of, or in addition to, summary continuous effect measures, reporting differences in proportions of women achieving defined clinically meaningful improvements would be more informative for decisionmaking. Reporting only summaries of continuous effect measures challenges interpretation for patients and providers.
- A large number of nonprescription agents were studied. The Dietary Supplement Health and Education Act requires manufacturers of these agents to determine their products’ safety and efficacy, but the manufacturers are not required to submit the safety or efficacy data to the FDA. As women may elect to use these agents, the data need to become available.
- Millions of women use compounded hormone treatments. Yet there is a stark absence of evidence concerning compounded hormone therapies, and the methods used to determine the personalized dosages. Although the gap is most concerning regarding safety, efficacy issues are important as well.
- For nonhormonal interventions where there is moderate evidence of efficacy, identifying predictors of response would likely be helpful.
- As noted previously, although we considered six categories of symptom relief outcomes, the extent of correlated response (not symptom presence) among them was unclear in the evidence. Although not an objective of this review, the evidence would provide little opportunity to examine that question.

Many important previous gaps in the evidence concerning long-term effects of hormone therapies have been filled. For some nonhormone therapies (Table 105), with reasonable certainty (i.e., moderate or greater strength of evidence) significant safety issues have not been apparent; the same cannot be said for the entirety of the nonprescription agents.

Finally, estrogen therapy has efficacy relieving many symptoms but is accompanied by other potentially important harms (varying according to whether combined with progestogen). Given the number of outcomes to consider with different exposure effects (e.g., duration of use); the overall risk-benefit calculus is not simple. Juxtaposing evidence concerning symptom relief (as obtained here) with models for the long-term harms and effect on osteoporosis374 according to patient characteristics (e.g., lower risk of hip fracture in blacks) could facilitate informed decisions by women and health-care providers.

## Implications for Clinical and Policy Decisionmaking

The implications of this review for clinical decision-making follow from better defining evidence supporting the multiple treatment options, each having different potential harms, for different yet overlapping menopausal symptoms. The results provide a guide to comparative efficacy alongside potential long-term benefits and harms; all are weighed in clinical decisions. Possibly most useful, for vasomotor symptoms and quality of life, the review provides clinicians with a simple ranked efficacy comparison for the most commonly used treatments. Although evidence concerning potential long-term benefits are included as they are part of the decision-making process, this review did not address use of therapies for those purposes.

From the policy perspective, there are two salient issues to consider. First, a 2007 Senate hearing concluded that there is a lack of evidence from well-designed scientific trials on the safety and efficacy of compounded hormone therapies. Yet no evidence on compounded hormones has appeared since the hearing. Efforts to address that absence are important. Second, is to clearly define and communicate, and translate when necessary, the net clinical benefits of hormone treatments according to duration of therapy when initiated for symptom relief (as many organizations have worked towards). Effective tools disseminating evidence to facilitate shared decision making in the most decision-informative could be considered.

## Limitations of the Comparative Effectiveness Review Process

This review was a large undertaking. The variable manner in which trials reported results, multiple trial arms, multiple treatments, along with the goal of not excluding results for any a priori potentially arbitrary reason (e.g., reporting outcomes using a particular metric, or reported mean change and standard deviation) required abstracting, verifying, and managing a large amount of data for KQ1. Obtaining standardized effects is challenging.57 A number of steps is required to calculate effect magnitudes often for more than one trial arm. There are multiple ways to obtain an effect measure and standard deviation for each trial arm. Unbiased ANCOVA effect estimates77, 375 were rarely reported requiring the use of other comparisons. Furthermore, given multiple trial arms and multiple outcomes, the number of calculations required was substantial. We stipulated an approach to perform those calculations, but judgment was still required. Confidence intervals and strength of evidence ratings do not incorporate this analytical uncertainty. Whether type I error rates imposed should be higher is difficult to ascertain. What is clear, however, is that pooled estimates should be interpreted with this understanding. Finally, the analyses included network and many standard pairwise meta-analyses. Network meta-analyses are not trivial undertakings.

Analyses of the multiple treatments required some classification scheme that has limitations. For example, the estrogen dose categorization scheme did not consider progestin, or distinguish between combined and sequential progestin administration. Progestin use was problematic to separate because trials may have not given to women without a uterus, yet reported an effect for the entire sample.

Interpreting network and pairwise meta-analyses deserves comment. In the pairwise meta-analyses, only direct randomized comparisons are included; the network analyses incorporate both direct and indirect evidence. Underlying the network of comparisons is assumed similarity of study characteristics and patients (transitivity) as well consistency of effects throughout the network. All enrolled women were menopausal or perimenopausal, but there were some differences in studies and samples as noted in the review. However, across all studies the assumption was likely satisfied. The closeness of most network and pairwise estimates shows that discrepancies or inconsistencies are likely small.

Finally, breast cancer patients were excluded from this review. There were two primary reasons to exclude women with breast cancer: (1) issues of comparability and exchangeability (estrogens being contraindicated), and (2) scope and quantity of literature.

## Conclusions

Women experiencing symptoms of menopause can consider a number of potential treatments of varying efficacy. From a large body of evidence, there is considerable certainty that estrogens are the most effective relieving vasomotor symptoms and are accompanied by the greatest improvement in quality-of-life measures. For other common symptoms—psychological, urogenital, and sleep disturbance—although estrogens are effective, some nonhormonal agents compare favorably. Estrogens are accompanied by potential long-term harms that require considering. There is limited evidence on the potential consequences of long-term use of nonhormonal agents when those agents are used to treat menopausal symptoms.