# Completed Clinical Trials From ClinicalTrials.gov

The following clinical trials are reported as complete, but no data or related publications could be found.

Table O Completed clinical trials from ClinicalTrials.gov

Trial | Status | Last Updated | Posted Study Results | N | Treatments | Duration | Estimated Study Completion Date
NCT00010712 | Completed | 8/17/2006 | No | - | black cohosh | 52 weeks | Jul-05
NCT00775242 | Completed | 8/21/2009 | No | 103 | estradiol and progesterone injection | 26 weeks? | Nov-08
NCT00141570 | Completed | 1/29/2009 | No | 350 | esterified estrogens and methyltestosterone | 12 weeks | -
NCT00195455 | Completed | 12/17/2007 | No | 133 | trimegestone estradiol | - | Mar-07
NCT00272935 | Completed | 1/8/2010 | No | 400 | cenestin placebo | 12 weeks | May-07
NCT00604825 | Completed | 10/13/2011 | No | 359 | premarin placebo | 12 weeks | Jul-08
NCT00141557 | Terminated (lack of enrollment) | 4/10/2008 | No | 133 | esterified estrogens and methyltestosterone esterified estrogens | 12 weeks | Mar-08
NCT00494208^a^ | Completed | 5/12/2010 | No | 270 | testosterone | 60 weeks | Dec-09
NCT00338312 | Completed | 3/22/2010 | No | 610 | placebo testosterone | 52 weeks | Jul-06
NCT00511953 | Completed | 6/6/2011 | No | 108 | gabapentin placebo | 13 weeks | Dec-07

a Results were published subsequent to our last literature search in January 2014.